# Acknowledgments

We would like to thank the people who worked on the abstractions themselves including: Tyler Bailey; Jesse Botker; Kevin Bozic, MD; Kevin Broder; Gideon Burstein, MD; Jason J. Caron; Stephanie Cintora; Todd Gengerke; Brad Hilger; Richard Iorio, MD; Craig Israelite, MD; William Macaulay, MD; Charles Nelson, MD; and Alexander W. Stricker III. We also wish to thank William M. Woodhouse for his role as data manager and Krystal Wiesenberg for data entry. Marilyn Eells was responsible for editing and formatting the report.