# Results

## Baseline Characteristics of Patients

The 62 studies that had pre- and post-functional data using one of the four established outcome measures (ie, the Knee Society score, the Hospital for Special Surgery score, the WOMAC, or the SF-36) are summarized in Appendix F, Evidence Table 1. All were simple pre- and post-comparisons. Although various demographic information is provided to describe the sample, that data were rarely and inconsistently used in the reported analyses.

Table 3 presents a summary of selected patient and clinical characteristics. We used the full sample from each study whenever possible. Because of the variation in reporting practices here and elsewhere, the mean rates were calculated using means weighted separately on the basis of the numbers of knees and patients in the studies. The data here used weights for numbers of patients and knees, as well as the raw averages. The weightings made little difference. Two studies did not report the numbers of patients. The discrepancy between the numbers of patients and knees reported is an artifact of which studies reported knees.

Table 3. Descriptive statistics on 62 studies

Patent Characteristics | Average | SD | Number of Studies Reporting
Mean Age (years)
Average | 67.5 | 4.4 | 57
Weighted by patients | 69.1 | | 50
Weighted by knees | 69.2 | | 56
Percent Female
Average | 65.4 | 17 | 47
Weighted by patients | 64.6 | | 41
Weighted by knees | 64.5 | | 47
Percent Obese (BMI >30)
Average | 36.7 | 3.5 | 3*
Weighted by patients | 37.7 | | 3
Weighted by knees | 37.3 | | 3
Percent Osteoarthritis
Average | 86.8 | 13 | 45
Weighted by patients | 86.7 | | 40
Weighted by knees | 85.6 | | 43

* One study of all obese patients not included

The average age of patients was approximately 75 years. Very few were over 85; about two-thirds were female; about one-third were considered obese (using a criterion of a Body Mass Index (BMI) of 30 or higher). Nearly 90 percent of patients had osteoarthritis. One-third of subjects underwent bilateral TKA. None of the studies provided information regarding racial/ethnic status. We did not separately address outcomes for patients undergoingbilateral TKAs from those undergoing unilateral procedures. However, we conducted separate analyses by numbers of knees and numbers of patients.

The most commonly used functional measures were the Knee Society score and the Hospital for Special Surgery scale. A major factor in their greater usage is likely the fact that they have existed longer. The WOMAC Arthritis Scale is considered by many in the field to be a psychometrically better measure, but it has only been used since 1991.^8^ The physical function component of the SF-36 is a generic functional outcomes measure, not specific to knees.

Table 4 presents the summary data on the mean duration of study followup periods according to the type of functional outcome assessment scale used. The results are shown using various approaches to weighting the numbers of cases used. They were weighted separately by the numbers of patients and the numbers of knees. Because there is substantial sample loss, we then divided each of these categories to weight by the numbers at baseline and at followup. Several studies used more than one scale. In comparison to the demographic data cited above, there is greater variation when the different weights are applied. When weighting by numbers of patients, the generic measure (the SF-36) was used for shorter followup periods. In general, determining the sample sizes at different points in time was difficult. A substantial number of studies failed to provide adequate data to identify how many patients (or knees) were available at followup.

Table 4. Mean followup duration according to functional assessment scale (in months)

| Number of Studies | Mean Weighted Followup Time (months)
| | Baseline Patients | Followup Patients | Baseline Knees | Followup Knees
KS | 46 | 66.2 | 79.3 | 89.8 | 65.7
HSS | 24 | 66.9 | 63.0 | 61.2 | 61.4
WOMAC | 8 | 44.5 | 68.1 | 67.7 | 72.7
SF-36 | 9 | 18.0 | 23.6 | 59.2 | 61.6

The longer established measure KS score is associated with longer followup periods, perhaps because it was in use earlier, allowing more time to elapse for such followup. For example, weighting for baseline patients the mean followup for KS and HSS is 66 and 67 months, compared to 45 months for WOMAC. However, weighting for baseline knees, KS has a mean followup of 90 months and WOMAC is 68 months, but HSS is only 61 months. The longest mean followup time was 90 months (KS score weighted for baseline knees), well less than the ten years that has been suggested in order to evaluate long term functional results. Only ten studies had followup time of at least ten years.

Note: Appendixes and evidence tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/epcindex.htm

Some information on attrition rate was reported for 49 studies. Of these the median percentage of subjects lost to followup was 2%, the range was 0–28%. In five studies more than 10% were lost to followup. If death and other exclusions are added to the definition, the range increases to 0–56% with a median of 12%. Five studies had a total loss rate of more than 40%; another five lost 30–40%; and another seven studies lost 20–30%

The issues of outcomes addressed here looked at only the aggregate outcome in the context of having had a TKA. No special efforts were made to distinguish the relative contribution of rehabilitation or type of procedure. Although the latter was the major focus of many studies, few actually compared alternative approaches.

## What is the Magnitude of Effect of Primary TKA?

Table 5 summarizes the raw data on change from pre- to post-TKA functional scores (albeit with widely varying followup periods). In each scale the range has been defined as 0–100. In general, a higher score is better, although the WOMAC was standardized such that a lower score is better. In each case there is strong evidence of improved function (and decreased pain). Of the 46 studies using KS scores only 30 provided pre- and post-intervention results according to the number of subjects enrolled (n = 12,261 subjects) (27 provided this information based on number of knees (n = 15,454 knees). There were 17 studies using HSS scores (2,546 patients) Seven studies, representing 2,925 patients reported results with the WOMAC.

Table 5. Weighted baseline and followup scores for TKA outcomes measures

Outcome Measure | Number of Studies Reporting Pre/post Scores Based on Number of Subjects | Baseline Score Based on Number of Subjects | Followup Score Based on Number of Subjects | Number of Studies Reporting Pre/post Scores Based on Number of Knees | Baseline Score Based on Number of Knees | Followup Score Based on Number of Knees
Knee Society (KS) | 30 / 7* (n=12,261) | 39.8 | 80.0 | 27 / 5** (n=15,454) | 41.1 | 82.4
Hospital for Special Surgery (HSS) | 17 / 3* (n=2,546) | 54.2 | 89.2 | 16 / 2** (n=3,333) | 52.8 | 88.7
Western Ontario and McMaster Osteoarthritis Index (WOMAC) | 7 (n=2,925) | 48.3 | 76.8 | NA †
SF-36 physical function | 8 / 7* (n=2,166) | 27.6 | 43.8 | 2 / 1** | 22.4 | 47.1

* subjects only

** knees only

†1 study only

Table 6 shows the mean scores at baseline and followup for each of the four major scales, organized by length of followup, analyzed in terms of patients; Table 7 shows the same data analyzed by knees. Baseline scores were highest in studies using the HSS and lowest in studies using the KS. This may reflect differences in severity of pain and function among subjects enrolled in these studies. HSS scores improved by about the same order of magnitude for each followup period; baseline scores were in the mid 50s and followup scores were in the high 80s and low 90s. The same general pattern applied to the KS scores but the results were a little less dramatic. The baseline values were in the high 30s and low 40s and the mean followup scores were high 70s and low 80s. The WOMAC scores showed more variation; the studies addressing followup at less than five years showed baseline mean values in the high 40s and followup values in the 70s, but the single study with more than five years of followup showed a mean baseline of 58.2 and a followup mean score of 98.4. The SF-36 mean functional scores increased from the mid-20s to the mid 40s, a level that still shows substantial limitations. Although there is no formal basis for translating the size of a change in the scores, the generally accepted rule of thumb for the KS and HSS scales is that a score of less than 60 is considered poor; 60–69 represents a fair results; 70–84 is considered a good results; 85–100 is considered an excellent result.

Table 6. Functional outcomes by measure and followup interval based on number of subjects

Study | Scale | Group | Base Score | n | SD | Followup Score | n | SD | Followup in Years
HSS / patients
0–2 years
Ververli et al., 1995^52^ | HSS | Group 1 | 63.5 | 42 | 10.7 | 84.5 | 42 | 12.1 | 2
| | Group 2 | 65 | 41 | 9.5 | 81.3 | 41 | 11.1
Worland et al., 1998^53^ | HSS | Continuous passive machine | 62.9 | 37 | 7 | 95.3 | 37 | 2.8 | 0.5
| HSS | Physical therapy | 61.7 | 43 | 10 | 95.7 | 43 | 3
| | | | 163 | | | 163
| | | | MEAN=63.3 | | | MEAN=89.1
2.1–5 years
Hasegawa et al., 2002^54^ | HSS | With heterotopic ossification | 48 | 9 | 16 | 91 | 9 | 7 | 3
| HSS | Without heterotopic ossification | 48 | 131 | 14 | 93 | 131 | 6
Hsu et al., 1998^55^ | HSS | | 64 | 113 | 13.2 | 90 | 113 | 10.2 | 4.8
Larson et al., 2001^56^ | HSS | | 58 | 82 | 10.25 | 89 | 82 | 8.75 | 4
Liu & Chen, 1998^57^ | HSS | Group 1 | 42 | 64 | 9.58 | 84.1 | 64 | 4.81 | 2
| | Group 2 | 47.4 | 24 | 11.7 | 85.3 | 24 | 4.51
Moskal & Diduch, 1998^58^ | HSS | | 48 | 514 | 15 | 89 | 488 | 22.25 | 4.3
Pereira et al., 1998^59^ | HSS | PCL sacrificing | 51.12 | 67 | NR | 92.16 | 67 | NR | 3
| | PCLsparing | 56.08 | 40 | NR | 90.2 | 40 | NR
Rand & Gustilo, 1996^60^ | HSS | | 59 | 182 | 10 | 88 | 182 | 8 | 2.3
| | | | 1226 | | | 1200
| | | | MEAN=51.9 | | | MEAN=89.3
>5 years
Diduch et al., 1997^61^ | HSS | | 55 | 88 | 11 | 92 | 80 | 6 | 8
Evanich et al., 1997^62^ | HSS | | 58 | 251 | NR | 98 | 169 | NR | 7.6
Healy et al., 2002^63^ | HSS | 1992 | 57.68 | 56 | 11 | 86.92 | 56 | 10.5 | 5,8 years
| HSS | 1995 | 60.64 | 103 | 15 | 88.06 | 103 | 9.25
Ikejiani et al., 2000^64^ | HSS | With patellar resurfacing | 56 | 45 | 13.4 | 91 | 45 | 7.4 | 6.5
| | Without patellar resurfacing | 54.8 | 140 | 12.7 | 89.1 | 140 | 9.5
Malkani et al., 1995^65^ | HSS | | 55 | 118 | 12 | 81 | 84 | 9 | 10
O'Rourke et al., 2002^66^ | HSS | Modular tibial component | 59 | 106 | 12 | 87 | 92 | 9.5 | 6.4
| | All polyethylene tibial components | 71 | 28 | 9.25 | 87 | 22 | 5
Regner et al., 1997^67^ | HSS | | 42 | 120 | 10 | 82 | 103 | 10 | 6.8
Schroder et al., 2001^68^ | HSS | | 52 | 102 | 12 | 91 | 52 | 8 | 10
| | | | 1157 | | | 946
| | | | MEAN=55.4 | | | MEAN=89.1
KS / patients
0–2 years
Bert et al., 2001^69^ | KS | KS | 41 | 264 | 15 | 85 | 90 | 16 | 1
| | Function | 45 | 264 | 17 | 71 | 90 | 19
Bourne et al., 1995^70^ | KS clinical | Patella resurfaced | 37 | 50 | 15 | 81 | 50 | 15 | 2
| | Patella not resurfaced | 41 | 50 | 14 | 87 | 50 | 8
| KS function | Patella resurfaced | 41 | 50 | 13 | 67 | 50 | 26
| | Patella not resurfaced | 44 | 50 | 13 | 76 | 50 | 19
Cohen et al., 1997^71^ | KS | Unilateral group | 55 | 100 | NR | 87 | 100 | NR | 0.5
| | Bilateral group | 53 | 86 | NR | 89 | 86 | NR
Deshmukh et al., 2002^27^ | KS | KS score | 23 | 177 | 16 | 79 | 130 | 19 | 1
| | KS function | 42 | 177 | 17 | 63 | 130 | 24
Heck et al., 1998^72^ | KS | KS score | 34.7 | 291 | 22.2 | 68.4 | 268 | 19.6 | 2
| | KS function | 41.2 | 291 | 18.8 | 69 | 268 | 26.2
Lin et al., 2002^73^ | KS score | Preclinical pathway | 43 | 53 | 12.54 | 93.5 | 36 | 4.77 | 2
| | Clinical pathway | 40.56 | 69 | 16.86 | 93.68 | 42 | 2.71
| KS function | Preclinical pathway | 34.14 | 53 | 22.76 | 84.72 | 36 | 9.47
| | Clinical pathway | 46.67 | 69 | 13.18 | 84.21 | 42 | 10.71
Matsueda & Gustilo, 2000^74^ | KS score | Parapatellar | 52 | 143 | 18.5 | 90 | 143 | 10 | 0.5
| | Subvastus | 51 | 148 | 15.25 | 90 | 148 | 12.5
| KS/ function | Parapatellar | 46 | 143 | 20 | 74 | 143 | 17.5
| | Subvastus | 47 | 148 | 17.5 | 75 | 148 | 17.5
| | | | 2676 | | | 2100
| | | | MEAN=42.3 | | | MEAN=77.6
2.1–5 years
Bullens et al., 2001^75^ | KS | | 32.9 | 108 | 16.3 | 83.5 | 86 | 12.9 | 4.9
Elke et al.,1995^76^ | KS score | OA | 30 | 300 | | 87 | 187
| | RA | 21 | 43 | | 77 | 27
| KS function | OA | 50 | 300 | | 65 | 187
| | RA | 40 | 43 | | 67 | 27
Jenny & Jenny, 1998^77^ | KS score | ACL replacing | 50 | 32 | 12 | 89 | 32 | 11 | 2.5
| | ACL retaining | 41 | 93 | 16 | 90 | 93 | 11
| KS function | ACL retaining | 41 | 32 | 20 | 80 | 32 | 13
| | ACL replacing | 38 | 93 | 23 | 79 | 93 | 21
Konig et al., 1998^30^ | KS score | | 28.7 | 249 | NR | 82.3 | 249 | NR | 3.3
Meding et al., 2001^78^ | KS score | | 37.3 | 1888 | NR | 84 | 1888 | NR | 2.5
| KS function | | 42.9 | 1888 | NR | 78 | 1888 | NR
Ranawat et al., 1997^79^ | KS score | | 44 | 118 | 15 | 93 | 96 | 10.75 | 4.9
| KS function | | 40 | 118 | 17.5 | 78 | 96 | 25
Rand & Gustilo, 1996^60^ | KS/pain | | 40 | 195 | 15 | 89 | 182 | 11 | 2.3
| KS function | | 46 | 195 | 17 | 81 | 182 | 20
Rodriguez et al., 1996^80^ | KS score | | 28 | 99 | NR | 55 | 67 | NR | 4.3
Yang et al., 2001^81^ | KS score | | 37 | 86 | 13.5 | 79 | 86 | 11 | 3
| KS function | | 44 | 86 | 16.25 | 64 | 86 | 14.25
| | | | 5966 | | | 5584
| | | | MEAN=37.2 | | | MEAN=80.6
>5 years
Brown et al., 2001^82^ | KS | Symmetric | 51 | 250 | 12 | 90 | 250 | 12 | 6.4
| | Asymmetric | 54 | 18 | 14 | 91 | 18 | 10
Clouter et al., 2001^83^ | KS | KS score | 33 | 130 | 10 | 90.7 | 89 | 8.5 | 10
| | KS function | 44 | 130 | 16 | 82 | 89 | 21
Duffy et al., 1998^84^ | KS score | Cement | 32 | 47 | 17.9 | 92.4 | 47 | 8.2 | 10
| | Cementless | 33 | 46 | 18.9 | 87.8 | 46 | 13.8
| KS/ function | Cement | 45.4 | 47 | 22.4 | 72.4 | 47 | 25.9
| | Cementless | 52.3 | 46 | 20.7 | 66.3 | 46 | 29.1
Ewald et al., 1999^85^ | KS score | | 42 | 180 | NR | 82 | 180 | NR | 10 to 14
| KS function | | 37 | 180 | NR | 68 | 180 | NR
Gill et al., 1999^86^ | KS score | | 39 | 223 | 17 | 90 | 223 | 25 | 16.8
| KS function | | 44 | 223 | 20 | 58 | 223 | 25
Healy et al., 2002^63^ | KS score | 1995 | 51.58 | 103 | 23.25 | 92.11 | 103 | 10 | 5,8
| | 1992 | 43.61 | 56 | 15.25 | 90.75 | 56 | 13.75
| KS function | 1995 | 49.9 | 103 | 25 | 75.11 | 103 | 20
| | 1992 | 45.18 | 56 | 20 | 74.69 | 56 | 25
Indelli et al., 2002^87^ | KS score | | 41 | 91 | 18 | 94 | 85 | 11 | 7.5
| KS function | | 48 | 91 | 24 | 79 | 85 | 18
Martin et al., 1997^88^ | KS score | | 28 | 231 | 19.2 | 88 | 231 | 7.6 | 6.5
| KS function | | 49 | 231 | NR | 72 | 231 | NR
Miyasaka et al., 1997^89^ | KS score | | 28.1 | 83 | 14.7 | 88.7 | 46 | 9.7 | 14
| KS function | | 30.2 | 83 | 22.2 | 69.2 | 46 | 28.6
Mokris et al., 1997^90^ | KS/pain | | 50 | 90 | 16.75 | 97 | 90 | 8.25 | 4.25
| KS function | | 41 | 90 | 18.75 | 88 | 90 | 15
Mont et al., 1999^91^ | KS score | | 52 | 101 | 13 | 94 | 101 | 8.5 | 5.4
| KS function | | 42 | 101 | 20 | 70 | 101 | 25
O'Rourke et al., 2002^66^ | KS score | Modular tibial component | 30 | 106 | 15 | 85 | 92 | 15.25 | 6.4
| | All polyethylene tibial component | 34 | 28 | 13 | 87 | 22 | 11.5
| KS function | Modular tibial component | 50 | 106 | 17.5 | 79 | 92 | 17.5
| | All polyethylene tibial component | 64 | 28 | 11.25 | 79 | 22 | 17.5
Rinta-Kiikka et al., 1996^92^ | KS score | | 48.5 | 97 | NR | 76.9 | 89 | NR | 5.3
| KS function | | 42.6 | 97 | NR | 64.2 | 89 | NR
Sextro et al., 2001^93^ | KS score | | 32.8 | 61 | 16 | 87.9 | 50 | 14.2 | 15.7
| KS function | | 48.7 | 66 | 16.5 | 51.3 | 50 | 32.9
| | | | 3619 | | | 3368
| | | | MEAN=42.3 | | | MEAN=80.5
WOMAC / patients
0–2 years
Bachmeier et al., 2001^94^ | WOMAC | Physical function | 38.3 | 108 | | 54.8 | 48 | | 0.8
Fortin et al., 1999^28^ | WOMAC function | High function | 24.3 | 59 | | 39.1 | 59 | | 0.5
| | Low function | 44.2 | 47 | | 65.4 | 47
Beaupre et al., 2001^95^ | WOMAC | Slider board pain | 46 | 40 | 13 | 85 | 32 | 15 | 0.4
| | Continuous passive machine pain | 47 | 38 | 14 | 76 | 34 | 15
| | Control pain | 51 | 39 | 15 | 79 | 34 | 16
| | Slider board stiffness | 50 | 40 | 22 | 73 | 32 | 19
| | Continuous passive machine stiffness | 44 | 38 | 15 | 65 | 34 | 21
| | Control stiffness | 49 | 39 | 18 | 69 | 34 | 19
| | Slider board function | 41 | 40 | 13 | 81 | 32 | 15
| | Continuous passive machine function | 51 | 38 | 14 | 74 | 34 | 15
| | Control function | 53 | 39 | 15 | 77 | 34 | 18
Jones et al., 2001^96^ | WOMAC pain | <80 years | 44 | 221 | 18 | 78 | 221 | 19 | 0.5
| | ≥80 years | 41 | 35 | 16 | 73 | 35 | 20
| WOMAC function | <80 years | 43 | 221 | 18 | 72 | 221 | 18
| | ≥80 years | 38 | 35 | 12 | 66 | 35 | 17
| WOMAC stiffness | <80 years | 39 | 221 | 21 | 64 | 221 | 22
| | ≥80 years | 43 | 35 | 21 | 65 | 35 | 23
Stickles et al., 2001^97^ | WOMAC | Body Mass Index <25 | 57 | 146 | NR | 77.5 | 146 | NR | 1
| | 25–30 | 53.7 | 304 | NR | 77.1 | 304 | NR
| | 30–35 | 49.9 | 271 | NR | 73 | 271 | NR
| | 35–40 | 46.8 | 149 | NR | 72.1 | 149 | NR
| | >40 | 46.9 | 92 | NR | 73.6 | 92 | NR
| | | | 2295 | | | 2184
| | | | MEAN=46.2 | | | MEAN=71.9
2.1–5 years
Clark et al., 2001^98^ | WOMAC | Posterior stabilized | 50.4 | 76 | | 78 | 57 | | 3
| | Cruciate retaining | 47.2 | 67 | | 75.9 | 51
| | | | 143 | | | 108
| | | | MEAN=48.9 | | | MEAN=77.0
>5 years
Hawker et al., 1998^29^ | | | 58.2 | 487 | | 98.4 | 487
| | | | MEAN=58.2 | | | MEAN=98.4
SF-36 / patients
0–2 years
Bachmeier et al., 2001^94^ | SF-36/ physical function | | 25.2 | 108 | 17.2 | 49.7 | 45 | 27 | 0.8
Beaupre et al., 2001^95^ | SF-36/ physical function | Slider board | 31 | 40 | 19 | 53 | 32 | 24 | 0.4
| | Continuus passive machine | 31 | 39 | 15 | 46 | 36 | 20
| | Control | 31 | 40 | 22 | 55 | 34 | 27
Bert et al., 2000^99^ | SF-36/ physical function | | 29 | 254 | 7 | 41 | 158 | 11 | 1
Fortin et al., 1999^28^ | SF-36/ physical function | High function | 37.3 | 59 | 22.2 | 63 | 59 | 25 | 0.5
| | Low function | 14.9 | 47 | 12.2 | 47 | 47 | 26.8
Heck et al., 1998^72^ | SF-36/ physical function | | 24.2 | 291 | 17.01 | 50.9 | 268 | 26.2 | 2
Jones et al., 2001^96^ | SF-36/ physical function | <80 age | 21 | 221 | 18 | 47 | 221 | 25 | 0.5
| | ≥80 age | 17 | 35 | 17 | 35 | 35 | 23
Kiebzak et al., 2002^100^ | SF-36/ physical function | | 27 | 70 | NR | 50 | 70 | NR | 2
Stickles et al., 2001^97^ | SF-36/ physical function | Body Mss Index <25 | 32.2 | 146 | NR | 40.2 | 146 | NR | 1
| | 25–30 | 30.7 | 304 | NR | 40 | 304 | NR
| | 30–35 | 30 | 271 | NR | 38.3 | 271 | NR
| | 35–40 | 27.8 | 149 | NR | 37.3 | 149 | NR
| | >40 | 28.1 | 92 | NR | 37.9 | 92 | NR
| | | | 2166 | | | 1967
| | | | MEAN=27.58 | | | MEAN=43.76

Table 7. Functional outcomes by measure and followup interval based on number of knees

| Study | Scale | Group | Base Score | Number of Knees | SD | Followup Score | Number of Knees | SD | Followup Years
HSS / KNEES 0–2 years
| Worland et al., 1998^53^ | HSS | Continous passive motion | 62.9 | 49 | 7 | 95.3 | 49 | 2.8 | 0.5
| | | Physical therapy | 61.7 | 54 | 10 | 95.7 | 54 | 3
| | | | TOTALS | 103 | | | 103
| | | | | MEAN=62.3 | | | MEAN=95.5
2.1–5 years
| Baldwin & Rubinstein, 1996^101^ | HSS | Group A | 55 | 272 | NR | 90 | 272 | NR | 4
| | | Group B | 48 | 74 | NR | 87 | 74 | NR
| Liu & Chen, 1998^57^ | HSS | Group 1 | 42 | 128 | 9.58 | 84.1 | 128 | 4.81 | 2.6
| | | Group 2 | 47.4 | 48 | 11.7 | 85.3 | 48 | 4.51
| Hsu et al., 1998^55^ | HSS | | 64 | 140 | 13.2 | 90 | 140 | 10.2 | 4.8
| Larson et al., 2001^56^ | HSS | | 58 | 118 | 10.25 | 89 | 118 | 8.75 | 4
| Moskal & Diduch, 1998^58^ | HSS | | 48 | 646 | 15 | 89 | 617 | 22.25 | 4.3
| Pereira et al., 1998^59^ | HSS | PCL sacrificing | 51.12 | 93 | NR | 92.16 | 93 | NR | 3
| | | PCL sparing | 56.08 | 50 | NR | 90.2 | 50 | NR
| Rand & Gustilo, 1996^60^ | HSS | | 59 | 251 | 10 | 88 | 251 | 8 | 2.3
| | | | TOTALS | 1820 | | | 1791
| | | | | MEAN=52.4 | | | MEAN=88.8
> 5 years
| Diduch et al., 1997^61^ | HSS | | 55 | 114 | 11 | 92 | 103 | 6 | 18
| Harwin, 1998^102^ | HSS | OA | 49 | 241 | 6 | 93 | 241 | 10 | 5.1
| | | RA | 42 | 109 | 8 | 84 | 109 | 10
| Ikejiani et al., 2000^64^ | HSS | Patellar resurfacing | 56 | 45 | 13.4 | 91 | 45 | 7.4 | 6.5
| | | without patellar resurfacing | 54.8 | 140 | 12.7 | 89.1 | 140 | 9.5
| Malkani et al., 1995^65^ | HSS | | 55 | 168 | 12 | 81 | 119 | 9 | 10
| O'Rourke et al., 2002^66^ | HSS | Modular tibial component | 59 | 145 | 12 | 87 | 128 | 9.5 | 6.4
| | | All-polyethylene tibial component | 71 | 31 | 9.25 | 87 | 25 | 5
| Regner et al., 1997^67^ | HSS | | 42 | 144 | 10 | 82 | 106 | 10 | 6.8
| Schroder et al., 2001^68^ | HSS | | 52 | 114 | 12 | 91 | 58 | 8 | 10
| Healy et al., 2002^63^ | HSS | 1992 | 57.68 | 56 | 11 | 86.92 | 56 | 10.5 | 5,8 years
| | HSS | 1995 | 60.64 | 103 | 15 | 88.06 | 103 | 9.25
| | | | TOTALS | 1410 | | | 1233
| | | | | MEAN=52.7 | | | MEAN=88.0
KS 0–2 years
| Cohen et al., 1997^71^ | KS | Unilateral group | 55 | 172 | NR | 87 | 172 | NR | 0.5
| | | Bilateral group | 53 | 100 | NR | 89 | 100 | NR
| Matsueda & Gustilo, 2000^74^ | KS score | Parapatellar | 52 | 169 | 18.5 | 90 | 169 | 10 | 0.5
| | | Subvastus | 51 | 167 | 15.25 | 90 | 167 | 12.5
| | KS/function | Parapatellar | 46 | 169 | 20 | 74 | 169 | 17.5
| | | Subvastus | 47 | 167 | 17.5 | 75 | 167 | 17.5
| | | | TOTALS | 944 | | | 944
| | | | | MEAN=50.5 | | | MEAN=83.8
2.1–5 years
| Bullens et al., 2001^75^ | KS | | 32.9 | 126 | 16.3 | 83.5 | 100 | 12.9 | 4.9
| Gioe & Bowman, 2000^103^ | KS score | All-polyethylene tibial component | 38.1 | 103 | 15.4 | 84.3 | 103 | 14.2 | 4.1
| | | Metal-backed tibial component | 35.4 | 97 | 16.1 | 85.4 | 97 | 11.8
| | KS/function | All-polyethylene tibial component | 55.9 | 103 | 15.4 | 74.4 | 103 | 19.6
| | | Metal-backed tibial component | 57.2 | 97 | 17.2 | 72.1 | 97 | 22.1
| Hube et al., 2002^104^ | KS | | 52.3 | 297 | NR | 90.6 | 276 | 6.25 | 3
| Jenny & Jenny, 1998^77^ | KS score | ACL retaining | 50 | 32 | 12 | 89 | 32 | 11 | 2.5
| | | ACL replacing | 41 | 93 | 16 | 90 | 93 | 11
| | KS/function | ACL retaining | 41 | 32 | 20 | 80 | 32 | 13
| | | ACL retaining | 38 | 93 | 23 | 79 | 93 | 21
| Jordan et al., 1997^105^ | KS score | | 29 | 472 | 12.25 | 93 | 410 | 3.25 | 4.7
| | KS/function | | 34 | 472 | 11.25 | 92 | 410 | 22.5
| Konig et al., 1997^106^ | KS score | | 28.7 | 276 | NR | 82.3 | 276 | NR | 4.7
| Meding et al., 2001^78^ | KS score | | 37.3 | 2759 | NR | 84 | 2759 | NR | 2.5
| | KS/function | | 42.9 | 2759 | NR | 78 | 2759 | NR
| Mokris et al., 1997^90^ | KS/pain | | 50 | 105 | 16.75 | 97 | 105 | 8.25 | 4.25
| | KS/function | | 41 | 105 | 18.75 | 88 | 105 | 15
| Ranawat et al., 1997^79^ | KS score | | 44 | 150 | 15 | 93 | 125 | 10.75 | 4.9
| | KS/function | | 40 | 150 | 17.5 | 78 | 125 | 25
| Rand & Gustilo, 1996^60^ | KS/pain | | 40 | 277 | 15 | 89 | 251 | 11 | 2.3
| | KS/function | | 46 | 277 | 17 | 81 | 251 | 20
| Rodriguez et al., 1996^80^ | KS score | | 28 | 145 | NR | 55 | 104 | NR | 4.3
| Title et al., 2001^107^ | KS score | Total condylar prosthesis | 43.4 | 74 | NR | 95.4 | 74 | 3.5 | 4.3
| | | Press-fit condylar prosthesis | 44 | 74 | NR | 96.7 | 74 | 3.2
| | KS/function | Total condylar prosthesis | 31 | 74 | NR | 85.5 | 74 | 20.8
| | | Press-fit condylar prosthesis | 30.4 | 74 | NR | 92.2 | 74 | 19.5
| Yang et al., 2001^81^ | KS score | | 37 | 109 | 13.5 | 79 | 109 | 11 | 3
| | KS/function | | 44 | 109 | 16.25 | 64 | 109 | 14.25
| | | | TOTALS | 9534 | | | 9220
| | | | | MEAN=39.6 | | | MEAN=82.8
> 5 years
| Brown et al., 2001^82^ | KS | Symmetric | 51 | 500 | 12 | 90 | 500 | 12 | 6.4
| | | Asymmetric | 54 | 36 | 14 | 91 | 36 | 10
| Cloutier et al., 2001^83^ | KS | KS score | 33 | 163 | 10 | 90.7 | 163 | 8.5 | 10
| | | KS function | 44 | 107 | 16 | 82 | 107 | 21
| Duffy et al., 1998^84^ | KS score | Cemented | 32 | 51 | 17.9 | 92.4 | 51 | 8.2 | 10
| | | Cementless | 33 | 55 | 18.9 | 87.8 | 55 | 13.8
| | KS/function | Cemented | 45.4 | 51 | 22.4 | 72.4 | 51 | 25.9
| | | Cementless | 52.3 | 55 | 20.7 | 66.3 | 55 | 29.1
| Ewald et al., 1999^85^ | KS score | | 42 | 306 | NR | 82 | 306 | NR | >10
| | KS/function | | 37 | 306 | NR | 68 | 306 | NR
| Gill et al., 2001^86^ | KS score | | 39 | 254 | 17 | 90 | 254 | 25 | 16.8
| | KS/function | | 44 | 254 | 20 | 58 | 254 | 25
| Harwin, 1998^102^ | KS score | OA | 42 | 241 | 6.75 | 92 | 241 | 4.5 | 5.1
| | | RA | 32 | 109 | 8 | 86 | 109 | 5
| | KS/function | OS | 52 | 241 | 6.5 | 90 | 241 | 6.5
| | | RA | 28 | 109 | 11 | 68 | 109 | 7
| Indelli et al., 2002^87^ | KS score | | 41 | 100 | 18 | 94 | 92 | 11 | 7.5
| | KS/function | | 48 | 100 | 24 | 79 | 92 | 18
| Martin et al., 1997^88^ | KS score | | 28 | 306 | 19.2 | 88 | 306 | 7.6 | 6.5
| | KS/function | | 49 | 306 | NR | 72 | 306 | NR
| Miyasaka et al., 1997^89^ | KS score | | 28.1 | 108 | 14.7 | 88.7 | 60 | 9.7 | 14.1
| | KS/function | | 30.2 | 108 | 22.2 | 69.2 | 60 | 28.6
| Mont et al., 1999^91^ | KS score | | 52 | 118 | 13 | 94 | 118 | 8.5 | 5.4
| | KS/function | | 42 | 118 | 20 | 70 | 118 | 25
| O'Rourke, et al., 2002^66^ | KS score | Modular tibial component | 30 | 145 | 15 | 85 | 128 | 15.25 | 6.4
| | | All-polyethylene tibial component | 34 | 31 | 13 | 87 | 25 | 11.5
| | KS/function | Modular tibial component | 50 | 145 | 17.5 | 79 | 128 | 17.5
| | | All-polyethylene tibial component | 64 | 31 | 11.25 | 79 | 25 | 17.5
| Rinta-Kiikka et al., 1996^92^ | KS score | | 48.5 | 102 | NR | 76.9 | 100 | NR | 5.3
| | KS/function | | 42.6 | 102 | NR | 64.2 | 100 | NR
| | | | TOTALS | 4658 | | TOTALS | 4496
| | | | | MEAN=42.4 | | | MEAN=81.4
WOMAC No Studies
SF-36 0–2 years
| Jones et al., 2001^96^ | SF-36/ physical function | <80 years | 21 | 221 | 18 | 47 | 221 | 25 | 0.5
| | | ≥80 years | 17 | 35 | 17 | 35 | 35 | 23
| | | | TOTALS | 256 | | | 256
| | | | | MEAN=20.5 | | | MEAN=45.4
2.1–5 years
| Giow & Bowman, 2000^103^ | SF-36/ physical function | All-polyethylene tibial component | 25 | 103 | 36 | 45 | 103 | 47 | 4.1
| | | Metal-backed tibial component | 25 | 97 | 18 | 54 | 97 | 23
| | | | TOTALS | 200 | | | 200
| | | | | MEAN=25 | | | MEAN=49.4
> 5 years No Studies

Tables 8–11 display the effect size (defined as the number of standard deviations of change) for this same data. The functional scores after TKA are consistently higher. The mean effect size for the HSS studies is 3.91 for those with followup up to two years, 3.01 for those 2–5 years, and 2.97 for those studies with more than five years of followup. For the studies using KS scores the mean effect size is 2.35 for those 0–2 years, 2.73 for those 2–5 years, and 2.67 for those 5+ years. For WOMAC studies the mean effect size for 0–2 years of followup is 1.62. The more generic SF-36 scores had the smallest mean effect size; for the studies with 0–2 years of followup it was 1.27 (though this is still considered a “large effect size”). The effect size is considerably higher for those studies where the clinician reports the results compared to those where patient reports are used.

Table 9. Meta analysis for KS

(0–2 years)
| Citation | N1 | N2 | NTotal | Effect | Lower | Upper
| Bert et. al., 2000, 2001^69^ | 90 | 264 | 354 | 1.48 | 1.22 | 1.74
| Bert et. al., 2000, 2001 ^69^ | 90 | 264 | 354 | 2.88 | 2.56 | 3.20
| Bourne et. al., 1995^70^ | 50 | 50 | 100 | 2.91 | 2.34 | 3.49
| Bourne et. al., 1995^70^ | 50 | 50 | 100 | 4.00 | 3.31 | 4.70
| Bourne et. al., 1995^70^ | 19 | 50 | 69 | 1.12 | .55 | 1.69
| Bourne et. al., 1995^70^ | 26 | 50 | 76 | .83 | .33 | 1.33
| Deshmukh et. al., 2002^27^ | 130 | 177 | 307 | 1.03 | .79 | 1.28
| Deshmukh et. al., 2002^27^ | 130 | 177 | 307 | 3.22 | 2.88 | 3.57
| Heck et. al., 1998^72^ | 268 | 291 | 559 | 1.24 | 1.05 | 1.42
| Heck et. al., 1998^72^ | 268 | 291 | 559 | 1.56 | 1.37 | 1.75
| Lin et. al., 2002^73^ | 36 | 53 | 89 | 4.94 | 4.07 | 5.81
| Lin et. al., 2002^73^ | 42 | 69 | 111 | 3.92 | 3.26 | 4.58
| Lin et. al., 2002^73^ | 36 | 53 | 89 | 2.69 | 2.10 | 3.29
| Lin et. al., 2002^73^ | 42 | 69 | 111 | 2.99 | 2.43 | 3.55
| Matsueda & Gustilo, 2000^74^ | 148 | 148 | 296 | 1.60 | 1.33 | 1.86
| Matsueda & Gustilo, 2000^74^ | 143 | 143 | 286 | 2.55 | 2.23 | 2.86
| Matsueda & Gustilo, 2000^74^ | 148 | 148 | 296 | 2.78 | 2.46 | 3.11
| Matsueda & Gustilo, 2000^74^ | 143 | 143 | 286 | 1.49 | 1.22 | 1.75
Fixed | Combined (18) | 1859 | 2490 | 4349 | 1.85 | 1.77 | 1.92
Random | Combined (18) | 1859 | 2490 | 4349 | 2.35 | 1.95 | 2.76
(2–5 years)
| Citation | N1 | N2 | NTotal | Effect | Lower | Upper
| Bullens et. al., 2001^75^ | 86 | 108 | 194 | 3.41 | 2.96 | 3.86
| Jenny & Jenny, 1998^77^ | 32 | 32 | 64 | 3.35 | 2.56 | 4.14
| Jenny & Jenny, 1998^77^ | 32 | 32 | 64 | 2.28 | 1.63 | 2.93
| Jenny & Jenny, 1998^77^ | 93 | 93 | 186 | 1.85 | 1.51 | 2.20
| Jenny & Jenny, 1998^77^ | 93 | 93 | 186 | 3.55 | 3.09 | 4.02
| Ranawat et. al., 1997^79^ | 96 | 118 | 214 | 3.66 | 3.21 | 4.10
| Ranawat et. al., 1997^79^ | 96 | 118 | 214 | 1.79 | 1.47 | 2.11
| Rand & Gustilo, 1996^60^ | 182 | 195 | 377 | 1.89 | 1.64 | 2.13
| Rand & Gustilo, 1996^60^ | 182 | 195 | 377 | 3.70 | 3.36 | 4.03
| Yang et. al., 2001^81^ | 86 | 86 | 172 | 1.32 | .99 | 1.66
| Yang et. al., 2001^81^ | 86 | 86 | 172 | 3.40 | 2.92 | 3.87
Fixed | Combined (11) | 1064 | 1156 | 2220 | 2.47 | 2.35 | 2.58
Random | Combined (11) | 1064 | 1156 | 2220 | 2.73 | 2.16 | 3.30
(5 + years)
| Citation | N1 | N2 | NTotal | Effect | Lower | Upper
| Brown et. al., 2001^82^ | 18 | 18 | 36 | 2.97 | 1.96 | 3.99
| Brown et. al., 2001^82^ | 250 | 250 | 500 | 3.25 | 2.98 | 3.51
| Cloutier et. al., 2001^83^ | 89 | 130 | 219 | 6.14 | 5.49 | 6.78
| Cloutier et. al., 2001^83^ | 89 | 130 | 219 | 2.08 | 1.75 | 2.42
| Duffy et. al., 1998^84^ | 46 | 46 | 92 | 3.27 | 2.63 | 3.91
| Duffy et. al., 1998^84^ | 47 | 47 | 94 | 1.11 | .67 | 1.55
| Duffy et. al., 1998^84^ | 47 | 47 | 94 | 4.27 | 3.52 | 5.03
| Duffy et. al., 1998^84^ | 46 | 46 | 92 | .55 | .13 | .97
| Gill et al., 1999^108^ | 223 | 223 | 446 | .62 | .43 | .81
| Gill et al., 1999^108^ | 223 | 223 | 446 | 2.38 | 2.14 | 2.63
| Healy et. al., 2002^63^ | 103 | 103 | 206 | 1.11 | .81 | 1.40
| Healy et. al., 2002^63^ | 103 | 103 | 206 | 2.26 | 1.91 | 2.61
| Healy et. al., 2002^63^ | 56 | 56 | 112 | 1.29 | .88 | 1.71
| Healy et. al., 2002^63^ | 56 | 56 | 112 | 3.22 | 2.64 | 3.79
| Indelli et. al., 2002^87^ | 85 | 91 | 176 | 3.51 | 3.03 | 3.99
| Indelli et. al., 2002^87^ | 85 | 91 | 176 | 1.45 | 1.11 | 1.78
| Martin et. al., 1997^88^ | 231 | 231 | 462 | 4.11 | 3.79 | 4.43
| Miyasaka et. al., 1997^89^ | 46 | 83 | 129 | 1.57 | 1.16 | 1.98
| Miyasaka et. al., 1997^89^ | 46 | 83 | 129 | 4.51 | 3.84 | 5.18
| Mokris et. al., 1997^90^ | 90 | 90 | 180 | 2.73 | 2.32 | 3.15
| Mokris et. al., 1997^90^ | 90 | 90 | 180 | 3.52 | 3.05 | 4.00
| Mont et. al, 1999^91^ | 101 | 101 | 202 | 1.23 | .93 | 1.54
| Mont et. al., 1999^91^ | 101 | 102 | 203 | 3.74 | 3.28 | 4.20
| O'Rourke et. al., 2002^66^ | 92 | 106 | 198 | 3.65 | 3.19 | 4.11
| O'Rourke et. al., 2002^66^ | 92 | 106 | 198 | 1.65 | 1.32 | 1.98
| O'Rourke et. al., 2002^66^ | 22 | 28 | 50 | 4.15 | 3.11 | 5.19
| O'Rourke et. al., 2002^66^ | 22 | 28 | 50 | 1.04 | .43 | 1.65
| Sextro et. al., 2001^93^ | 50 | 61 | 111 | 3.61 | 2.99 | 4.23
| Sextro et. al., 2001^93^ | 50 | 66 | 116 | .09 | -.28 | .47
Fixed | Combined (29) | 2599 | 2835 | 5434 | 2.07 | 2.00 | 2.14
Random | Combined (29) | 2599 | 2835 | 5434 | 2.57 | 2.08 | 3.05

Table 10. Meta analysis for WOMAC

(0–2 years)
| Citation | N1 | N2 | NTotal | Effect | Lower | Upper
| Beaupre et. al., 2001^95^ | 34 | 38 | 72 | 1.98 | 1.40 | 2.56
| Beaupre et. al., 2001^95^ | 34 | 39 | 73 | 1.79 | 1.23 | 2.35
| Beaupre et. al., 2001^95^ | 32 | 40 | 72 | 1.10 | .59 | 1.61
| Beaupre et. al., 2001^95^ | 32 | 40 | 72 | 2.77 | 2.10 | 3.44
| Beaupre et. al., 2001^95^ | 34 | 38 | 72 | 1.15 | .64 | 1.66
| Beaupre et. al., 2001^95^ | 34 | 39 | 73 | 1.07 | .57 | 1.57
| Beaupre et. al., 2001^95^ | 32 | 40 | 72 | 2.84 | 2.16 | 3.52
| Beaupre et. al., 2001^95^ | 34 | 39 | 73 | 1.44 | .91 | 1.97
| Beaupre et. al., 2001^95^ | 34 | 38 | 72 | 1.57 | 1.03 | 2.11
| Jones et. al., 2001^96^ | 221 | 221 | 442 | 1.16 | .96 | 1.36
| Jones et. al., 2001^96^ | 221 | 221 | 442 | 1.83 | 1.61 | 2.06
| Jones et. al., 2001^96^ | 35 | 35 | 70 | 1.88 | 1.30 | 2.46
| Jones et. al., 2001^96^ | 221 | 221 | 442 | 1.61 | 1.39 | 1.82
| Jones et. al., 2001^96^ | 35 | 35 | 70 | 1.75 | 1.18 | 2.31
| Jones et. al., 2001^96^ | 35 | 35 | 70 | .99 | .48 | 1.49
Fixed | Combined (15) | 1068 | 1119 | 2187 | 1.54 | 1.44 | 1.64
Random | Combined (15) | 1068 | 1119 | 2187 | 1.62 | 1.39 | 1.86

Table 8. Meta analysis for HSS

(0–2 years)
| Citation | N1 | N2 | NTotal | Effect | Lower | Upper
| Ververeli et. al., 1995^52^ | 41 | 41 | 82 | 1.56 | 1.06 | 2.07
| Ververeli et. al., 1995^52^ | 42 | 42 | 84 | 1.82 | 1.30 | 2.34
| Worland et. al., 1998^53^ | 37 | 37 | 74 | 6.01 | 4.90 | 7.13
| Worland et. al., 1998^53^ | 43 | 43 | 86 | 4.56 | 3.74 | 5.39
Fixed | Combined (4) | 163 | 163 | 326 | 2.47 | 2.15 | 2.78
Random | Combined (4) | 163 | 163 | 326 | 3.43 | 1.66 | 5.21
(2–5 years)
| Citation | N1 | N2 | NTotal | Effect | Lower | Upper
| Hasegawa et. al., 2002^54^ | 9 | 9 | 18 | 3.32 | 1.66 | 4.98
| Hasegawa et. al., 2002^54^ | 131 | 131 | 262 | 4.17 | 3.73 | 4.60
| Hsu et. al., 1998^55^ | 113 | 113 | 226 | 2.20 | 1.86 | 2.53
| Larson et. al., 2001^56^ | 82 | 82 | 164 | 3.24 | 2.77 | 3.71
| Liu & Chen, 1998 ^57^ | 64 | 64 | 128 | 5.51 | 4.74 | 6.29
| Liu & Chen, 1998^57^ | 24 | 24 | 48 | 4.21 | 3.13 | 5.28
| Moskal & Diduch, 1998^58^ | 488 | 514 | 1002 | 2.15 | 2.00 | 2.31
| Rand & Gustilo, 1996^60^ | 182 | 182 | 364 | 3.20 | 2.88 | 3.51
Fixed | Combined (8) | 1093 | 1119 | 2212 | 2.63 | 2.51 | 2.74
Random | Combined (8) | 1093 | 1119 | 2212 | 3.45 | 2.74 | 4.16
(5 + years)
| Citation | N1 | N2 | NTotal | Effect | Lower | Upper
| Diduch et. al., 1997^61^ | 80 | 88 | 168 | 4.10 | 3.56 | 4.65
| Healy et. al., 2002^63^ | 103 | 103 | 206 | 2.16 | 1.81 | 2.51
| Healy et. al., 2002^63^ | 56 | 56 | 112 | 2.68 | 2.16 | 3.20
| Ikejiani et. al., 2000^64^ | 45 | 45 | 90 | 3.21 | 2.56 | 3.85
| Ikejiani et. al., 2000^64^ | 140 | 140 | 280 | 3.02 | 2.68 | 3.37
| Malkani et. al., 1995^65^ | 84 | 118 | 202 | 2.39 | 2.02 | 2.75
| O'Rourke et. al., 2002^66^ | 92 | 106 | 198 | 2.56 | 2.18 | 2.94
| O'Rourke et. al., 2002^66^ | 22 | 28 | 50 | 2.05 | 1.33 | 2.76
| Regner et. al., 1997^67^ | 103 | 120 | 223 | 3.99 | 3.53 | 4.45
| Schroder et. al., 2001^68^ | 52 | 102 | 154 | 3.59 | 3.06 | 4.11
Fixed | Combined (10) | 777 | 906 | 1683 | 2.87 | 2.73 | 3.01
Random | Combined (10) | 777 | 906 | 1683 | 2.97 | 2.53 | 3.40

Table 11. Meta analysis for SF-36

(0–2 years)
| Citation | N1 | N2 | NTotal | Effect | Lower | Upper
| Bachmeier et. al., 2001^94^ | 45 | 108 | 153 | 1.22 | .84 | 1.60
| Beaupre et. al., 2001^95^ | 32 | 40 | 72 | 1.02 | .51 | 1.52
| Beaupre et. al., 2001^95^ | 36 | 39 | 75 | .84 | .36 | 1.33
| Beaupre et. al., 2001^95^ | 34 | 40 | 74 | .97 | .48 | 1.47
| Bert et. al., 2000, 2001^69,^ ^99^ | 158 | 254 | 412 | 1.37 | 1.15 | 1.59
| Fortin et. al., 1999^28^ | 47 | 47 | 94 | 1.52 | 1.05 | 1.99
| Fortin et. al., 1999^28^ | 59 | 59 | 118 | 1.10 | .70 | 1.49
| Heck et. al., 1998^72^ | 268 | 291 | 559 | 1.24 | 1.06 | 1.42
| Jones et. al., 2001^96^ | 35 | 35 | 70 | .88 | .38 | 1.38
| Jones et. al., 2001^96^ | 221 | 221 | 442 | 1.19 | .99 | 1.39
Fixed | Combined (10) | 935 | 1134 | 2069 | 1.21 | 1.11 | 1.30
Random | Combined (10) | 935 | 1134 | 2069 | 1.20 | 1.10 | 1.30

## Revisions and Complications

Revision rates were calculated in several ways. The basic data are shown as an evidence table in Appendix F, Evidence Table 2. Table 12 summarizes the revision rates for primary TKAs. The results are organized to show the rates at different followup intervals and are grouped by both knees and patients. The revision rates are further subdivided into operations specified as revisions and all procedures performed on the knees in question. The revision rate through five or more years is 2.0 percent of knees and 2.1 percent of patients.

Table 12. Revision rates after primary TKAs

| Based on Knees | | Based on Patients
Followup | Revisions | Revisions Other Procedures | Revisions | Revisions Other Procedures
0–2 years | 0 | 0 | < 1% | < 1%
2.1-5 years | 2.0% | 3.5% | 1.6% | 2.9%
5+ years | 2.0% | 3.1% | 2.1% | 3.5%

The data base used to calculate perioperative complication rates (defined as occurring within six months of the TKA) is shown in Appendix F, Evidence Table 3. Complications were defined by each investigator. The vast majority were “knee related” or deep venous thrombosis. When the unit of analysis was numbers of knees operated on, the complication rate was 5.4 percent; when the denominator was numbers of patients, the rate was 7.6 percent. There were essentially no cardiopulmonary complications reported. Given the number of elderly subjects undergoing a major surgical procedure this suggests that these adverse effects were not addressed in the literature.

Although the sampling approach was not specifically designed to search for all outcomes associated with using different types of prostheses or different surgical approaches, we did analyze the studies that fell within the search parameters. In some cases it was difficult to classify a study as primarily addressing either the use of a specific type of prosthesis or testing a specific surgical procedure or technique. Several studies reported prostheses that were used in specific types of procedures. Table 13 is arranged to attempt to classify the emphasis of studies by procedure or prosthesis, but some overlap is inevitable. A number of the studies of prostheses were case series that reported generally good results. A few tested the use of a prosthesis with a specific group of patients. The studies of procedures were a mixture of case studies and comparative studies.

Table 13. Assessment of TKA prostheses and surgical procedures

Study | Prosthesis Type | Measure(s) and Baseline Score | Followup Length and Score | Notes
Prothesis
Baldwin & Rubinstein, 1996^101^ | Intermedics Natural Knee TKA, (1) Subjects with excellent/good bone quality (GB) vs. (2) Subjects with fair/bad bone quality (BB) | Hospital of Special Surgery (HSS) | Followup = 4 years | Study concludes bone quality had little effect on the four-year outcome of this ingrowth TKA.
| | HSS | HSS
| | GB: 55 | GB: 92
| | BB: 48 | BB: 90
Bert et al., 2000, 2001^69,^ ^99^ | Total condylar TKA. Low demand patients were randomized to receive either (1) All-polyethylene or (2) metal-backed implant type. Not reported for medium/high demand subjects | Knee Society Knee Score (KS) | Followup = 1 year | Study hypothesis that prosthetic choice should be determined by peroperative activity level (demand matching) was not validated.
| | AP, low demand: 41 | KS
| | MB, low demand: 38 | AP, low demand: 82
| | Function score (KSF) | MB, low demand: 87
| | AP, low demand: 41 | KSF
| | MB, low demand: 43 | AP, low demand: 72
| | | MB, low demand: 54
Cloutier et al., 2001^83^ | Total condylar, posterior cruciate-retaining | KS: 33 | Followup = 10 years | After TKA with PCR both anterior and posterior cruciate ligaments (even degenerate) remain functional after an average of 10 years. Survival at 10 years with end point being revision was 94.8%.
| | KSF: 44 | KS: 90.7
| | | KSF: 82
Evanich et al., 1997^62^ | Cementless Intermedics Natural Knee TKA using metal-backed, porous-coated patellar component | HSS: 58 | Followup = 6–10 years | Overall patellar survivorship was 96%. Study concludes comparatively good results from the use of a metal-backed patellar component if component design, surgical technique and patellar alignment are properly addressed.
| | | HSS: 98
Ewald et al., 1999^85^ | Kinematic nonconstrained TKA, posterior cruciate-retaining | KS: 42 | Followup = 10–14 years | Overall revision rate was 6.5%. Data from study suggests patella replacement is not appropriate with this design
| | KSF: 37 | KS: 82
| | | KSF: 68
Gill & Joshi, 2001^86^ | Cemented posterior cruciate ligament-retaining TKA. Total Condylar Knee (54%) and Kinematic Condylar (46%). | KS: 39 | Followup = 16.8 years | Study finds the long-term results of cemented posterior cruciate ligament-retaining TKA excellent in terms of improved function and pain relief.
| | KSF: 44 | KS: 90
| | | KSF: 58
Gill et al., 1999^108^ | Total Condylar Knee, posterior cruciate-retaining | KS: 40.3 | Followup = 16–21 years | Prosthetic survivorship at 20 years was 96% for revision. Total Condylar with retention of the posterior cruciate produces results comparable to the original Total Condylar Knee with cruciate-sacrifice.
| | | KS: 88.4
Gioe & Bowman, 2000^103^ | Press-Fit Condylar, (1) All-polyethylene (APT) vs. (2) Metal-backed tibial (MBT) components. | KS | Follow up = 3 years | Study reports TKA with all-polyethylene components functions equivalently to metal-backed tibial components, and is less costly.
| | APT: 38.1 | KS
| | MBT: 35.4 | APT: 84.3
| | KSF | MBT: 85.4
| | APT: 55.9 | KSF
| | MBT: 57.2 | APT: 74.4
| | | MBT: 72.1
Hsu et al., 1998^55^ | Hybrid Miller-Galante I (MGI) TKA using uncemented femoral components with cemented tibial and patellar components | HSS: 64 | Followup = 4.8 years | Study does not recommend MGI TKA due to high rate of patellar complications but may be a useful alternative fixation mode in TKA procedures.
| | | HSS: 90
Indelli et al., 2002^87^ | Insall-Burstein II | KS: 41 | Followup = 7.5 years | Survivorship analysis using worst-case scenario showed a success rate of 91%.
| | | KS: 94
Jordan et al., 1997^105^ | Mobile meniscal bearing TKA | KS: 29 | Followup = 8 years | Kaplan-Meier survivor analysis, using revision surgery for any mechanical reason, showed a survivorship of 94.6%.
| | KSF: 34 | KS: 93
| | | KSF: 94
Larson et al., 2001^56^ | Insall-Burstein II posterior-stabilized TKA | HSS: 58 | Followup = 4 years | 80% and 17% of the knees were rated excellent and good, respectively. Using the patellar resurfacing technique used in this study, patellofemoral complications were only 4.2%.
| | | HSS: 89
Liu & Chen, 1998^57^ | Four different implants used. | | | Not possible to test effect of prosthesis.
Malakani et al., 1995^65^ | Kinematic Condylar prosthesis, posterior cruciate-retaining | HSS: 55 | Followup = 10 years | Using revision as end point, rate of survival was 96%. Study found knee scores, rate of survival of implants were similar to reported previously subjects who had a total condylar TKA with sacrifice of the posterior cruciate ligament. Loosening of patellar components was noted to be a major problem.
| | KS: 33 | HSS: 81
| | KSF: 46 | KS: 80
| | | KSF: 64
Meding et al., 2001^78^ | Posterior cruciate-retaining TKA (98%) | | | Not possible to test effect of prosthesis.
| Insall-Burstein II posterior stabilized TKA (2%)
Miyasaka et al., 1997^89^ | Total Condylar, posterior cruciate-sacrificing | KS: 28.1 | Followup = 14 years | Survival of retention of the prosthesis was 91% at 13 years.
| | KSF: 30.2 | KS: 88.7
| | | KSF: 69.2
Mokris et al., 1997^90^ | Genesis TKA system, conversion module allowing for posterior cruciate-sacrifice | KS: 50 | Followup = 6.5 years | Clinically, results were excellent in 95% of knees, good in 4%.
| | KSF: 41 | KS: 97
| | | KSF: 88
Mont et al., 1999^91^ | Duracon TKA system, posterior cruciate-retaining | KS: 52 | Followup = 5 years | At final follow up 96% of knees had good or excellent results. Almost complete absence of patellofemoral complications was noted.
| | KSF: 42 | KS: 94
| | | KSF: 70
O'Rourke et al., 2002^66^ | Insall-Burstein II, (1) All-polyethylene (APT) vs. (2) Cemented metal-backed tibial (MBT) components. | KS | Followup = 6.4 years | Modular Insall-Burstein II TKAs were found to function well at followup although the authors noted that the high prevalence of osteolysis in subjects with good/excellent clinical scores was worrisome. Routine followup radiographs after TKA to detect asymptomatic osteolytic changes was recommended.
| | APT: 34 | KS
| | MBT: 30 | APT: 87
| | KSF | MBT: 85
| | APT: 64 | KSF
| | MBT: 50 | APT: 79
| | HSS | MBT: 79
| | APT: 71 | HSS
| | MBT: 59 | APT: 87
| | | MBT: 87
Regner et al., 1997^67^ | Freeman-Samuelson TKA with three different types of tibial components fixed with macrointerlocking pegs: (1) High density polyethylene without stem (Group 1); (2) Metal-backed tibial without stem (Group 2); (3) Metal-backed tibial with stem (Group 3) | HSS: 42 | Followup = 6.8 years | Using revision as end point, rate of survival was 79% at 10 years. Investigators found cementless fixation of this design using the macrointerlocking pegs and no other stabilization resulted in poor fixation and a high revision rate and cannot be recommended.
| | | HSS: 82
Rinta-Kiikka et al., 1996^92^ | Cementless Synatomic TKA, posterior cruciate-retaining | KS: 48.5 | Followup = 5–7 years | Clinical survival rate, based on aseptic loosening, was 88.6%.
| | KSF: 42.6 | KS: 76.9
| | | KSF: 64.2
Ritter et al., 1995^109^ | Anatomic Graduated Components TKA, posterior cruciate-retaining | | Followup = 10.7 years | Clinical survival rate, based on revision, was 98.86% at 15 years.
| | | KS: 81
Rodriguez et al., 1996^80^ | Total Condylar TKA | KSF: 28 | Followup = 12.7 years | At the 15-year followup period, survivorship analysis suggested a 91% probability of survival for the prosthesis. Cemented Total Condylar TKA in severe rheumatoid arthritis provided durable pain relief and restoration in function.
| | | KSF: 55
Schroder et al., 2001^68^ | Cementless porous-coated Anatomic Graduated Components TKA | HSS: 52 | Followup = 10 years | At followup, 92% of the patients were satisfied or very satisfied with their TKA. Cumulative prosthesis survival after 10–11 years was 97%.
| | | HSS: 91
Sextro et al., 2001^93^ | Kinematic I condylar TKA, posterior cruciate-retaining | KS: 32.8 | Followup = 15.7 years | At the 15-year followup period, survivorship was 88.7%, using revision as the endpoint. Study shows good function and survivorship of the Kinematic I condylar TKA.
| | KSF: 48.7 | KS: 87.9
| | | KSF: 51.3
Title et al., 2001^107^ | (1) Total Condylar TKA, posterior cruciate-sacrificing (TCP) vs. (2) Press-Fit Condylar, posterior cruciate-substituting (PFC) | KS | Followup = 4 and 4.5 years | Both designs showed comparable pain relief and walking ability.
| | TCP: 43.4 | KS
| | PFC: 44 | TCP: 95.4
| | KSF | PFC: 96.7
| | TCP: 31 | KSF
| | PFC: 30.4 | TCP: 85.5
| | | PFC: 92.2
Yang et al., 2001^81^ | Total condylar-type design with or without posterior cruciate-retention | | | Not possible to test effect of prosthesis.
Procedures
Bourne et al., 1995^70^ | All subjects received single type featuring an anatomic patellofemoral joint, (1) Patella resurfaced group (PR) vs. (2) Patella not resurfaced group (PNR) | KS | Followup = 2 years | The not resurfaced group had significantly less pain at two-year followup. A required longer followup suggested.
| | PR: 37 | KS
| | PNR: 41 | PR: 81
| | KSF | PNR: 87
| | PR: 41 | KSF
| | PNR: 44 | PR: 67
| | | PNR: 76
Brown et al., 2001^82^ | Non reported identical prosthesis type, reports on component asymmetry. (1) Asymmetric TKA (AS) vs. (2) Symmetric TKA (S) | KS | Followup = 6.4 years | No statistical differences in knee scores were noted between right and left TKAs performed with asymetrically sized components.
| | AS: 54 | KS
| | S: 51 | AS: 91
| | | S: 90
Bullens et al., 2001^75^ | Press-Fit Condylar TKA, posterior cruciate-retaining (PCR) in 95% | KS: 32.9 | Followup = 4.9 years | Five-year survival with revision as end point being revision 99% (best-case scenario), but decreased to 69% with revision, pain scale (visual analog -VAS) >20, satisfaction VAS <80, or lost to follow up as endpoint (worst-case scenario).
| | KSF: 29.1 | KS: 83.5
| | | KSF: 51.5
Clark et al., 2001^98^ | (1) Posterior cruciate-sacrificed (PCS) vs. (2) Posterior cruciate-retaining (PCR) TKAs | KS | Followup = 2 years | No notable differences between groups at years two and three of followup.
| | PCS: 98.8 | KS
| | PCR: 100.6 | PCS: 157.1
| | WOMAC | PCR: 156.5
| | PCS: 50.4 | WOMAC
| | PCR: 47.2 | PCS: 22.8
| | | PCR: 18.5
Cohen et al., 1997^71^ | AMK, a condylar cruciate-sparing implant, (1) Bilateral, and (2) Unilateral TKA | KS | Followup = 0.5 years | Study concludes simultaneous bilateral TKA does not result in any significant increase in patient morbidity or effect post-op function compared to unilateral TKA.
| | B: 53 | KS
| | U: 55 | B: 89
| | | U: 87
Deshmukh et al., 2002^27^ | Cemented Kinemax, patella retained. Role of body weight investigated | KS: 23 | Followup = 0.5 years | Study found body weight did not adversely affect the outcome of TKA in the short-term.
| | KSF: 42 | KS: 79
| | | KSF: 63
Diduch et al., 1997^61^ | Posterior stabilized, posterior cruciate-substituting | HSS: 55 | Followup = 8 years | Survival at 18 years with end point being revision was 94%.
| | | HSS: 92
Duffy et al., 1998^84^ | Press-Fit Condylar, (1) Uncemented (UC) vs. (2) Cemented (C) (Press-Fit Condylar) | KS | Followup = 10 years | Survival at end point being revision or aseptic loosening was 72% in the uncemented group and 94% in the cemented group.
| | UC: 33 | KS
| | C: 32 | UC: 87.8
| | KSF | C: 92.4
| | UC: 52.3 | KSF
| | C: 45.4 | UC: 66.3
| | | C: 72.4
Elke et al., 1995^76^ | Unconstrained posterior cruciate ligament-retaining TKA. 424 cemented, 100 uncemented TKA | KS not broken down by cemented vs. uncemented | Followup = 4.8–9.8 years | Cemented TKA can be recommended for patients with RA.
Griffin et al., 1998^110^ | Posterior stabilized, cemented with metal-backed tibial components and patella resurfacing in obese patients | HSS | Followup = 10 years | HSS scores comparable between groups and revision rates were not higher in the obese group at followup.
| | Obese: 47.7 | HSS
| | Not Obese: 55 | Obese: 88.3
| | | Not Obese: 90.3
Harwin, 1998^102^ | Kinemax cemented posterior cruciate ligament-retaining condylar with a symmetrical femoral component articulating with a medially offset symmetrical dome patella component | KS: 38 | Followup = 5.1 years | Study suggests cemented TKA with symmetrical patellofemoral resurfacing with an offset patella dome and posterior cruciate ligament-retention yields low patellofemoral complications and reoperations
| | KSF: 47 | KS: 91
| | | KSF: 86
Hasegawa et al., 2002^54^ | Cruciate-retaining (cementless) and posterior stabilized (cemented) | | | Not possible to test effect of prosthesis.
Hube et al., 2002^104^ | Midvastus approach for TKA | KS: 52.3 | Followup = 3 years | 95% of the patients had excellent or good functional result.
| | | KS: 90.6
Ilkejiani et al., 2000^64^ | Genesis knee system, (1) Patella resurfaced group (PR) vs. (2) Patella not resurfaced group (PNR) | HSS | Followup = 2 years | No significant difference between groups with regard to pain, HSS scores, and complications.
| | PR: 54.8 | HSS
| | PNR: 56.0 | PR: 89.1
| | | PNR: 91
Jenny & Jenny, 1998^77^ | Search total knee prosthesis which allows retention or replacement of the anterior cruciate ligament (ACL). (1) ACL-retaining group (AR) vs, (2) ACL-replacing (ARP) | KS | Followup = 2–3 years | Results showed clinical and functional outcomes were neither improved nor worsened with the ACL-retaining prosthesis.
| | AR: 50 | KS
| | ARP: 41 | AR: 89
| | KSF | ARP: 90
| | AR: 41 | KSF
| | ARP: 38 | AR: 80
| | | ARP: 79
Konig et al., 1997, 1998, 2000^30,^ ^106,^ ^111^ | Posterior cruciate-retaining, press-fit condylar TKA using uncemented femoral components with cemented tibial and patellar components | Data from Konig et al., 1997^85^ | Followup = 3.2 years | Study showed hybrid TKA provides good results comparable to cemented TKA.
| | KS: 28.7 | KS: 82.3
| | KSF: 45.5 | KSF: 71.9
Lombardi Jr et al., 2001^112^ | (1) Maxim posterior cruciate-retaining (PCR) vs. (2) Maxim posterior cruciate-sacrificing (PCS) | KS | Followup = 5 years | No significant differences in outcome between the groups were observed.
| | PCR: 118.04 | KS - Total
| | PCS: 112.90 | PCR: 162.16
| | KSF | PCS: 158.05
| | PCR: 54.77 | KSF
| | PCS: 47.91 | PCR: 71.22
| | KS-Pain | PCS: 66.77
| | PCR: 16.67 | KSF - Pain
| | PCS: 13.63 | PCR: 44.23
| | Converted from HSS | PCS: 44.10
Martin et al., 1997^88^ | Press-Fit Condylar TKA. | KS: 28 | Followup = 6.5 years | Study reports good results with the Press-Fit Condylar, 95% of patients were pain free on level walking and were satisfied with their functional result.
| | KSF: 49 | KS: 88
| | | KSF: 72
Matsueda & Gustilo, 2000^74^ | Genesis TKA system | KS | Follow up = 0.5 years | There were no significant differences in the KS score.
| | S: 51 | KS
| | MP: 52 | S: 90
| | KSF | MP: 90
| | S: 47 | KSF
| | MP: 46 | S: 75
| | | MP: 74
Moskal & Diduch, 1998^58^ | Several designs | | | Not possible to test effect of prosthesis.
Pereira et al., 1998^59^ | Kinemax, (1) Posterior cruciate-retaining (PCR) vs. (2) Posterior cruciate-sacrificing (PCS) | HSS | Followup = 3 years | Data revealed no difference in clinical outcome between PCR and PCS.
| | PCR: 56.08 | HSS
| | PCS: 51.12 | PCR: 90.2
| | | PCS: 92.16
Ranawat et al., 1997^79^ | Press-Fit Condylar modular TKA, posterior cruciate-substituting | KS: 44 | Followup = 4.8 years | Study found Press-Fit Condylar modular TKA resulted in excellent relief of pain and restoration of function with a low prevalence of patellofemoral problems. Survival of the implant at 6 years was 97%.
| | KSF: 40 | KS: 93
| | | KSF: 78
Rand & Gustilo, 1996^60^ | Genesis TKA system, (1) Resurfacing patellar component (RSC) vs. (2) Inset Biconvex patellar component (BPC) | KS | Follow up = 2.3 years | At followup, KS score was higher in the RSC group. The inset BPC appeared to provide better radiographic alignment than the RSC, but it had a higher incidence of radiolucent lines.
| | RSC: 37 | KS
| | BPC: 42 | RSC: 92
| | KSF | BPC: 86
| | RSC: 48 | KSF
| | BPC: 44 | RSC: 81
| | HSS | BPC: 82
| | RSC: 60 | HSS
| | BPC: 57 | RSC: 88
| | | BPC: 88

TKA studies assessing prophylaxis for postoperative deep venous thrombosis (DVT) or infection were identified by searching the 611 references meeting and not meeting inclusion criteria. The Cochrane Library was also searched back to 1994. The investigators decided a priori to include only randomized controlled trials (RCTs) with the exception of large cohort studies. Fourteen studies were identified and extracted; nine DVT, three infection, and two tourniquet studies. All included studies were randomized controlled trials with the exception of one large cohort study.^24^ One trial was identified through The Cochrane Library.^25^

Several other procedures, which involved primarily non-surgical elements of care, were also described. These are summarized in Table 14. Three of these addressed the use of continuous passive motion as a rehabilitative approach; two studies were positive. The other two studies tested different clinical pathways and showed mixed results.

Table 14. Assessment of TKA procedures/programs

Study | Procedure Type | Measure(s) and Baseline Scores | Followup Length and Scores | Notes
Beaupre et al., 2001^95^ | (1) Standard exercise and continuous passive motion (CPM) vs. (2) Standard exercise and Slider Board (SB) vs. (3) Standard exercise alone (SE) | Western Ontario and McMaster Osteoarthritis Index (WOMAC) and SF-36, Physical Functioning (SF-36 PF) | Followup = 0.5 years | No differences between groups in WOMAC and SF-36 scores at any measurement interval. When postop rehabilitation regimens that focus on early mobilization are used, adjunct CPM or SB that are added to SE are not required.
| | WOMAC | WOMAC
| | Pain, CPM: 47 | Pain, CPM: 76
| | Stiffness, CPM: 44 | Stiffness, CPM: 65
| | Function, CPM: 51 | Function, CPM: 74
| | Pain, SB: 46 | Pain, SB: 85
| | Stiffness, SB: 50 | Stiffness, SB: 73
| | Function, SB: 41 | Function, SB: 81
| | Pain, SE: 51 | Pain, SE: 79
| | Stiffness, SE: 49 | Stiffness, SE: 69
| | Function, SE: 53 | Function, SE: 77
| | SF-36, PF | SF-36 PF
| | CPM: 31 | CPM: 46
| | SB: 31 | SB: 53
| | SE: 31 | SE: 55
Healy et al., 2002^63^ | (1) Clinical pathway group (CP) vs. (2) No clinical pathway group (NCP) | KS | CP Followup = 5 years | Both groups had excellent relief of pain and improvement in function. The CP program reduced resource utilization and cost.
| | CP: 51.58 | NCP Followup = 8 years
| | NCP: 43.61 | KS
| | KSF | CP: 92.11
| | CP: 49.90 | NCP: 90.75
| | NCP: 45.18 | KSF
| | HSS | CP: 75.11
| | CP: 60.64 | NCP: 74.69
| | NCP: 57.68 | HSS
| | | CP: 88.06
| | | NCP: 86.92
Lin et al., 2002^73^ | (1) No (or Pre) clinical pathway group (NCP) vs. (2) Clinical pathway group (CP) | KS | Followup = 2 years | No significant differences were found between groups in the knee scores. Clinical pathway is an effective management tool for TKA.
| | CP: 40.6 | KS
| | NCP: 43.0 | CP: 93.6
| | KSF | NCP: 93.5
| | CP: 46.7 | KSF
| | NCP: 34.1 | CP: 84.2
| | | NCP:84.7
Ververeli et al., 1995^52^ | (1) Continuous passive motion (CPM) vs. (2) no CPM (NCPM) | HSS | Followup = 2 years | No clinical differences in knee scores at follow up. CPM is efficacious in increasing short-term flexion and decreasing need for knee manipulation without increasing costs.
| | CPM: 63.5 | HSS
| | NCPM: 65 | CPM: 84.5
| | | NCPM: 81.3
Worlund et al., 1998^53^ | (1) Continuous passive motion (CPM) vs. (2) Professional physical therapy (PT) | HSS | Followup = 0.5 years | Study concludes CPM is an adequate rehabilitation alternative with lower costs and no difference in clinical results.
| | CPM: 62.9 | HSS:
| | PT: 61.7 | CPM: 95.3
| | | PT: 95.7

The review of randomized trials addressing prevention of venous thrombosis and pulmonary embolus uncovered several studies that tested various approaches to anticoagulation and other preventive techniques. These studies are summarized in Table 15. Two studies suggest that compression ultrasonography is not justified. Two find drug therapy better than mechanical approaches. Several studies compared anticoagulant drugs and drug regimens.

Table 15. Complications: Prevention of Venous Thrombosis (VT)/Pulmonary Embolism (PE) studies

Study | Study Type: Intervention; Control | Results | Conclusions
Blanchard et al., 1999^113^ | RCT: (1) Nadroparin calcium, a LMWH, adjusted to body weight., subcutaneously 12 hours before and after surgery then once a day for 10–12 days vs. (2) Continuous intermittment pneumatic compression device (CIPC) of the foot. | DVT: 31/48 (65%, 95% CI 49.5–77.8) for CIPC group and 16/60 (27%, 95% CI 16.1–39.7) for the nadroparin group (p<0.001). Only one patient in the nadroparin group had severe bleeding. | Authors conclude that a once daily fixed, weight-adjusted dose of nadroparin is superior to CIPC of the foot.
Colwell et al., 1995^114^ | RCT, open-label: (1) Postoperative Enoxaparin 30 mg subcutaneously bid vs. (2) Unfractionated heparin 5000 IU subcutaneously three times daily. MDT = 7 (up to 14 days) | 77/225 (34%) of heparin subjects and 56/228 (25%) of enoxaparin subjects had an incidence of DVT (p=0.02). Two subjects receiving heparin had a PE, one fatal. three major hemorrhagic episodes in each group. | Study found postoperative enoxaparin more effective and as safe as unfractionated heparin in preventing DVT in patients having elective TKA.
Francis et al., 1996^115^ | RCT: (1) “Two-step” warfarin, administered 10–14 days preoperatively then postoperatively vs. (2) warfarin, one dose night before TKA. Postoperatively, dose adjusted to target INR 2.2. Treatment up to nine days. | Occurrence of DVT nearly identical, 39% in the two-step regimen vs. 38% for the night before group. Occurrence of proximal VT was 5% vs. 7%, respectively (p ns). Patients in two-step regimen received 1.3 transfusions vs. 0.95 of the night before regimen (p<0.05). | Authors conclude night before warfarin regimen is more convenient and may be associated with less bleeding than the two-step warfarin regimen.
Heit et al., 2000^116^ | Double-blind (DB), placebo-controlled, randomized controlled trial (RCT), TKA and THA. (1) Postoperative Ardeparin, a low molecular-weight heparin (LMWH), 50 anti Xa, IU/kg body weight subcutaneously bid vs. (2) Placebo. Mean duration of treatment (MDT) = 7 days postoperative. | Results for TKA only. | Study found the cumulative incidence of symptomatic DVT or death was not significantly reduced by ardeparin prophylaxis. Authors conclude extended ardeparin use is not clinically important for most patients and future research should identify high-risk patients who would benefit most from extended prophylaxis.
| | DVT, PE, or death: 5 (1.4%) for ardeparin group, 6 (1.7%) for placebo, OR = 0.8 (95% CI 0.2–2.7).
| | DVT: 1 (0.3%) for ardeparin group, 3 (0.8%) for placebo, OR = 0.3 (95% CI 0.03–3.1).
Leclerc et al., 1996^117^ | DB, RCT: (1) Postoperative Enoxaparin 30 mg subcutaneously bid vs. (2) Postoperative Warfarin, dose adjusted to INR 2–3. MDT = 9 (up to 14 days). | 109 of 211 (51%) warfarin subjects had an incidence of DVT vs. 76/206 (37%) of enoxaparin subjects (p=0.003). 22 (10.4%) warfarin and 24 (11.7%) had proximal VT (p>0.2). 6 (1.8%) warfarin and 7 (2.1%) had major bleeding (p>0.2). | Study found postoperative fixed-dose enoxaparin more effective than adjusted-dose warfarin in preventing DVT after TKA. No differences were observed for incidence of proximal VT or clinically overt hemorrhage.
Leclerc et al., 1998^24^ | Cohort study, TKA and THA: | Results for TKA cohort only. | Postoperative use of enoxaparin for a mean of nine days is associated with a clinically acceptable rate of symptomatic VT and major hemorrhage. Authors conclude predischarge compression ultrasonography cannot be justified.
| Postoperative Enoxaparin, a LMWH, 30 mg subcutaneously bid. MDT = 9 (up to 14 days. | VT: 33/842 (3.9%, 95% CI 2.6–5.2)
| | Symptomatic proximal VT or PE: 23/842 (2.7%)
| | Fatal PE: 3/842 (0.4%)
| | Major hemorrhage: 24/842 (2.9%)
Perhoniemi et al., 1996^118^ | DB, RCT, TKA, and THA: (1) Postoperative Enoxaparin 40 mg subcutaneously once a day vs. (2) Dihydroergotamine 0.5 mg + Heparin 5000 IU (HDHE) subcutaneously bid. One dose from each group prior to surgery. Treatment for seven days. | Results for TKA and THA combined. Overall incidence of thromboembolic events was low (3%). One DVT seen in the Enoxaparin group and two PE in HDHE group. | Study found the two regimens showed comparable efficacy and overall safety in preventing DVT.
Robinson et al., 1997^119^ | DB, RCT, TKA, and THA. All subjects receiving postoperative warfarin adjusted to target International Normalized Ratio (INR) 2–3 for a mean of 9.8 days were randomized to (1) Bilateral Compression Ultrasonography vs. (2) Sham. | Results for TKA only. In the screening group, one subject developed symptomatic proximal DVT and one had a nonfatal PE. One subject in the sham group had a symptomatic proximal DVT. Asymptomatic DVT was detected in six subjects in the screening group. | Use of warfarin prophylaxis during hospitalization results in very low rates of symptomatic DVT or PE after discharge. Authors conclude use of compression ultrasonography is not justified in this setting.
Westrich & Sculco, 1996^120^ | RCT: (1) Postoperative Aspirin 325 mg bid (also given night of operation) vs. (2) Postoperative Aspirin + Pulsatile pneumatic plantar-compression device (PPPC) for 5 days. Warfarin administered if either treatment was judged to have failed. | 22/81 (27%) of PPPC subjects had an incidence of DVT vs. 49/83 (59%) of aspirin alone subjects (p<0.001). | Study confirms safety and efficacy of PPPC with aspirin compared with aspirin alone and supports use of mechanical compression for prophylaxis against DVT.

Table 16 summarizes three randomized trial that address infection prevention. Each compares alternative antibiotic regimens.

Table 16. Complications: Prevention of infection studies

Study | Study Type: Intervention; Control | Results | Conclusions
Chiu et al., 2002^121^ | Randomized controlled trial (RCT): (1) Cefuroxime 2 grams -impregnated cement vs. (2) Cement without cefuroxime. | No knees developed deep infections in the Cefuroxime-impregnated cement group vs. 5 knees (3.1%, p=0.02) in the group receiving cement without Cefuroxime. | Cefuroxime-impregnated cement was demonstrated to be effective in the prevention of early to late deep infection after TKA.
Mauerhan et al., 1993^25^ | Double blind (DB), RCT, TKA and THA: | Results for TKA cohort only. | Study found no significant differences in the prevalence of wound infections between the two antibiotic regimens.
| (1) Cefuroxime 1.5 grams followed by 750 mg x 2 doses for a total of one day of antibiotic treatment vs. (2) Cefazolin 1 gram three times daily for three days. | Rate of deep wound infection was 0.6% (1/178) for subjects receiving Cefuroxime vs. 1.4% (3/207) for subjects receiving Cefazolin.
Periti et al., 1999^122^ | RCT, TKA, and THA: (1) Teicoplannin 400 mg IV x 1 dose at induction of anesthesia vs. (2) Cefazolin, 5 doses over 24-hour period (2 grams at induction of anesthesia and 1gram daily IV). | Results for TKA cohort only. | Study concludes a single preoperative dose of Teicoplannin ensures adequate surgical antisepsis compared with a standard, multiple-dose regimen of Cefazolin.
| | 6 (1.5%) subjects in the Teicoplannin group and 7 (1.7%) subjects in the Cefazolin group developed a surgical wound infection during postoperative hospital stay (p ns).

Table 17 shows two randomized trials that tested the use of tourniquets in performing TKAs. One concluded tourniquets were safe and the other that they did not reduce surgical complications.

Table 17. Complications: Tourniquet studies

Study | Study type: Intervention; Control | Results | Conclusions
Abdel-Salam & Eyres, 1995^123^ | RCT: (1) Undergo TKA surgery with tourniquet vs. (2) Surgery without tourniquet. | 4/40 (10%) subjects in tourniquet group had DVT within 8–21 days after surgery vs. none (0/40) for the no tourniquet group. | Study concludes TKA can be safely performed without the use of the tourniquet.
| | 5/40 (12.5%) subjects in tourniquet group had a wound infection within 10 days of surgery vs. none (0/40) for the no tourniquet group.
Wakankar et al., 1999^124^ | Randomized controlled trial (RCT): (1) Undergo TKA surgery with tourniquet vs. (2) Surgery without tourniquet. | One subject in tourniquet group had an asymptomatic DVT on post-op ultrasonography. | Study found no siginificant differences in the incidence of DVTs or wound complications. Use of tourniquet is safe for TKA.

## What are the Correlates of Functional Outcomes?

We differentiated “indications for TKA” from “correlates or factors related to outcomes.” The former addresses what factors are needed to warrant a TKA (or conversely, what factors are contraindications to TKA either because the procedure is ineffective, unnecessary, or places the patient at unacceptably high perioperative risk); whereas the latter addresses whether outcomes vary according to the clinical or demographic factors. The number of studies that employed any analytic technique examining the functional outcome in terms of at least one independent variable of interest was limited. Table 18 illustrates this point. (Indeed, the list may over-encompass in that it includes any analysis, whether or not the dependent variable came from one of the four functional measures assessed. Also, we counted instances where the analysis was alluded to, even if the results were not specifically shown.) It should be noted that the table is organized such that any study using a combination of variables will also be counted for an individual variable. Thus, a total of only 12 of the 69 studies used any analysis that directly assessed the relationship of these patient variables to a change in functional status. The descriptor most frequently used in an analysis was BMI, followed closely by age and the type of arthritis. In some instances, the report indicated an explored relationship but the specific statistical details of the analysis were not given.

Table 18. Number of studies that include potential correlates of function

Potential Correlates | Number of Studies
BMI | 6
Age | 7
Arthritis | 3
Gender | 5
Age and gender | 6
Age, gender, BMI | 4
Any | 12

Table 19 summarizes the results from the few studies that examined the relationship between patient characteristics and outcomes. Neither age nor obesity seems to be significantly correlated with TKA outcomes. In one small study, patients over age 80 (n=35) had similar improvement in pain, function, and stiffness after six month followup compared with patients less than age 80 (n=221) as evaluated by the WOMAC. Another study by Stickles (n=962) reported a trend toward greater improvement from baseline WOMAC with higher BMI (57 percent improvement from baseline for BMI >40 vs. 36 percent for BMI <25; p=0.08 for trend). In one study of 120 subjects, those with rheumatoid arthritis (n=81) had a greater percent improvement from baseline in HSS than those with osteoarthritis. However, most of these analyses examined only one independent variable at a time in simple bivariate analyses. For example, obese patients and those with rheumatoid arthritis had lower (worse) WOMAC scores compared with less obese patients or those with osteoarthritis. Therefore, improved scores at followup could be due to more severe disease preoperatively rather than the type of arthritis or presence of obesity. The few studies that did use more sophisticated statistical methods reported on followup results at one year or less but deserve further attention. Table 20 summarizes the five studies that used multiple regression analyses. All but the study by Hawker evaluated fewer than 300 subjects. The Jones study employed stepwise regression, which may eliminate variables whose contribution is accounted for by another variable.^26^ They used separate models for the two components of the WOMAC score. For pre/post change in pain the authors found no significant relationship for age, sex, and BMI at six month followup in patients with predominantly osteoarthritis. The significant patient predictor was preoperative bodily pain (from the SF-36). Other significant predictors were hospital length of stay and use of a cementless prosthesis. For change in function, the three patient factors (age, sex, BMI) were also not significant predictors. In this case, the significant predictors of function were length of hospital stay and preoperative pain, as well as preoperative joint pain and the number of comorbid conditions. That is, patients with a longer length of hospital stay, greater preoperative pain, and comorbid conditions had a larger improvement in function.

Table 19. TKA outcomes scores based on age, gender, BMI-index/obesity, and type of arthritis

Study/Group, n (baseline) | Outcome Instrument | Baseline Score | Followup Score | Percent Improvement*/ p-value Between Groups (scores)
Age (n=2 studies)
Jones et al., 2001 ^96^ | WOMAC** | | Followup = 6 months
Age < 80 years (n=221) | pain | 44 ± 18 (sd) | 78 ± 19 | 77%
Age = 80 years (n=35) | pain | 41 ± 16 | 73 ± 20 | 78% / p = 0.17
Age < 80 years (n=221) | function | 43 ± 18 | 72 ± 18 | 67%
Age = 80 years (n=35) | function | 38 ± 12 | 66 ± 17 | 74% / p = 0.09
Age < 80 years (n=221) | stiffness | 39 ± 21 | 64 ± 22 | 64%
Age = 80 years (n=35) | stiffness | 43 ± 21 | 65 ± 23 | 51% / p = 0.78
Diduch et al., 1997 ^61^ | | | Mean followup = 8 years
Age = 55 (n=88) | HSS† | 55 ± 11 (sd) | 92 ± 6 | 67%
Gender (n=1 study)
Hawker et al., 1998 ^29^ | | | Followup = 2–7 years
Men (n=172) | WOMAC | 51.9 ± 1.8 (se) | 19.6 ± 2.5 (se) | 62.0%
Women (n=315) | WOMAC | 61.0 ± 1.6 (se) | 17.9 ± 1.6 (se) | 70.7%
Obesity/Body Mass Index (BMI) (n=2 studies)
Stickles et al., 2001 ^97^
BMI (kg/m2) | | | Followup = 1 year
< 25 (n=146) | WOMAC | 57.0 | 77.5 | 36%
25–30 (n=304) | WOMAC | 53.7 | 77.1 | 44%
30–35 (n=271) | WOMAC | 49.9 | 73.0 | 46%
35–40 (n=149) | WOMAC | 46.8 | 72.1 | 54%
> 40 (n=92) | WOMAC | 46.9 | 73.6 | 57% / p = 0.0819
Griffin et al., 1998 ^110^ | | | Followup = 10 years
Obese-BMI > 30 (n=22) | HSS | 47.7 | 88.3 | 85%
Nonobese-BMI < 30 (n=34) | HSS | 55.0 | 90.3 | 64%
Type of Arthritis (n=3 studies)
Harwin, 1998 ^102^ | KS†† | | Mean followup = 5.1 years
OA (n=241) | knee score | 42 (33–60) | 92 (80–98) | 119%
RA (n=109) | knee score | 32 (16–48) | 86 (72–92) | 168%
OA (n=241) | function | 52 (40–66) | 90 (72–98) | 73%
RA (n=109) | function | 28 (16–60) | 68 (52–80) | 143%
Regner et al., 1997 ^67^ | | | Mean followup = 6.8 years
OA (n=39) | HSS | 46 ± 8 (sd) | 84 ± 8 | 83%
RA (n=81) | HSS | 39 ± 10 | 81 ± 11 | 108%
Elke et al., 1995 ^76^ | KS | | Followup = 4.5–9.8 years
OA (n=300) | knee score | -30 (from graph) | 87 | 190%
RA (n=43) | knee score | -21 (from graph) | 77 | 260%
OA (n=300) | function | -50 (from graph) | -65 (from graph) | 30%
RA (n=43) | function | -40 (from graph) | -67 (from graph) | 68%

* from last followup

** WOMAC = Western Ontario and McMaster Universities Osteoarthritis Index

†HSS = Hospital for Special Surgery

††KS = Knee Society

Table 20. TKAR studies using multiple regression modeling

Study | N | Independent Variables of Interest Assessed | Findings
Jones, et al., 2001 ^96^ | 247 (pain) | Age (continuous) | Regression models were run for changes in pain and function. The dependent variables were pain and function measured by the WOMAC (calculated as the difference between preoperative and 6-month post-operative scores).
Stepwise multiple linear regression | 248 (function) | Sex (female) | Change in pain: Regression analysis found age and female sex were not significant predictors for change in pain at 6 months. Change in function: Age, female sex, and BMI were not significant predictors for change in function at 6 months.
| | Body mass index (BMI) | Change in function: Age, female sex, and BMI were not significant predictors for change in function at 6 months.
| Model for change in pain
| Variable | Coefficient Unstandardized (95% CI) | Coefficient Standardized | P value
| Intercept | 52.41 (26.07 to 78.75) | | <.001
| Age | 0.01 (-0.24 to 0.42) | 0.03 | .58
| Female | -1.10 (-6.30 to 4.11) | -0.03 | .68
| Waiting time | 0.01 (-0.02 to 0.04) | 0.05 | .40
| Length of stay | -1.31 (-2.64 to -0.01) | -0.12 | .05
| Preop bodily pain (SF-36) | -0.42 (-0.56 to -0.27) | -0.35 | <.001
| Number of comorbid conditions | -0.67 (-1.96 to 0.62) | -0.06 | .31
| Cementless prosthesis | -9.48 (-16.20 to -2.77) | -0.17 | .01
| Model for change in fuction
| Variable | Coefficient Unstandardized (95% CI) | Coefficient Standardized | P value
| Intercept | 74.42 (44.57 to 103.91) | | <.001
| Age | 0.06 (-0.25 to 0.38) | 0.03 | .69
| Female | 0.43 (-4.47 to 5.34) | 0.01 | .86
| Waiting time | -0.002 (-0.03 to 0.02) | -0.01 | .86
| Length of stay | -1.33 (-2.53 to -0.13) | -0.13 | .03
| Preop joint pain (WOMAC) | -0.43 (-0.57 to -0.28) | -0.38 | <.001
| BMI | -0.31 (-0.71 to 0.10) | -0.09 | .14
| Contralateral joint involvement | -1.68 (-5.27 to 1.91) | -0.05 | .36
| Lives alone | -3.04 (-8.43 to 2.34) | -0.07 | .27
| Number of comorbid conditions | -1.56 (-2.74 to -0.37) | -0.16 | .01
| Preop bodily pain (SF-36) | -0.21 (-0.35 to -0.07) | -0.19 | .003
| (from Jones et al., Arch Intern Med, Vol 161, Feb 12, 2001, pp 454–60)
Study | N | Independent variables of interest assessed | Findings
Deshmukh et al., 2002 ^27^ | 180 | Age | Regression models were run for changes in pain and function measured by the KS** (change in scores at 12 months). BMI accounted for only a small percentage of variation in the outcome scores indicating body weight did not negatively influence the outcome of total knee arthroplasty at followup in the short-term.
Hierarchical multiple regression | | Sex
| | BMI/Obesity
Fortin et al., 1999 ^28^ | 106 | Age | Regression models were run for changes in pain and function measured by the WOMAC (6-month post-operative scores).
Multiple linear regression | | Sex | Change in pain: Regression analysis found age and sex were not independent predictors for change in pain at 6 months.
| | | Change in function: Age and sex were not independent predictors for change in function at 6 months.
Hawker et al., 1988 ^29^ | 1193 (All) | Demographic characteristics | Regression analyses were used to evaluate factors related to knee pain, knee function, and satisfaction with knee replacement. Pain and function were measured with the WOMAC.
Stepwise multiple linear regression | 362 (Indiana) | BMI | Pain: Age, gender, and BMI-index were not significant predictors of pain in the knee (bivariate analyses).
Note: Only independent variables that showed a significant association with the dependent variable in bivariate analyses were included in the final set of variables. | 344 (Pennsylvania) | | Physical function: A lower BMI was a predictor of better physical function after TKA. Age and gender were not significant predictors of physical function (bivariate analyses).
| | | Satisfaction with knee replacement: A greater BMI index was a predictor of lower level patient satisfaction with knee replacement. Pennsylvania sample odds ratio (OR) = 0.90 (95% CI 0.82 to 0.98) and Indiana sample. OR = 0.91 (0.83 to 1.00).
Heck et al., 1998 ^72^ | 291 | Age | Logistic regression modeling was used to determine improvement in the SF-36 physical health status at 2-years followup.
Logistic regression modeling | | Gender | Age (older patients) was a significant predictor of improvement of physical health (OR = 1.09, CIs not provided).
| | Race
Konig et al., 1998) ^30^ | 249 | Age | Regression analyses were used to evaluate factors related to knee pain, knee score and function measured by the KS at 2-years followup.
Multiple linear regression | | Sex | Pain: Age, gender, and BMI-index were not significant predictors of regression
| | BMI | Knee score: Age, gender, and BMI-index were not significantly correlated with the knee score at last followup.
| | | Function: BMI correlated (p < 0.0025) with function at last followup.

The study by Deshmukh employed hierarchical multiple regression but did not show the actual results.^27^ In looking at changes in function and pain at 12 months post TKA as measured by the KS score, the authors controlled for age and sex. Their results indicated that BMI accounted for only a small amount of the explained variance.

Fortin et al. used multiple linear regression analysis to examine the effects of age and gender on WOMAC scores at six months.^28^ There were no significant relationships between these characteristics for either pain or function.

A large study comprised primarily of Canadian women with osteoarthritis analyzed several sources of data in a stepwise multiple regression model with WOMAC scores as the dependent variable.^29^ They found that age, gender, and BMI were not significant predictors of knee pain. However, a lower BMI did predict better physical function and greater satisfaction with the procedure.

The study by Konig used multiple linear regression analysis to assess KS scores at two years.^30^ Age, gender, and BMI were not significantly related to pain or the overall KS scores. However, BMI did correlate with function.

## Does Access to TKA Vary with Race and Gender?

The six studies that addressed TKA-related access issues according to race or gender are shown in Table 21. Several of these studies included both hip and knee replacement surgery. Most of the studies that address access relied on large administrative data sets, which did not contain detailed clinical data on which to base the indications for knee surgery. However, some of these studies had at least some clinical information on the underlying problems of the sample being studied. Dunlop used the AHEAD data set, which has self-reported conditions including arthritis.^31–33^ Hawker identified persons with arthritis as the basis for their sample.^31^ Wilson limited their study to Medicare beneficiaries with a diagnosis of osteoarthritis.^33^

Table 21. Gender/racial disparities in total knee arthroplasty studies

Study | Population Focus; N | Objective | Results
Dunlop et al., 2003^32^ | Racial groups, USA | Focus on health conditions/economic access to explain differences in joint arthroplasty (JA) | Older blacks and Hispanics were less likely to use JA compared to whites. Annual rates for JA were 1.48 (95% CI 1.24–1.72) for whites, 0.98 (95% CI 0.39–1.56) for blacks, 0.97 (95% CI 0.01–1.93) for Hispanics. The odds ratio (OR) for JA, black/Hispanics vs. whites, was 0.37, 95% CI 0.20–0.71] after controlling for demographics, arthritis, and other health needs.
| KNEE AND HIP | | Conclusion: JA was not explained by differences in health needs/economic access
| n=6,159 subjects aged 69 to 103 years with arthritis (AHEAD participants)
Hawker et al., 2000^31^ | Gender, Canada | Gender differences in the need for knee arthroplasty (TKA) and willingness to undergo procedure | Versus men, women had worse symptoms and greater disability but were less likely to receive TKA [OR = 0.54, 95% CI 0.21–0.80, adjusted for age and self-reported arthritis or osteoporosis], and were less likely to discuss getting TKA with a physician despite equal willingness to have surgery [OR = 0.63, 95% CI 0.44–0.90]. The potential need for JA was 45 persons per 1000 for women and 21 persons per 1000 for men.
| KNEE AND HIP | | Conclusion: Degree of underuse for arthoplasty is greater than 3 times for women. Authors propose barriers, perceived or actual, exist at the level of the interaction between primary care physician and the patient in the process of referral to orthopaedic surgery.
| n=2,411 subjects aged >55 years with arthritis
Katz et al., 1996^125^ | Gender and racial, USA | What demographic variables are determinants of area TKA rates | TKA more likely in women than men [OR = 1.95, No CIs]
| KNEE | | Black women vs. black men, OR= 1.66
| n=414,079 of Medicare beneficiaries | | White women vs. white men, OR= 1.24
| | | White men vs. black men, OR = 2.50
| | | White women vs. black women, OR = 1.16
| | | Conclusion: Variation in TKA rates unexplained
McBean & Gornick, 1994^126^ | Racial, USA | Explore differences by race in the rates of TKA and other procedures performed in hospitals for Medicare beneficiaries | Rates for TKA for blacks and whites in 1986 were 1.21 and 2.11 per 1,000 enrollees, respectively. The rates in 1992 for blacks and whites were 2.68 and 4.17, respectively. The black vs. white ratios for TKA were 0.57 in 1986 and 0.64 in 1992.
| n=52,501 (1986) | | Conclusion: Black beneficiaries were less likely to receive TKA than whites. The difference in TKA rates suggests barriers to TKA and other “referral sensitive” surgeries.
| n=111,475 (1992)
| Data were derived from MedPAR (Medicine Part A data file)
| Age ≥ 65
Wilson et al., 1994^33^ | Gender and racial, USA KNEE | Determine differences in the use of TKA among black and white Americans and investigate whether clinical/economic factors contribute to these differences | Findings showed blacks received TKA less often than whites although blacks had higher rates (nonsignificantly) of OA of the knee than whites. Mean annual rates of TKA for 1984-1988 were 112.6 per 100,000 and 35.6 per 100,000 for white and black men, aged 65–69, respectively. The white vs. black rate ratio was 3.16 (95% CI 1.69–5.91). For women aged 65–69, the mean annual rates of TKA were 141.8 per 100,000 for whites and 91.5 per 100,000 for blacks, with a rate ratio of 1.55 (95% CI 1.00–2.41).
| n=290,675 from several databases, including Medicare and the National Hospital Discharge Survey | | Conclusion: Although blacks have higher rates of knee OA they are not treated with TKA as often as whites. Racial differences do not appear to have an economic basis. Future research should focus on non-clinical and non-economic factors of the inequality of TKA procedures between blacks and whites.
| Age >65 with osteoarthritis (OA)
Escarce et al., 1993^127^ | Racial, USA | Examine racial differences in the use of medical procedures amongst Medicare enrollees | Rates for TKA for whites and blacks were 18.2 and 8.9 per 1000, respectively. RR for whites vs. blacks was 2.02 [95% CI 1.63–2.49], adjusted for age and sex.
| Several Medical procedures, including KNEE | | Conclusion: Race may exacerbate the impact of other barriers (eg. financial) to access to medical procedures.
| n=1,309,474 from Medicare beneficiaries
| Age ≥ 65

The conclusions with regard to the differential treatment of women are mixed, but the preponderance of evidence suggests that women are almost twice as likely to undergo a TKA as men. The evidence regarding non-white groups is quite consistent. Non-whites receive TKAs about half as often as whites. Table 22 summarizes that evidence. With the exception of those by Hawker, Dunlop, and Wilson, studies address simply the rate at which the procedures were performed, with no attention to the actual size of the population at risk.^31–33^ The results are often expressed as odds ratios, which compare the risk of one group receiving the procedure with that of another group. The argument that the higher rates of TKAs in women may be due to the higher prevalence of arthritis among women does not apply to the study by Wilson, which examined only persons with arthritis. However, it is possible that the severity or type of arthritis (OA vs. RA) varied. Conversely, the lower rates of TKAs among blacks occurred despite a higher prevalence of osteoarthritis in this group, suggesting that the prevalence of osteoarthritis was not a mitigating factor. The study by Wilson looked at race and gender simultaneously. They report the odds ratio of race for TKA is almost the same for men (0.32) and women (0.37), and conversely the odds ratio of female gender for whites (1.26) is less than for nonwhites (2.57).

Table 22. Summary of race and gender effects on TKA rates

| Odds Ratios
| Nonwhite/White | Women/Men
Dunlop et al., 2003^32^ | 0.37 (0.20–0.71)
Hawker et al., 2000^31^ | | 0.54 (0.21–0.80)
Katz et al., 1996^125^ | 0.40 (Male) | 1.95
| 0.86 (Female)
McBean & Gornick, 1994^126^ | 0.57 (1986)
| 0.64 (1992)
Wilson et al., 1994^33^ | 0.32 (0.59–0.17) (Male) | 1.26 (White)
| 0.37 (0.7–1.0) (Female) | 2.57 (Black)
Escarce et al., 1993^127^ | 0.49 (0.4–0.61)

## Total Knee Arthroplasty Revisions (TKAR)

(Summary and Update of the Systematic Review by Saleh et al., 2002)

Like all biomedical devices, total knee replacements can fail over time.^34^ The primary factors believed to cause TKA failures (and thus require consideration for TKA revision-TKAR) include trauma, chronic progressive joint disease, prosthetic loosening, and infection of the prosthetic joint. Coincident with the increased incidence of primary TKA, there has also been an increase in the number of TKAR procedures.^35^ In 2001 Medicare paid for 16,895 TKAR procedures.^9^ The number of TKAR procedures is expected to continue to increase by approximately 14 percent annually as a result of complications associated with TKA, including infection, fracture, and time-dependent implant failure that necessitate re-operation.^36^

As noted earlier, information on indications differs from that for outcomes by requiring a broader set of observations with which to distinguish the clinical outcomes for those treated and untreated. Unfortunately, the data for TKAR is even more limited than for primary TKA. There are limited long-term TKAR outcome data reporting knee specific or global knee scores. Callahan et al defined a generic global knee score as “an instrument that measured patient outcomes in the domains of pain, function, and range of motion and combined these domains in a summary scale.”^5^ Examples of such scales include the Hospital for Special Surgery score (HSS) and Knee Society (KS) score. However, we also grouped over 30 other knee instruments that measure the same domains that under the same heading.

The primary assessment of the outcomes of TKAR for this report is derived from a systematic review of the literature published through 2000 that was done by one of the principals (shown as Appendix E). Additionally, we updated this report with articles published through June 2003. The objective of the original systematic review was to describe patient outcomes following TKAR procedures using GKS ratings. English Language articles published from 1966 through 2000, were identified through a computerized literature search and bibliography review. The specific aim was to describe patient outcomes following TKAR procedures by using GKS to address the following questions:

- Does TKAR improve function as measured by increase in GKS?
- Is there correlation between outcomes and preoperative disease severity as measured by GKS?
- What proportion of TKAR subjects attains excellent/good (E/G) postoperative results and what proportion attains satisfactory/poor (S/P) results?
- Does the proportion of subjects with E/G results, or the postoperative HSS score / KS score, vary with the length of followup, the year of study publication, or preoperative diagnosis (i.e., infection, loosening, etc.)?
- Is there a difference between the multiple and single knee revision cohorts in the percentage of subjects that attain E/G postoperatively?
- Is there a difference between the multiple and single knee revision cohorts in the preoperative HSS or KS scores or the score increases?

We report a summary of the results from the original systematic review and then describe findings from our review update of new articles published between 2000 and June 2003.

### Does TKAR improve GKS and is this improvement related to preoperative disease severity?

There was a large improvement in GKS scores following TKAR that was both statistically and clinically significant. As noted earlier, the KS score can be subdivided into pain and function subscores. The preoperative combined mean KS score was 35.4 (95% CI 30.7–39.9). There was an increase of 30.8 (95% CI 26.6–35.0) points to 66.2 (95% CI 61.8–70.2) points postoperatively (p <0.0001). The preoperative functional mean KS score was 30.4 (95% CI 22.8–37.9) with an increase of 27.0 (95% CI 21.8–32.2) points to 57.4 (95% CI 51.6–62.7) points postoperatively (p <0.0001); the preoperative clinical mean KS score was 32.8 (95% CI 25.5–40.0) with a highly significant increase of 42.1 (95% CI 39.2–45.0) points to 74.9 (95% CI 68.6–80.8) points postoperatively (p <0.0001). The latter two subscales were on a subset of the 15 studies on which combined results could be calculated. The preoperative mean HSS score was 51.5 (95% percent CI 48.9–54.1). There was an increase of 28.3 (95% CI 25.3–31.2) points to 79.8 (95% CI 76.4–83.1) points postoperatively (p < 0.0001). However, we found no significant correlation between the preoperative score and the amount of improvement in either the overall KS (r = -0.09, p >0.7) or the HSS (r = -0.263, p >0.3) studies suggesting that improvement in symptoms were not associated with preoperative knee status.

### Do patients undergoing multiple TKARs have more severe disease as judged by preoperative GKS scores compared with single TKAR cohorts?

Although there was no difference in age or gender between the multiple and single knee reports, there was a significant difference in preoperative HSS. Patients undergoing “multiple knee TKAR” had lower preoperative scores (multiple knee HSS = 49.5, 95% CI 45.9–53.2; single knee = 54.5, 95% CI 51.4–57.5; p <0.1). These results suggest that the multiple knee cohorts may have more severe disease then subjects evaluated in single knee TKAR studies. In contrast, the preoperative combined mean KS score in the multiple knees group was higher (77.0, 95% CI 64.2–89.8) than the single knee group (59.85, 95% CI 45.2,-4.5), p >0.1. This result, however, was heavily influenced by a very low preoperative combined score of 32.8 (25.5–40.0) in one large study (n = 574 subjects or 598 knees).^37^

### Do outcomes vary between multiple and single TKAR groups as measured by KS or HSS?

There was no difference in the pooled change in either the KS or HSS from pre- and postoperative scores when comparing subjects undergoing multiple vs. single TKAR ([KS multiple knee = 60.0, 95% CI 49.4–70.5; KS single knee = 64.4, 95% CI 50.3–78.5; nine studies and 953 patients/1,001 knees. [HSS multiple knee = 28.9, 95% CI 25.5–32.3; single knee HS = 27.2, 95% CI 22.5–32.0; ten studies and 1,010 patients/1,050 knees. The mean difference in both GKS increased over time up to around 60 months. Thereafter KS (Figure 2) and HSS marginally declined (Figure 3).

Figure 2. Mean increase in Knee Society scores from each cohort (postoperative less preoperative scores) as a function of postoperative followup (months) for subjects undergoing TKA revision surgery

Figure 3. Mean increase in Hospital Special Surgery scores (postoperative less preoperative scores) for each cohort as a function of postoperative followup (months) for subjects undergoing TKA revision surgery

### What proportion of TKAR subjects attains excellent/good (E/G) results postoperatively as measured by GKS? Do results vary between the multiple and single knee cohorts, length of followup, or presence of infection as the proximate cause for revision?

The percentage of subjects undergoing TKAR who attained a self-reported E/G result postoperatively was 77.7% (95% CI 75.2–80.2). In studies reporting on cohorts where some subjects had both knees revised the percentage of subjects attaining E/G was 72.7% (95% CI 69.5–76.3). In comparison, in studies where no subjects had multiple knees revised, the proportion of E/G was 82.6% (95% CI 79.1–86.3) p <0.05).

Patients undergoing single TKAR had better postoperative scores than those receiving multiple TKAR. Additionally, the percentage of subjects reporting E/G results increased over followup duration until approximately 60 months (Figure 4). There was a difference in the proportion of subjects reporting an E/G outcome between articles in which a higher percentage of patients with infection as the proximate cause for revision as compared to those in which fewer patients were infected (p < 0.05). Series reporting outcomes from uninfected patient had a higher proportion of subjects with E/G outcomes compared to subjects from “infected series” (percent E/G uninfected = 78.5%; 95% CI 74.7%–82.3%; % E/G infected = 67.5%; 95% CI 61.5%–73.4%).

Figure 4. Proportion of subjects undergoing TKA revision surgery in each cohort self-rated as excellent or good as a function of postoperative followup (months)

### What is the complication rate following TKAR?

The results from our systematic review (as well as a previous review by Callahan and colleagues) demonstrate that the revision rate after about four years of primary TKA is approximately 3–4%. Forty-four of 46 (95.7%) cohorts reported complication data on 1,683 subjects who incurred 443 complications (26.3%). It was not possible to determine which or how many complications occurred in any given patient or patient subset. There were a total of 217 knee complications in 1,683 subjects necessitating re-revision (12.9%). Using a broad definition of complications, Callahan et al. found a 30% overall complication rate and a 7.2% revision rate in 18 bicompartmental knee arthroplasty reports with 884 enrolled patients and an 18.5% overall complication rate and a 9.2% revision rate in 46 unicompartmental knee arthroplasty (UKA) reports with 2,391 enrolled patients.^38^

### Updated findings of the TKAR report

We updated the previous review by Saleh et al. to include articles published from 2000 through June 2003. An additional 27 articles were identified of which 14 (n = 638 knees) met inclusion criteria. They are summarized in Table 23. The updated findings do not alter the conclusions of the original report just described. They do add additional information related to various types of revision knee systems or surgical procedures. Descriptions of the individual reports are provided below.

Table 23. Updates on total knee revision studies

Reference | Measure | N | Outcomes | Followup | Age | Gender | Arthritis | Notes
Gofton et al., 2002^43^ | KS-Pain, function, total | 97 Revision TKAs | Preop: | Followup mean=4.7 months (2–11.2) | Mean 69.1 (41.1–81.5) | Male=32 | 71=OA | Review of midterm results of contemporary revisions knee systems with alternative design features fixed with hybrid cementing. All components cobalt chromium alloy comparing posterior stabilized vs. varus/valgus constrained articular inserts.
| | -6 Attrition | 1) Posterior stabilized-KS pain=16 ± 13 | 1) Posterior stabilized-KS: Pain=38 ± 14 | | Female=52 | 10=RA | Findings: Found no difference in post-op KS though there was a difference in preop KS: Post stabilized=91±38, Varus/Valgus=73±41
| | -2 death | Function=44 ± 24 | Function=57 ± 29 | | | 3=TA
| | =89 | Total=91 ± 38 | Total=137 ± 39
| | 59 posterior stabilized, | 2) Varus/ valgus-KS: Pain=15 ± 15 | 2) Varus/valgus stabilized
| | 30 varus/ valgus stabilized | Function=34 ± 24 | Pain=39 ± 14
| | | Total=73 ± 41 | Function=44 ± 28
| | | | Total=123 ± 42
Nazarian et al., 2002^44^ | KS | 227 TKAs | Preop KS Average for all 4 groups=52 (37–70) | Postop followup=mean 4.7 months (2–11.2) | Mean=67 (43–84) | Male=105 | OA/RA/post traumatic osteonecrosis | Objective: Compare retrospectively the results of TKAR constrained condylar knee implant with and without intramedullary stems. Groups I–IV showed marked improvement in post-op KS though there was no statistically significant difference between groups. No correlation with other factors.
| | -20 | | Group I-with femoral/tibial stems KS=82 | | Female=75
| | =207 in study | | Group II-femoral stem only KS=85
| | | | Group III-tibial stem only KS=84
| | | | Group IV not reported
Brooks et al., 2002^39^ | HSS overall and HSS instability portion (max=10 patients) | 16 patients with tibiofemoral instability treated with polyethylene exchange | Preop HSS= 51.7(20–71) | Average followup=56 months | Average=54 (28–75) | Male=5 | - | The study found treatment of tibiofemoral instability with TKAR via polyethylene exchange only to be effective in certain types (I–IV) of instability:
| | -2 attrition | HSS instability= 4.1 (0–8) | HSS mean= 75.29 (50–97) | | Female=9 | | I=Ligaments competent and unbalanced.
| | =14 remaining in study | | HSS instability= 9 (5–10) | | | | II=Ligaments incompetent.
| | | | | | | | III=Flexion/extension gap mismatch
| | | | | | | | IV=combined instability pattern.
| | | | | | | | Found to be effective in types II and III (statistically significant)
Springer et al., 2001^51^ | KS pain, function and KS scores | 77 knees (Kinematic Rotating Hinge) | Preop KS score average= 40.3 (2–93) | Followup KS Knee score | Average=72 (46–89) | Male=23 | - | Recommended that knee rotating hinge TKA be reserved for final salvage option when performing complex primary or salvage TKAR
| | -6 knees attrition | | Category A- 32 patients | | Female=35 | | -Found no significant difference in improvement upon KRH revision between groups A,B,C in KS scores.
| | =69 Kinematic Rotating Hinge remaining | | Unilateral or bilateral TKA=81.9 (54–99) | | | | -No improvement in KS pain score for category A/C or significant Improvement for B
| | 57 Revisions | | Category B- 11 patients unilateral TKA + symptomatic conralateral. Knee.=57.2 (33–94) | | | | -No significant Improvement is KS function score for A,B,C
| | 12 Primary | | Category C-26 patients multiple arthridities or medical infirmity=79 (44–99)
Benjamin et al., 2001^46^ | KS | 33 patients (# knees not reported)-all patients had morselized grafting to reconstruct tibial and femoral defects in revision TKA | Preop KS scores for morselized graft TKAs (revision)=28–35 | Post-op (2 year average) KS scores with morselized graft TKA revision.= 62–79 | - | - | OA=27 | Study compared KS scores of patients with and without morselized bone grafting for tibial or femoral defects in patients undergoing TKARwith one revision knee system
| | | For patients without morselized graft TKAs (revision)=28–35 | KS scores without morselized graft TKA revision=53–75 | | | RA=6 | -No statistical significance in KS scores found
Parviz et al., 2002^49^ | KS pain and function scores | 37 knees | Group I-Isolated patellar component resection-preop KS pain = 49, function = 48 | Average followup=7.9 years (2–18 years) | Average=66.6 (32–85) | Male=17 | OA=27 | Objective: Evaluate clinical and functional results of patella resection arthroplasty for severely compromised patella for which insertion of another patellar component was not possible.
| | -2 deaths | Group II-Patellar resection + revision of tibial and/or femoral component-preop KS pain = 50, function = 49 | Group I-post-op pain=51, function= 50 | | Female=14 | RA=6 | Findings: No statistically significant difference found between Groups I and II without KS function score post-op KS function scores were better for patients in group II post-op
| | =35 knees | | Group II postop-pain= 66, function= 56 | | | Osteonecrosis=1 patient
| | | | | | | Post traumatic arthritis=1 patient
Lonner et al., 2002^45^ | KS clinical and function scores | 17 knees | Pre-op KS clinical-average= 49 (7–84) | Followup average= | Average= 68 (59–79) | Male=13 | - | Evaluated the short term results of cancellous allografting + molded wire mesh for massive uncontained defects about the knee.
| | | KS functional-average= 48 (20–80) | 3 months KS clinical-average= 95 (88–99) | | Female=4 | | Findings: found to be an effective method of treatment for the above
| | | | KS function= 73 (60–110) | | | | No statistical analysis.
Jones et al., 2001^26^ | HSS | 19 knees | Preoperative HSS=43.6 | Followup=47 months (27–71) | Mean=63 years (33–83) | Male=4 | OA=7 knees | Sought to delineate the success of S-ROM mobile bearing hinge prosthesis under appropriate conditions (severe instability/bone loss)
| KS pain | -3 deaths | KS pain=33.6 | HSS=70.8 | | Female=11 | RA=6 knees
| KS function | 16 knees in study | KS function=29.2 | KS pain=76.5 | | | Post-traumatic=2 knees
| | | All revisions were with the S-ROM mobile bearing hinge prosthesis | KS function=43.5
| | | | All revisions were with the S-ROM mobile bearing hinge prosthesis.
Christensen et al., 2002^42^ | KS | 11 | 39 | Followup=37.6 months | 62.1 | Male=1 | OA=10 | Evaluates improvement in range of motion and KS scores after revision total knee arthroplasty
| | | | KS=66 | | Female=10 | RA=1
Hanssen, 2001^47^ | KS | 8 | 39.5 | Followup=36 months | 65.9 | Male=5 | OA=7 | Surgical technique for severe patellar bone loss during TKAR
| | | | KS=88 | | Female=3 | RA=1
Babis et al., 2002^40^ | KS | 56 | 53 | Followup=4. 6 years | 66 | Male=29 | | Isolated tibial insert exchange leads to early failure rates
| | | | KS=68 | | Female=26
Leopold et al., 2003^48^ | HSS | 40 | 72 | Followup=62 months | | | | Isolated revision of the patellar component in revision TKA
| | | | HSS=87
Miller et al., 2002^41^ | KS | 38 | 50 | Followup=6 months | 71 | Male=23 | OA=29 | UKR to TKA vs. primary TKA comparing PCL substituting and PCLsparing
| | | | KS=68 | | Female=11 | RA=2
Werle et al., 2002^50^ | HSS | 5 | HSS=38 | Followup=37 months | 67 | Female=5 | Infection, osteolysis | Use of large distal femoral augments to compensate for structural metaphyseal bone loss in revision
| KS | | KS=22 | HSS=71
| | | | KS=60

Two articles assessed the effectiveness of polyethylene exchange as an isolated revision procedure. Brooks et al. assessed the effectiveness of isolated polyethylene exchange in revision TKA for tibiofemoral instability.^39^ Based on 14 cases, the authors found the procedure to be an effective, low morbidity treatment to treat one type of prosthetic knee instability. Achievement of a successful result with this technique occurs with competent balanced ligaments. Patients with incompetent ligaments or with a significant flexion extension mismatch are less likely to achieve a successful result. Babis et al assessed the results of isolated tibial insert exchange during TKAR in 55 patients (n=56 TKAR).^40^ The study demonstrated that isolated tibial insert exchange led to an unacceptably high early failure rate. The authors recommended that orthopedists proceed with caution in all cases in which isolated tibial insert exchange was being considered.

Miller et al. retrospectively compared UKA revision to TKA with a group of primary TKA.^41^ The study revealed that UKA revisions had a higher incidence of wound infection and less improvement in Knee Society pain and function scores compared to primary TKA. In addition, the study suggested that posterior cruciate ligament (PCL) substituting designs were superior to posterior cruciate ligament sparing designs and had Knee Society pain and function scores that were comparable to the primary TKA group.

Christensen et al evaluated improvements in range of motion and Knee Society pain and function scores following revision TKA in 11 patients who presented with pain and limited range of motion.^42^ The study results indicated that range of motion and Knee Society scores improved significantly following revision TKA.

Gofton et al evaluated the midterm results of revision knee procedures using a modular all-cobalt chrome stem in 97 TKARs.^43^ The study compared posterior stabilized and varus/valgus constrained articular inserts. There were no differences in post-operative KS scores between the posterior stabilized and the varus/valgus constrained groups.

Nazarian et al retrospectively reviewed the results of TKAR using the Insall-Burstein constrained condylar knee implant used with and without intrameduallary stems.^44^ The study found no significant difference in Knee Society scores between the two above noted groups.

Three articles focused on the use of bone grafting in revision TKA. Lonner et al evaluated the short-term results of impaction cancellous allografting and molded wire mesh in the management of massive uncontained defects about the knee in revision TKA.^45^ The authors found it to be an effective method of managing bone defects. Benjamin et al compared the KS scores of patients with and without morselized bone grafting used for tibial or femoral defects in patients undergoing revision TKA with one revision knee system.^46^ The authors found no difference in preoperative or post operative knee scores between the two groups. They concluded that morselized bone grafting is a reasonable alternative in the reconstruction of osseous defects in patients undergoing revision TKA. Hanssen described a surgical technique for restoration of patellar bone stock in patients with severe patellar bone loss undergoing revision TKA.^47^ KS pain and function scores were improved in short to mid-term clinical results.

Two articles evaluated revision/resection of the patellar component in TKAR. Leopold et al followed 40 knees with a Miller Galante I prosthesis that underwent isolated patellar revision of TKA with or without lateral retinacular release.^48^ After a mean followup of 62 months isolated patellar revision with or without lateral retinacular release was associated with an “unacceptably high rate of reoperation and a relatively low rate of success”; the gain in mean HSS score was only from 72 to 87. Parvizi et al undertook a study to evaluate the clinical and functional results of patellar component resection arthroplasty with or without revision of the tibial or femoral components for severely compromised patella for which insertion of another patellar component was not an option.^49^ The study demonstrated that patients treated with isolated patellar component resection arthroplasty were more likely to require reoperation and experience persistent pain when compared with patients who had concomitant revision of the tibial and femoral components.

Werle et al. assessed the use of large (30mm) metal distal femoral augments to compensate for severe structural femoral metaphyseal bone loss in revision TKA.^50^ The study found the technique to be “acceptable” as there were improvements in Hospital for Special Surgery scores, Knee Society scores and ROM upon compilation of intermediate term results (37 months).

Two articles assessed the use of a hinged prosthesis in revision TKA. Springer et al reviewed 69 knees treated with Kinematic Rotating Hinged Knee prosthesis for complex primary TKA and salvage revision TKA.^51^ Based on the study results, the authors recommended that KRH arthroplasty be reserved for final salvage option of the treatment options available when performing complex primary and salvage revision knee arthroplasties. Jones et al undertook a retrospective study to delineate the success of S-ROM mobile bearing hinge total knee prosthesis for revision TKA.^26^ The indication for TKA included severe instability and bone loss. The authors concluded that a satisfactory result can be achieved when using S-ROM mobile bearing hinge total knee prosthesis for the above indications.