# Introduction

Throughout this report the term total knee arthroplasty will be used in lieu of total knee replacement because the abbreviation of the latter term may be confused with total knee revision.

At present, approximately 43 million individuals suffer from arthritis. Because this condition becomes increasingly prevalent with advancing age,^1, ^ ^2^ given the population projections, the Centers for Disease Control estimate that by 2030 over 41 million persons aged 65 and older will have arthritis or chronic joint symptoms.^3^ In particular, arthritis of the knee and accompanying joint symptoms result in considerable morbidity, loss of functional status, independence, and quality of life. The high prevalence of arthritis in the population is reflected in the high cost of treatment, which has been estimated at $95 billion per year.^4^ These figures do not include the additional costs due to lost job productivity. Treatment options are primarily designed to relieve pain and improve functional status.

Standardized instruments have been developed in order to assess the severity of the symptoms and evaluate outcomes related to treatment. For example, Callahan et al., defined a generic global knee score (GKS) as “an instrument that measured patient outcomes in the domains of pain, function, and range of motion and combined these domains in a summary scale.”^5^ Widely used scales include the Hospital for Special Surgery score (HSS),^6^ Knee Society (KS) score,^7^ and Western Ontario and MacMaster University (WOMAC) Osteoarthritis Index.^8^ (Copies of these scales are shown in Appendix A.) These scales typically cover aspects of pain and function (usually emphasizing walking). The HSS and KS are completed by clinicians; the WOMAC and SF-36 are designed to be completed by patients. They are intended to provide a score of 0 to 100, where a higher score implies a better outcome. For at least the HSS and KS scores, less than 60 is considered poor pain and function status; 60–69 represents fair pain and function status; 70–84 is considered good; 85–100 is considered excellent pain and function status.

Treatment options include physical therapy, analgesic and/or anti-inflammatory medications, and surgical therapy. The primary surgical treatment for patients is replacement of the native knee joint with a prosthesis (Total Knee Arthroplasty—TKA). A wide variety of prostheses and surgical techniques have been utilized but all are considered under the category of TKA. Total knee arthroplasty is one of the most common orthopaedic procedures performed. In 2001 171,335 primary knee replacements and 16,895 revisions were performed.^9^ Medicare paid approximately $3.2 billion in 2000 for hip and knee joint replacements. Because these procedures are elective and expensive and because the prevalence of arthritis is expected to grow substantially as the population ages, these procedures are likely to come under increasing scrutiny. By 2030, it is estimated that there will be an 85 percent increase in TKA.^10^ With this growth in mind, as well as the uncertainty related to the indications for, and outcomes associated with TKA, the Minnesota EPC was asked to conduct a systematic review of the literature to address four specific questions:

1. What are the current indications for, and outcomes from, primary total knee replacement?
2. How do specific characteristics of the patient, material and design of the prosthesis, and surgical factors, affect the short-term and long-term outcomes of primary total knee replacement?
3. Are there important perioperative interventions that influence outcomes?
4. What are the indications, approaches, and outcomes for revision total knee replacement?
5. What factors explain disparities in the utilization of total knee replacement in different populations?
6. What are the directions for future research?

The Total Knee Replacement evidence report will help inform the deliberations of the Consensus Conference Panel.

Previous reports suggest that TKA improve functional status, relieve pain, and result in relatively low perioperative morbidity. A systematic review and meta-analysis of 130 studies evaluating 154 cohorts published in 1994 by Callahan and colleagues evaluated patient outcomes following tricompartmental total knee replacement. They noted that global rating scale scores improved by 100% for the typical patient and that 89% of patients reported good or excellent outcomes after a mean followup of 4.1 years. The weighted mean complication rate was 18.1% and the mean mortality rate per year of followup was 1.5%. The overall rate of revision during 4.1 years was 3.8%.^5^

However, based on conclusions from consensus panels or surveys of health care providers, there is considerable disagreement about the indications for the procedure (Tables 1 and 2); that is, which patients are most likely to benefit from TKA and, conversely, in which patients is TKA contraindicated or of low value. For example, there is substantial variation in opinion about the indications for surgery, among orthopaedic surgeons^11–13^ or between orthopaedists and rheumatologists and family physicians,^14–16^ The level of agreement for primary TKA indications is significantly higher among orthopaedists than among family physicians or among rheumatologists.^14^ Efforts at achieving consensus have yielded mixed results. One study found some level of agreement among a consensus panel comprised of specialty and primary care physicians, an epidemiologist, and physiotherapist around criteria such as the patient's pain at rest, severity of functional impairment, problems with caregiving, and perceived likely improvement in function.^17^ Another panel composed of varied specialties found a lack of evidence on which to base decisions, especially the lack of comparison with other forms of treatment including nonsurgical intervention strategies. However, they did propose three “useful variables for surgical decision making”: 1) severity of joint damage as determined by pain at night, severity of pain and function; 2) other patient-related variables (eg, patient motivation and social impact of problems); and 3) the health care system and living environment (patient's socioeconomic status, availability of surgeons).^18^

Table 1. Studies of beliefs about indications, referrals, and thresholds for total knee arthroplasty

Study | Journal | Population focus, N | Objective | Results
Wright et al., 1995^12^ | Can Med Assoc J | All orthopaedic surgeons in Ontario, Canada n=325 | Determine extent of agreement on indications for TKA and how perceptions differ according to the number of procedures performed | - Clinical agreement (>90%) in 14 of 34 patient characteristics (38%) in determining need for TKA
| | | | - Clinical disagreement (<60%) with 7 of 34 (21%) patient characteristics
| | | | - No agreement in treatment with 3 hypothetical case scenarios with varying degrees of osteoarthritis (n=205) (highest agreement was 86.8%)
| | | | - High volume orthopaedists disagreed with low volume orthopaedists in 7 of 34 patient characteristics as indication for TKA (21%)
| | | | - Speculated causes for disagreement:
| | | | 1. may reflect limitation of available knowledge
| | | | 2. may reflect controversy within orthopaedic literature
| | | | 3. information may not be adequately disseminated to, or adopted by, practicing orthopedists despite the fact that the factor's effect on outcome of TKA has been clearly demonstrated in the medical literature
| | | | 4. surgeons may choose to treat patients based on personal experience or training
Coyte et al., 1996^14^ | J Rheum | Rheumatologists and family practitioners n=98 Rheumatologists, 250 family practitioners (66 & 99 in final analysis respectively) | Assess agreement for indications for TKA, outcomes of TKA, and non-surgical management of osteoarthritis between family practitioners and rheuma-tologists. These results were to be compared with data on orthopaedists | - Clinical agreement (>90%) for BOTH rheumatologists and family practitioners with 2 of 32 patients factors
| | | | - Rheumatologists clinical agreement (>90%) with 6 of 32 (13%) patients factors
| | | | - Family practitioners Clinical agreement (>90%) with 4 of 32 (19%)
| | | | - Clinical disagreement (<60%) with 10 of 32 factors for family practitioners
| | | | - Clinical disagreement (<60%) with 10 of 32 factors for rheumatologists
| | | | - Disagreement among specialties: Family practitioners > rheumatologists > orthopaedists (family practitioners & orthopaedists P<0.0001, rheumatologists & orthopaedists P<0.04).
Wright et al., 1999^15^ | Medical Care | Orthopaedists and primary care physicians n=(Provider data from Wright et al., 1995 in Can Med Assoc J and Coyte et al., 1996 in J Rheum) [See both studies above for provider numbers] | Identify factors that might be amenable to intervention by investigating determinants of regional variation in the use of knee replacement surgery | - Surgeon opinion or “enthusiasm” was “the dominant modifiable determinant of area variation” in the utilization of TKA
| | | | - Surgeons propensity to operate (based on responses to the survey in the article cited above) and opinions on patient outcome were both positively correlated with the total # of procedures performed in the study period (p<0.0001)
Hadorn & Holmes, 1997a, 1997b^19,^ ^20^ | BMJ | New health policy description | Describes New Zealand's new priority criteria for major joint replacement (TKA & THA) | - Checklist utilizes 4 major components incorporating both clinical and social factors in determining order for receiving TKA: Pain (40% of scale), Functional Activity (20%), Movement and deformity (20%), Other factors (20%)
| | | | - Checklist created to assess where patients would be placed on list for elective surgeries prior to New Zealand moving away from waiting list format to booking appointments
Mancuso et al., 1996^13^ | J Arthroplasty | Orthopaedists n=328 (80 in final analysis) | Survey of all orthopaedists in specific geographic area regarding their indications and modifying factors for primary TKA and THA | - Clinical agreement (>90%) with 6 of 24 (25%) factors related to determining need for TKA
| | | | - Clinical disagreement (<60%) with 3 of 24 (13%) factors related to determining need for TKA
| | | | - They found no correlation with # of years in practice and agreement
Dieppe et al., 1999^18^ | Rheumatology | Review article: consensus panel of professionals to examine problems re: use of TKA in management of osteoarthritis | “review literature of effectiveness of TKA for osteoarthritis of the knee, the evidence of practice variation and underutilization, and the publications on possible indications for TKA” | - Primary care MDs likely to lack confidence in the exam of the knee joint leading to delays in diagnosis and inability to assess severity of joint damage due to little exposure in training
| | | | - 4 potential problems:
| | | | 1. persistent negative attitudes towards osteoarthritis in general and towards value of TKAR in particular amongst the public and primary care MDs
| | | | 2. the lack of simple tools to help assess severity and impact of knee osteoarthritis that can be used in the community
| | | | 3. the absence of any clear guidelines or agreed evidence based indications for TKA
| | | | 4. the absence of any studies that compare the efficacy of TKA with that of non-surgical intervention strategies
| | | | - 3 useful variables for surgical decision making in TKA:
| | | | 1. severity of joint damage (pain at night, severity of pain, function)
| | | | 2. other patient related variables (psychosocial, patient motivation)
| | | | 3. the environment (socio-economic status - availability of surgeons, economic status of patients)
| | | | Consensus panel conclusions and recommendations:
| | | | 1. no clear evidence-based indications for TKA
| | | | 2. no comparisons with other forms of treatment
| | | | 3. no understanding of which patients are particularly likely to benefit from the procedure
| | | | 4. the absence of any studies that compare the efficacy of TKAR with that of non-surgical intervention strategies
Malmlin et al., 1998^16^ | Arch Fam Med | Family practitioners and general internists n=300 each (70 and 72 in final analysis) | Description and comparison of the self-reported practice patterns of family practitioners and general internists for the evaluation and management of severe osteoarthritis of the knee, including factors that might influence referral for TKA | - Combining family practitioners and general internists, clinical agreement (>90%) with 6 of 26 patient factors (23%) determining need for TKA
| | | | - Clinical disagreement (<60%) with 5 of 26 patient factors determining need for TKA
Tierney et al., 1994^11^ | Clin Ortho | All orthopaedists in Indiana, USA. n=280 (188 in final analysis) | To understand reasons for variation of who gets TKAs using orthopaedists' perspectives of indications and outcomes and comparing them with self-reported annual number of TKAs they performed | - Clinical agreement (>95%) in 7 of 34 patient factors (21%)
| | | | - Agreement (=95% and >60%) with 21 of 33 factors
| | | | - No agreement (<60%) with 5 of 34 (15%) patient factors
| | | | - When correlated with # of TKAs in prior year, significant factors were:
| | | | [underlined: Patient Characteristics]: female gender (r=0.17, p=0.02), non-compliant patient (r=0.20, p=0.008), unstable knee (r=0.20, p=0.008)
| | | | [underlined: Continuous parameters]: old age (r=0.16, p=0.03), varus deformity (r=0.16, p=0.03), valgus deformity (r=0.17, p=0.02) - Independent variables associated with reported # of TKAs in prior year
| | | | Independent Variable | Fraction of Variance explained | P-value
| | | | Female gender | 0.06 | 0.0009
| | | | Unstable knee | 0.02 | 0.488
| | | | Patient can be too old | 0.01 | 0.076
Naylor & Williams, 1996^17^ | Quality in Health Care | Consensus Panel (n=11) 4 orthopaedic MDs 2 rheumatoid MDs 2 general practitioners 1 “general physician” 1 epidemiologist 1 physiotherapist | Consensus finding using 120 case scenarios to try and gain agreement on priorities and appropriateness for hip and knee replacement surgery. Consensus findings also with 42 case scenarios for urgency of replacement | - Found that key determinants to prioritize surgery were: pain at rest, severity of functional impairment, problems with care-giving, perceived likely improvement in function
| | | | - Panel agreement statistics:
| | | | • Agreement of =9/11 panelists occurred 61% (73/120) of appropriateness scenarios for referral for TKA (not appropriate, uncertain, appropriate) and in 17% of urgency categories
| | | | • Agreement of =10/11 panelistsoccurred in 92% of appropriateness scenarios and 74% (31/42) of urgency scenarios

Table 2. Summary of studies of clinical agreement about patient factors for either referral or surgery (set at >90% for significant agreement)

Study | Journal / Population | Pro | Neutral | Con | Clinical Factors of Disagreement (<60% agreement)
Wright et al., 1995^12^ | Can Med Assoc J | Pain despite meds | Male | Peripheral vascular disease | Patient is >80 years old
| Orthopaedic surgeons | | Female | Isolated patellofemoral arthritis | Nursing home resident
| | | White race | Alcohol/Drug Abuse | Severe hip osteoarthritis
| | | Non-white race | Local active skin infection | Local psoriasis
| | | | Major psychiatric disorder | Quadriceps lag
| | | | Patient non-compliant | Weak quads
| | | | Age <55 years old | Sensation of instability
| | | | High physical demands at work
| | | | Septic arthritis >1 year ago
Mancuso et al., 1996^13^ | J Arthoplasty | Be independent | | Poor soft tissue coverage | Age >80 years old
| Orthopaedic surgeons | | | Dementia | Weight >200 pounds
| | | | Poor patient motivation | Wants psychiatric benefit
| | | | Hostile personality
| | | | Unreal expectations
Malmin et al., 1998^16^ | Arch Fam Med | Pain despite meds | Male | | Septic knee arthritis > 1 year ago
| Family practitioners and general internists | Persistent weight bearing knee pain | Female | | No health insurance
| | | White race | | Isolated patellofemoral arthritis
| | | Non-white race | | Patient demands TKA
| | | | | Painful feet
Coyte, Hawker et al., 1996^14^ | J Rheum | Pain despite meds - family practitioner/rheumatologist | Male - Family practitioners/ rheumatologists | Peripheral vascular disease (Rheumatologist) | Family practitioner/rheumatologist:
| Rheumatologists and family practitioners | Limited walking <1 block - family practitioner | Female - Family practitioners/ rheumatologists | Isolated patellofemoral arthritis (Rheumatologist) | non-compliant patient
| | | | Local active skin infection (Rheumatologist) | obese patient
| | | | | septic knee >1 year ago
| | | | | Varus or Valgus deformity
| | | | | High physical demands at work
| | | | | Family practitioner:
| | | | | <55 years old, severe hip osteoarthritis,
| | | | | Quadriceps lag, weak quads
| | | | | Rheumatologist:
| | | | | Nursing home resident
| | | | | Patient demands TKA
| | | | | Limited active flexion/extension
| | | | | Sensation of instability
Tierney et al., 1994^11^ | Clin Ortho | Persistent weight bearing pain | Female | Alcohol/drug abuse | Nursing home resident
| Orthopaedic surgeons | | Race (white or black) | Major psychiatric disorder | Painful feet
| | | | Local active skin infection | Patient demands TKA
| | | | | Unstable knee
| | | | | Severe hip osteoarthritis

Table 1 summarizes the studies that have examined physicians' beliefs about indications and contraindications for TKAs. Based on a survey of all orthopaedic surgeons in Ontario, Canada (n=325) surgeons' enthusiasm for performing TKAs was correlated with the rate of these procedures and the dominant modifiable determinant of regional variation utilization.^15^ In order to understand reasons for variation in utilization TKA, Tierney et al surveyed orthopedists in Indiana (n = 280). Analysis was limited to 188 respondents who had cared for at least one patient with osteoarthritis of the knee in the prior two weeks. Persistent weight-bearing pain was the only factor positively affecting the decision to perform knee replacement (agreed to by at least 95% respondents). Interestingly, surgeons who reported more knee replacements in the prior year had significantly higher estimates of pain relief and functional improvement following surgery, and lower estimates of prosthesis infection and failure rates. However, measured factors only explained 24% of the variation in self-reported knee replacement performance. The authors recommended that other factors such as access to orthopaedic surgeons performing TKA, decision making of referring physicians, and patient perceptions about knee replacement should be evaluated.^11^

Table 2 summarizes studies that sought areas of consensus about the indications for knee replacement surgery. As such, it is not evidence of effectiveness. Rather, it shows the areas of agreement for either referral to an orthopaedic surgeon or proceeding with TKA (defined as 90 percent or better consensus) across such studies. Pain is the overridingly consistent element. A larger number of contraindications were noted at least twice: peripheral vascular disease, alcohol or drug abuse, mental disorders, and local skin infection. The largest group of variables, however, (the area where less than 60 percent consensus was reached) included age greater than 80 years, nursing home residents, severe hip osteoarthritis, weak quadriceps, joint instability, obesity, septic knee arthritis, patients demanding a TKA, and painful feet. The level of agreement from study to study may be influenced by the techniques used to obtain consensus.