# Appendix F. Evidence Tables

Evidence Table 1. Primary TKA studies with at least a pre/post design

Reference | Measure | N Patients Baseline | N Patients Followup | Knees Baseline | Knees Followup | Followup (months) | Age | Gender | Arthritis | BMI | Notes
Bachmeier et al, 2001^94^ | WOMAC, SF-36 | | 108 | | | 10 | 72 | 61% Female | 100% OA | | Compared WOMAC and SF-36; no control variables used; WOMAC more sensitive than SF-36
Baldwin & Rubinstein, 1996^101^ | HSS | 300 | | 346 | 301 | 48 | 67.5 | 58% Female | | | Tested only effect of bone quality
Beaupre et al., 2001^95^ | WOMAC, SF-36 | 120 | 93 | | | 4.5 | 68.4 | 40% Female | 91% OA | | RCT to test role of exercise; no effect
Bert et al., 2000, 2001^69, ^ ^99^ | KS, SF-36 | 279 | 277 | | | 12 | 72 | 70% Female | | Mean=30 | No effect of expected post-op activity/demand level according to pre-op activity level
Bourne et al., 1995^70^ | KS | 100 | | | | 24 | 70 | 42 Male 83 Female | 100% OA | | Resurfacing patella
Brown et al., 2001^82^ | KS, HSS | 268 | 246 | 536 | | 76.8 | 68 | 68% Female | 89% OA 8% RA | | No effect of component size asymmetry
Bullens et al., 2001^75^ | KS, WOMAC | 108 | 86 | 126 | 100 | 58.8 | 67.4 | | 67 OA 37 RA | | Done to compare KS scores and satisfaction visual anolog scale; poor correlation, No difference in RA/OA in KS scores but RA had better satisfaction
Clark et al., 2001^98^ | KS, WOMAC | 143 | 108 | | | 36 | 71.4 | | 75% OA 25% RA | | RCT of posterior-stabilized vs. cruciate-retaining implants; no significant difference
Cloutier et al., 2001^83^ | KS | 130 | 89 | 163 | 107 | 120 | 67 | 34 Male 96 Female | 122 OA 41 RA | | Cruciate ligament retention
Cohen et al., 1997^71^ | KS | 186 | | 272 | | 6 | 69.5 | 71 Male 115 Female | 148 OA 22 RA | Mean = 177 pounds | No difference in pre- or post-op scores
Deshmukh et al., 2002^27^ | KS | 180 | 130 | | | 12 | 68.8 | 85 Male 95 Female | | 31 normal, 83 overweight 64 obese, 2 morbidly obese | Regression model included age, sex, side of arthritis, comorbidity, preop scores, and BMI R2 15.5%; age, sex, side of arthritis 3.4%; comorbidity 2.9%; baseline 9.2%; BMI accounted for almost no variance
Diduch et al., 1997^61^ | HSS, KS | 88 | 84 | 114 | 103 | 96 | 51 | 29 Male 55 Female | 64%OA
Duffy et al., 1998^84^ | KS | 104 | 102 | 120 | 108 | 120 | Uncemented = 54 Cemented = 65 | Cementless: 23 Male 23 Female Cemented: 23 Male 24 Female | OA: Uncemented-42 Cemented-42 RA: Uncemented-9 Cemented-6 | Mean = 80.9 kg | Cemented had better survival
Elke et al., 1995^76^ | KS | 394 | | 524 | | 50.4 | 75.1 68.4 | No difference | 61 RA 415 OA | | RA vs. OA no difference
Evanich et al., 1997^62^ | HSS | 251 | 169 | 302 | 212 | 91 | 66 | 48% Female | 78% OA 17% RA | | Countersunk metal-backed patellas
Ewald et al., 1999^85^ | KS | 412 | 180 | 539 | 306 | | 63 | | RA 151 OA 155 | | Kinematic arthroplasty
Fortin et al., 1999^28^ | SF-36, WOMAC | 130 | 106 | | | 6 | 67 | 96 Male 126 Female | All had OA | | In regression model, education and comorbidity did not predict outcomes for knees alone but did in pooled TKAR/THR
Gill & Joshi, 2001^86^ | KS | 223 | 223 | 254 | 254 | 201.6 | 68 | 89 Male 165 Female | 289 total TKAs 254 with OA, 35 with RA. ONLY studied patients with OA | | Survivorship of TKAR; no further analysis. PCL retaining
Gill et al., 1999^108^ | KS | 139 | 63 | 159 | 72 | 206.4 | 61 | 21 Male 42 Female | 68 OA 3 RA | | Total condylar TKA; survival analysis
Gioe & Bowman, 2000^103^ | KS, SF-36 | 296 | 195 | 324 | 213 | 49 | 69±6 | 285 Male 11 Female | 272 OA | | RCT of tibial components; no multivariate analysis
Griffin et al., 1998^110^ | KS, HSS | 120 | 56 | 165 | 73 | 127.2 | 67.8 | 15 Male 41 Female | 51 OA | 20 obese 30 nonobese | Obese showed more improvement
Harwin, 1998^102^ | KS, HSS | 336 | 326 | 366 | 356 | 61.2 | 65.1 | 138 Male 188 Female | 241 OA 109 RA | | Symmetrical TKA; pre/post only. Results reported separately by OA and RA
Hawker et al., 1998^29^ | WOMAC, KS | 1496 | 1193 | | | 24–84 | 72.6 | 70% Female | 87% OA 6% RA | Mean BMI=28 | Primary & revision: education, race, income, living environment. Correlates of pain at followup: pre-op pain, osteotomy before replacement, low SF-36 social function & emotional role function, high SF-36 pain, less satisfaction; none significant in multivariate. Age, BMI not related to outcomes
Hasegawa et al., 2002^54^ | HSS | 140 | | 221 | | 12–60 | 68 | 16 Male 124 Female | 129 OA 92 RA | Mean = 53 kg | Risk factors for heterotopic ossification: knee flexion, effusion (bivariate only);age, gender, arthritis, BMI not significant
Healy et al. 2002^63^ | KS, HSS | 159 | 142 | 159 | 142 | 96 (no CP) 60 (CP) | 69.9 | | 100% OA | Mean = 84.5 kg | Clinical pathway vs. no clinical pathway. Clinical pathways reduced hospital cost for TKA without affecting short-term patient outcome.
Heck et al. 1998^72^ | KS, WOMAC, SF-36 | 291 | 268 | 330 | | 24 | 70.2 | 109 Male 182 Female | 100%OA | Mean Body Mass Index = 30.2 | Logistic regression found maximal improvement in SF-36 physical component score in subjects who had surgery at institutions performing ≥50 TKA/year, had a better mental health status at baseline, and were treated with physical composite sparing device.
Hsu et al., 1998^55^ | HSS | 113 | 113 | 140 | 140 | 57.6 | 62.6 | 73% Female | 135 OA 5 RA | | Test hybrid: uncemented femur/cemented tibia, decreased pain, increased muscle strength
Hube et al., 2002^104^ | KS | 221 | | 297 | 276 | 36.2 | 66.3 (33–81) | 123 Male 153 Female | 261 OA 33 RA 3 infection | | Midvastus approach; pre/post only
Ilkejiani et al., 2000^64^ | HSS | 185 | 185 | 185 | 185 | 78 | 67 | 79 Male 121 Female | OA | Weight recorded | Patellar resurfacing; pre/post
Indelli et al., 2002^87^ | KS | 91 | 85 | 100 | 92 | 90 | 69 (57–85) | 13 Male 72 Female | All with OA | | Prosthesis; pre/post
Jenny & Jenny, 1998^77^ | KS | 125 | 125 | 125 | 125 | 30 | 69 | 39 Male 86 Female | | | Anterior cruciate ligament-retaining vs. replacing prostheses; pre/post
Jones et al., 2001^96^ | WOMAC, SF-36 | 257 | 257 | 257 | 257 | 6 | 70.7 | 63% Female | 93% OA | Mean Body Mass Index 31.4 | Education, age, gender, BMI, prior joint surgery, living arrangement, comorbidity included in regression model. Age not associated with improvement in WOMAC. Gains in WOMAC & SF-36 but not significant OLS: pain (WOMAC): LOS -, preop pain (SF36 +, cementless -; function (WOMAC): LOS-, preop joint pain (WOMAC)-, # comorb-, preop bodily pain (SF36)
Jordan et al., 1997^105^ | KS | 375 | | 473 | 410 | 56.4 | 68 | 113 Male 261 Female | 427 OA 45 RA | Weight recorded | Cementless miniscal bearing TKAs; pre/post
Kiebzak et al., 2002^100^ | SF-36 | 415 | | | | 24 | | 234 Female | | | American Society of Anesthesiologists (ASA), number of cormorb, differences greater for men (except role emotional). Only 54 used in analysis
Konig et al., 1997, 1998, 2000^30, ^ ^106,^ ^111^ | KS | 357 | 294 | 399 | 329 | 56.4 | 69.4 | 56 Male 238 Female | 278 OA 34 RA 16 other | | Preop walking distance related to pain on followup; none predicted KS score; KS function score predicted by: preop walk distance, age, BMI, preop patient category
Larson et al., 2001^56^ | HSS | 94 | 82 | 127 | 118 | 48 | 67 (41–81) | 20 Male 62 Female | 87 OA 30 RA | Mean 28 (17–44) 26 obese 1 morbidly obese | Mean BMI same with and without patellar complications 50% of patellar fracture or anterior knee pain obese cf 32% without; not significant. No significant difference in age, gender, preop diagnosis, knee score, followup time; range of motion; lateral release; knee manipulation; type of prosthesis
Lin et al., 2002^73^ | KS | 122 | 78 | | | 24 | 67.7–70 | | 100% OA | | Impact of clinical pathway; affected utilization but not outcomes
Liu & Chen, 1998^57^ | HSS | 88 | | 176 | | 31 | 67.4 | 97.5% Female | 82 OA 6 RA | | No sign diff
Lombardi Jr et al., 2001^112^ | HSS, KS | 240 | 240 | 351 | 351 | 77 | 65.5 | Reported | 223 OA 23 RA | Reported | No difference in followup KS, significant difference in pain improvement & outcome improvement stabilized > retain
Malkani et al., 1995^65^ | HSS, KS, | 118 | 84 | 168 | 119 | 120 | 64 | | | Height and weight reported | Improvement
Martin et al., 1997^88^ | KS | 290 | 231 | 378 | 306 | 78 | 67 | 60 Male 171 Female | 202 OA 91 RA | | Followup knee and function scores significant by Charnley scores. Function pre/post difference significant by Charnley score. No difference by surfaced patellas. Cemented femur had better function score
Matsueda & Gustilo, 2000^74^ | KS | 365 | 291 | 425 | 336 | 6 | 68.4 | 90 Male 211 Female | 253 OA 27 RA other 11 | | Compared subvastus and medial parapatellar approaches; no functional difference
Meding et al., 2001^78^ | KS | 1888 | 1888 | 2759 | 2759 | 30 | 70.6 | 60% Female | | Recorded | Preop KS and KS functional score related to radiographic changes but not pain score
Miyasaka et al., 1997^89^ | KS | 83 | 46 | 108 | 60 | 169 | 61 | 22 Male 39 Female | RA: 38 OA: 21 | Weight recorded | Pre/post valgus deformity
Mokris, et al., 1997^90^ | KS | 90 | 90 | 105 | 105 | 51 | 68.7 | 34 Male 56 Female | 97 OA 6 RA | | Pre/post
Mont et al., 1999^91^ | KS | 104 | 101 | 121 | 118 | 65 | 70 | 38 Male 63 Female (62% Female) | 97 OA 2 RA | | Pre/post
Moskal & Diduch, 1998^58^ | HSS | 514 | 488 | 646 | 617 | 51.6 | 64 | 69.6% Female | | Mean height & weight | Test role of post op x-rays; pre/post
O'Rourke et al., 2002^66^ | KS, HSS | 134 | 114 | 176 | 153 | 76.8 | 72.4 | 59.4% Female | | Mean BMI 30.9 | Improved osteolysis correl with KS. Trend towards anterior knee pain with higher BMI
Pereira et al., 1998^59^ | HSS | | 107 | 163 | | 36 | 69 | 40 Male 103 Female | 130 OA 8 RA | | PCL sparing vs. sacrificing associated with greater improvement
Ranawat et al., 1997^79^ | KS | 118 | 96 | 150 | 125 | 58.7 | 70 | | OA vs. RA | | Functional status for OA significance better than for RA Knee score for OA better than for RA
Rand & Gustilo, 1996^60^ | KS | 202 | 182 | 277 | 251 | 27.6 | 69 | 69 Male 113 Female | 156 OA 19 RA | | Inset vs. resurfacing patellar prostheses; resurfacing had better function; pain score higher
Regner et al., 1997^67^ | HSS | 120 | 88 | 144 | | 81.6 | 61 | 22 Male 98 Female | | | Pre- and post-op reported by OA/RA. Revision rate not affected by age, sex, arthritis, alignment or prosthesis
Rinta-Kiikka et al., 1996^92^ | KS | 97 | 89 | 102 | 94 | 64 | 67 | 77% Female | 74 OA 16 RA | Reported | Correlates of survival: age; extension deficit, knee score, function score, pain score at last review. BMI not associated
Ritter et al., 1995^109^ | KS | 3054 | | 4583 | | 180 | 70.4 | 60 Female | 87% OA
Rodriguez et al., 1996^80^ | HSS KS | 99 | 67 | 145 | 104 | 52 | 12.7 (5–18) | 91Male 13 Female | All with RA | | RA patients stage II/IV
Schroder et al., 2001^68^ | HSS | 102 | 52 | 114 | 58 | 120 | 78 | | 48 OA 10 RA | | Pre/post OA/RA no difference
Sextro et al., 2001^93^ | KS | 118 | 50 | 168 | 66 | 188.4 | 65.1 | 72 Female | 109 OA knees 52 RA knees
Stickles et al., 2001^97^ | WOMAC, SF-36 | 4161 | 1011 | | | 12 | 69.9 | 637 Female | 100% OA | Mean 31.2 | No difference in WOMAC, SF physical component score, mental component score by BMIcategories in multiple regression model
Title et al., 2001^107^ | KS | 128 | 128 | 148 | 148 | 51 | 63 | 53 Female | 122 OA knees 24 RA knees | | Total condylar prosthesis vs. press fit condylar - 2 cohorts matched for age, diagnosis, gender, and body weight
Ververeli et al., 1995^52^ | HSS | 103 | 103 | | | 24 | 69.5 | 73 Female | 100% OA | | Continuous passive motion better than physical therapy alone
Worland et al., 1998^53^ | HSS | 91 | 80 | 114 | 103 | 6 | 70.2 | 53 Female 27 Male | 100% OA | | RCT, Continuous passive machine vs. professional physical therapy. Continuous passive motion adequate rehabilitation alternative with lower costs and no differences in results vs. physical therapy
Yang et al., 2001^81^ | KS | 90 | 86 | 113 | 109 | 36 | 69 | 13 Male 73 Female | 82 OA 4 RA

Evidence Table 2. Basic information for calculating revision rates

Study | Patients | Knees | Followup - Years | Revisions Related to Knee Prosthesis | Unit of Reporting | Total Reoperations (Revisions + Other) | Notes
Bachmeier et al., 2001^94^ | 108 | NR | 0.5 | 0 | subjects | 0
Baldwin & Rubinstein, 1996^101^ | 300 | 346 | 4 | 9 | knees | 17 | 17 reoperations total (revisions + infections)
Beaupre et al., 2001^95^ | 120 | NR | 0.5 | 0 | subjects | 0
Bert et al., 2001^69^ | 279 | NR | 1 | 1 | both | 1 | From Bert et al., 2000
Bourne et al., 1995^70^ | 100 | NR | 2 | 2 | subjects | 2 | Not due to infection, pat-femoral joints resurfaced due to pain
Brown et al., 2001^82^ | 268 | 536 | 6.4 | 0 | both | 0
Bullens et al., 2001^75^ | 108 | 126 | 4.9 | 1 | knees | 5 | Survival rates, no numbers; 5 reoperations total
Clark et al., 2001^98^ | 143 | NR | 3 | NR | | NR
Cloutier et al., 2001^83^ | 130 | 163 | 10 | 3 | knees | 7 | 3 due to infection
Cohen et al., 1997^71^ | 186 | 272 | 0.5 | 0 | both | 0 | 6 month followup
Deshmukh et al., 2002^27^ | 180 | NR | 1 | NR | | NR | 12 month followup
Diduch, et al., 1997^61^ | 88 | 114 | 18 | 4 | subjects | 6 | 3 subjects had a revision of patellar component only; 2 revised because of infection
Duffy, et al., 1998^84^ | 104 | 120 | 10 | 37 | knees | 38 | 25 patellar revisions plus 10 cementless and 2 cemented, femoral or tibial aseptic loosening only, 1 infection
Elke et al., 1995^76^ | 394 | 524 | 4.2 | 28 | knees | 38 | All problems, including infections (6), others (4)
Evanich et al., 1997^62^ | 251 | 302 | 7.6 | 11 | subjects | 12 | One deep wound infection requiring removal of knee
Ewald et al., 1999^85^ | 412 | 539 | =10 | 15 | knees | 20 | 10 patellar loosening, 3 extensive polyethylene wear, 2 for other loosenings
Fortin et al., 1999^28^ | 130 | NR | 0.5 | 0 | both | 1 | 1 severe infection requiring removal of knee; 6 month followup
Gill et al., 2001^86^ | 223 | 254 | 16.8 | 9 | knees | 10 | 1 knee revised for infection
Gill et al., 1999^108^ | 139 | 159 | 17.2 | 1 | knees | 1 | 3 failures, only 1 revised
Gioe & Bowman, 2000^103^ | 296 | 324 | 4.1 | 5 | knees | 13 | 8 for infection
Griffin et al., 1998^110^ | 120 | 165 | 10.6 | 3 | knees | 3
Harwin et al., 1998^102^ | 336 | 366 | 5.1 | 0 | knees | 10 | 8 for infection
Hasegawa et al., 2002^54^ | 140 | 221 | 12–60 | NR
Hawker et al., 1998^29^ | 1496 | NR | 24–84 | NR
Healy et al., 2002^63^ | 159 | 159 | 5,8 | 2 | both | 8 | 6 for manipulation
Heck et al., 1998^72^ | 291 | 330 | 2 | 0 | both | 0
Hsu et al., 1998^55^ | 113 | 140 | 4.8 | 20 | knees | 23 | 3 infections. Knee-related includes 4 Insall operations
Hube et al., 2002^104^ | 221 | 276 | 3 | 0 | | | 1 arthroscopic resection to correct patella clunk syndrome
Ikejiani et al., 2000^64^ | 145 | 185 | 6.5 | 1 | subjects | 1
Indelli et al., 2002^87^ | 91 | 100 | 7.5 | 0 | both | 0 | 1 revision recommended
Jenny & Jenny 1998^77^ | 125 | 125 | 2.5 | 8 | subjects | 8
Jones et al., 2001^96^ | 257 | 257 | 0.5 | 0 | subjects | | 6 month followup
Jordan et al., 1997^105^ | 375 | 473 | 4.7 | 19 | both | 24 | 5 infections
Kiebzak et al., 2002^100^ | 415 | NR | 2 | NR | | | Focuses on use of SF-36
Konig et al., 1998^30^ | 357 | 399 | 4.7 | 1 | knees | 2 | Exchange operations from Konig et al., 2000
Larson et al., 1999^138^ | 94 | 127 | 4 | 0 | both | 0
Lin et al., 2002^73^ | 122 | NR | 2 | 0
Liu & Chen, 1998^57^ | 88 | 176 | 2.6 | NR
Lombardi et al., 2001^112^ | 240 | 351 | 4.4 | 0 | knees | 17 | No revisions due to asceptic loosening
Malkani et al., 1995^65^ | 118 | 168 | 10 | 6 | knees | 21 | 13 for manipulation, 1 infection, 1 fracture
Martin et al., 1997^88^ | 290 | 378 | 6.5 | 12 | both | 17 | 2 due to infection, 2 hemarthroses, 1 crepitus
Matsueda & Gustilo, 2000^74^ | 365 | 425 | .5 | 0 | | 0 | Retrospective - No revisions
Meding et al., 2001^78^ | 1888 | 2759 | 2.5 | NR
Miyasaka et al., 1997^89^ | 83 | 108 | 14.1 | 3 | knees | 6 | 2 for infection, 1 for trauma
Mokris et al., 1997^90^ | 90 | 105 | 4.25 | 0 | | 0
Mont et al., 1999^91^ | 104 | 121 | 5.4 | 0 | knees | 5 | 4 subjects
Moskal & Diduch, 1998^58^ | 514 | 646 | 4.3 | 0 | both | 6 | Retrospective, included 57 revision subjects
O'Rourke et al., 2002^66^ | 134 | 176 | 6.4 | 3 | knees | 5 | 2 subjects
Pereira et al., 1998^59^ | 107 | 163 | 3 | NR
Ranawat et al., 1997^79^ | 118 | 150 | 4.9 | 1 | knees | 3 | 2 for infection
Rand & Gustilo, 1996^60^ | 202 | 277 | 2.3 | 0 | knees | 4 | 2 manipulation, 1 deep infection, 1 fracture
Regner et al., 1997^67^ | 120 | 144 | 6.8 | 17 | knees | 17
Rinta-Kiikka et al., 1996^92^ | 97 | 102 | 5.3 | 4 | knees | 5 | 1 for trauma
Ritter et al., 2001^139^ | 3054 | 4583 | 15 | 68 | knees | 68 | 6 femoral, 19 tibial, 15 all polyethylene, 28 metal-back patellar components
Rodriguez et al., 1996^80^ | 99 | 145 | 4.3 | 2 | knees | 7 | revision = 2 subjects
Schroder et al., 2001^68^ | 102 | 114 | 10 | 2 | both | 4 | 1 infection, 1 fracture
Sextro et al., 2001^93^ | 118 | 168 | 15.7 | 12 | knees | 13 | 1 trauma fracture
Stickles et al., 2001^97^ | 4161 | NR | 1 | Noted but not reported
Title et al., 2001^107^ | 128 | 148 | 4.3 | 0
Ververeli et al., 1995^52^ | 103 | NR | 2 | 0 | both | 1 | 1 infection
Worland et al., 1998^53^ | 91 | 114 | 5 | NR
Yang et al., 2001^81^ | 90 | 113 | 3 | 0 | both | 8 | 6 for infection, 1 for pain, 1 for fracture

Evidence Table 3. Basic information for calculating complication rates

Study | Patients | Knees | Complications | Number of Knees | Number of Subjects | Notes: Complications
Bachmeier, et al., 2001^94^ | 108 | NR | 14 | 14 | 14 | Adverse events requiring hospitalization, 10 maniupulations, 3 infections, 1 DVT
Baldwin & Rubinstein, 1996^140^ | 300 | 346 | 41 | 39 | NR | 4 DVT, 7 pulmonary embolisms, 3 deep infections, 3 manipulations, 6 subluxations. Revisions included.
Beaupre et al., 2001^95^ | 120 | NR | 20 | 20 | 20 | Adverse events requiring hospitalization. 14 knee-related, 4 DVT, 2 increased hemovac drainage, 4 cardiovascular, 1 pulmonary embolism
Bert et al., 2001^69^ | 279 | NR | 27 | 22 | 22 | All complications, non-device (21) and device (6).
Bourne et al., 1995^70^ | 100 | NR | 2 | 2 | 2 | “Reoperations” for disabling pain
Brown et al., 2001^82^ | 268 | 536 | 15 | NR | NR | 2 DVT, 3 late infections, 1 arthrofibrosis (requiring manipulation), 1 hemarthrosis (requiring evacuation).
Bullens et al., 2001^75^ | 108 | 126 | 12 | 12 | NR | Knee-related including 7 maniupulations, 1 tibial fissure, 1 femur shaft perforation. 5 reoperations (3 infections, 1 fracture, 1 looseneing)
Clark et al., 2001^98^ | 143 | NR | NR
Cloutier et al., 2001^83^ | 130 | 163 | 12 | 12 | NR | Knee-related only, 1 operative drainage
Cohen et al., 1997^71^ | 186 | 272 | 40 | NR | NR | 26 local (16 infections, 3 manipulations), 14 systemic (2 pulmonary embolisms, 1 DVT
Deshmukh et al., 2002^27^ | 180 | NR | NR
Diduch et al., 1997^61^ | 88 | 114 | 3 | 3 | 3 | Dislocations only
Duffy et al., 1998^84^ | 104 | 120 | 8 | 8 | NR | 8 complications minus revisions including 3 DVT, 3 deep, 1 fibrous ankylosis infections,
Elke et al., 1995^76^ | 394 | 524 | NR | NR | NR | Revisions only
Evanich et al., 1997^62^ | 251 | 302 | 20 | 20 | 20 | 4 perioperative, skin slough, superficial wound infection, transient peroneal nerve palsy, deep wound infection. 16 postop knee manipulations 4–8 weeks from procedure.
Ewald et al., 1999^85^ | 412 | 539 | NR | | | Revisions only
Fortin et al., 1999^28^ | 130 | NR | 3 | 3 | 3 | Requiring hospitalization (1 angina, 1 infected knee, 1 manipulation)
Gill et al., 2001^86^ | 223 | 254 | 13 | 13 | NR | Knee related, 3 infections, 10 fractures
Gill et al., 1999^108^ | 139 | 159 | 5 | 5 | NR | Knee related - 4 fractures, 1 tendon rupture
Gioe & Bowman, 2000^103^ | 296 | 324 | NR | | | Requiring revision only
Griffin et al., 1998^110^ | 120 | 165 | 11 | 11 | NR | “Symptoms of the patellofemoral joint,” including patellar clunk and fractures
Harwin, 1998^102^ | 336 | 366 | 15 | NR | NR | 5 patellofemoral complications plus 10 reoperations (infection, fracture, sublaxation)
Hasegawa et al., 2002^54^ | 140 | 221 | 10 | 10 | NR | Heterotopic ossification, study focus
Hawker et al., 1998^29^ | 1496 | NR | NR
Healy et al., 2002^63^ | 159 | 159 | 7 | 7 | 7 | 7 readmissions to hospital, 6 manipulations under anesthesia
Heck et al., 1998^72^ | 291 | 330 | 94 | NR | NR | In hospital complications, including 5 DVT
Hsu et al., 1998^55^ | 113 | 140 | 23 | 23 | NR | Knee-related only, including revisions
Hube et al., 2002^104^ | 221 | 276 | 2 | 2 | 2 | Knee-related only, 2 patellar clunk syndrome.
Ikejani et al., 2000^64^ | 145 | 185 | 10 | 10 | 10 | 7 falls, 1 DVT, 1 phlebitis, 1 revision
Indelli et al., 2002^87^ | 91 | 100 | 10 | 10 | 10 | Postoperative (6 DVT, 2 urinary tract infections, 1 hematoma, 1 mobilization).
Jenny & Jenny, 1998^77^ | 125 | 125 | 8 | NR | NR | Knee-related only (3 deep infections, 2 fractures, 2 loosenings, 1 ligamnet instability).
Jones et al., 2001^96^ | 257 | 257 | 29 | 29 | 29 | In-hospital (9 DVT, 12 urinary tract infections, 4 infection)
Jordan et al., 1997^105^ | 375 | 473 | 24 | NR | NR | 12 polyethylene fractures, 5 tibial subluxations, 2 loosenings, 5 infections.
Kiebzak et al., 2002^100^ | 415 | NR | NR
Konig et al., 1998^30^ | 357 | 399 | 20 | NR | NR | (From Konig et al., 2000) 10 DVT (2 pulmonary emobolisms), 1 peroneal palsy, 1 ruptured tendon, 2 mobilizations, 4 deep infections, 1 exchange of femoral component
Larson et al., 1999^138^ | 94 | 127 | 3 | 3 | NR | 3 patellar fractures
Lin et al., 2002^73^ | 122 | NR | NR | | | No readmissions within 30 days
Liu & Chen, 1998^57^ | 88 | 176 | 22 | NR | NR | Postoperative (including 1 DVT, 6 subluxations, 3 infections)
Lombardi et al., 2001^112^ | 240 | 351 | 17 | 17 | NR | “Subsequent surgeries only”
Malkani et al., 1995^65^ | 118 | 168 | 26 | 26 | 23 | 5 hematomas postop, 5 infections, loosenings and fractures, 2 thrombophlebitis, 2 gastro intestinal hemorrhages, 1 peptic ulcer, 1 peptic ileus. Includes revisions
Martin et al., 1997^88^ | 290 | 378 | 17 | 17 | 17 | Requiring reoperations including wear of previously used metal-backed patellas, loosenings and infections, 1 knee crepitus, 2 hemarthroses
Matsueda & Gustilo, 2000^74^ | 365 | 425 | 6 | 6 | NR | Sublaxations only
Meding et al., 2001^78^ | 1888 | 2759 | NR
Miyasaka et al., 1997^89^ | 83 | 108 | 3 | 3 | 3 | Knee-related only, 3 fractures
Mokris et al., 1997^90^ | 90 | 105 | 14 | 14 | 11 | 3 DVT, 3 subluxations, 2 infections, 2 fractures, 2 hematomas, 1 cerebro vascular accident, 1 wound slough.
Mont et al., 1999^91^ | 104 | 121 | 5 | 5 | 4 | Reoperations only (2 infection, 1 fracture, 1 tendon rupture, 1 due to instability)
Moskal & Diduch, 1998^58^ | 514 | 646 | 10 | 10 | 10 | 3 late fractures, 7 soft tissue complications
O'Rourke et al., 2002^66^ | 134 | 176 | 11 | 11 | 10 | 3 manipulations, 4 fractures, 1 avulsion of the medial collateral ligament, 1 wound necrosis, 1 hematoma, 1 DVT. Revisions excluded
Pereira et al., 1998^59^ | 107 | 163 | NR
Ranawat et al., 1997^79^ | 118 | 150 | 10 | 10 | NR | Complications of the patellofemoral joint
Rand & Gustilo, 1996^60^ | 202 | 277 | 18 | 18 | 17 | Includes infections, fractures, pulmonary emboli (4), myocardial infarction, manipulations (2).
Regner et al., 1997^67^ | 120 | 144 | NR | | | Revisions only
Rinta-Kiikka et al., 1996^92^ | 97 | 102 | 6 | 6 | NR | Superficial infections
Ritter et al., 2001^139^ | 3054 | 4583 | NR | | | Revisions only
Rodriguez et al., 1996^80^ | 99 | 145 | 8 | 8 | 7 | Knee failures only, 6 due to sepsis
Schroder et al., 2001^68^ | 102 | 114 | 6 | 6 | 6 | Knee failures only, 3 due to fractures
Sextro et al., 2001^93^ | 118 | 168 | 35 | NR | NR | Includes 7 hematomas, 5 superficial wound infections, 2 pulmonary embolisms, 1 amputation/fracture, 2 femoral and 4 patella fractures, 16 subjects requiring manipulation
Stickles et al., 2001^97^ | 1011 | NR | 90 | NR | 90 | Based on total complication rates. Complications included medical (DVT) and orthopaedic (hematoma, fracture, infection, loosening, failure).
Title et al., 2001^107^ | 128 | 148 | NR
Ververeli et al., 1995^52^ | 103 | NR | 9 | 9 | 9 | Perioperative: 3 pulmonary embolisms; 5 persistent serious drainage. Late: 1 infected knee
Worland et al., 1998^53^ | 91 | 114 | NR
Yang et al., 2001^81^ | 90 | 113 | 45 | NR | NR | Perioperative: 8 calf swellings (1 DVT), 17 UTI, 8 superficial infections, 3 deep infections, 1 myocardial infarction, 1 cerebro vascular accident. Late: 3 deep infections, 1 manipulation, 1 fracture, 2 loosenings