# Appendix E. Functional Outcome Following Total Knee Arthroplasty Revision: A Meta-analysis

Khaled J. Saleh, MD, MSc, FRCSC * ^1, ^ ^2, ^ ^3 ^Daryll C. Dykes, MD, PhD ^1, ^ ^2 ^Richard L. Tweedie, PhD DSc^4, ^Khadeeja Mohamed ^4^ , Ashwin Ravichandran ^1^ , Raied M. Saleh^1^ , Terence J. Gioe, MD ^1,^ ^3^ , David A. Heck MD^5^

* Correspondence

Phone: 612/626-3973 / Fax: 612/626-6032

saleh002@umn.edu

1. Department of Orthopaedic Surgery
  University of Minnesota School of Medicine
  420 Delaware Street SE, MMC 492
  Minneapolis, Minnesota 55455
2. Clinical Outcomes Research Center
  University of Minnesota School of Medicine
  420 Delaware Street SE, MMC 492
  Minneapolis, Minnesota 55455
3. Minneapolis Veterans Affair Medical Center
  I Veterans Dive
  Minneapolis Minnesota 55417
4. Division of Biostatistics, School of Public Health
  University of Minnesota
  420 Delaware Street SE
  Minneapolis,Minnesota 55455
5. Department of Orthopaedic Surgery
  Indiana University
  541 Clinical Dr, Suite 600
  Indianapolis Indiana 46202-5111

Running Title: Revision Knee Arthroplasty

Acknowledgement

Funded in part by The American Geriatric Society, The Minnesota Medical Foundation and The Orthopaedic Research and Education Foundation

## ABSTRACT

Objective- The objective of this study was to perform a systematic literature review to describe patient outcomes following Total Knee Arthroplasty Revision (TKAR) procedures using various Global Knee Score (GKS) ratings. Data Sources-English Language articles published from 1966 through 2000, were identified through a computerized literature search and bibliography review. Study selection-A multistage assessment was used to determine those articles containing data that could meet our objective. Analysis- Meta-analyses of Global Knee Scores were undertaken using a fixed effects model with the assumption that the variances of each individual measurement were identical across studies. Results- 58 articles with a total of 1965 patients met the initial inclusion criteria. Forty-two articles comprising 45 unique patient cohorts and a total of 1515 patients had sufficient GKS data for analysis and were used in the meta-analyses. Conclusions- Revision total knee arthroplasty is an effective procedure for failed knee replacements based on global knee rating scales.

## INTRODUCTION

Arthritis is generally a slowly progressive disease that afflicts more than two-thirds (68%) of Americans older than 55 years of age.^1^ It becomes increasingly prevalent with advancing age.^2,^ ^3^. At present, 43 million individuals have arthritis. By the year 2020, it is estimated that 59.4 million persons will be affected by this disease.^1^ The high prevalence of arthritis in the population is reflected in the high cost of treatment and has been estimated to cost 95 billion dollars (US) per year.^1^ In 1996 over 607,000 hip and knee replacements were performed in the U.S.^6^ By the year 2030, it is estimated that there will be an 85 % increase in knee replacements and an 80% increase in hip replacements^7^

Like all biomedical devices, total knee replacements can fail over time.^16^ Coincident with the increased incidence of primary TKA, there has also been an increase in the number of total knee arthroplasty revision (TKAR) procedures.^17^ In 1995, 19,138 TKAR procedures were performed in the U.S.^18^ Using Ontario 1989-94 discharge data, Coyte^18^ derived an annual growth rate of 14.1% for TKAR procedures. The number of TKAR procedures is expected to continue to grow as a result of complications associated with TKA, including infection, fracture and time-dependent implant failure that necessitate re-operation.^21^.

Unfortunately, long-term TKAR outcome data reporting knee specific or Global Knee Scores (GKS) in the arthroplasty literature is deficient. Callahan et al^24^ defined a Global Knee Score as “an instrument that measured patient outcomes in the domains of pain, function, and range of motion and combined these domains in a summary scale.” Examples of such scales include the Hospital for Special Surgery score (HSS) and Knee Society (KS) score. The specific aim of this study was to perform a systematic literature review to describe patient outcomes following TKAR procedures by using GKS to examine the following questions:

- Is there a significant increase from the preoperative GKS to the postoperative GKS?
- Is there correlation between preoperative GKS and the increase in the postoperative scores?
- What proportion of TKAR subjects attains excellent/good (E/G) results postoperatively, and what proportion attains satisfactory/poor (S/P) results?
- Does the proportion of E/G, or the postoperative values of HSS and KS scores, vary with the length of followup, the year of study publication, or preoperative diagnosis (i.e., infection, loosening, etc.)?

Arthritis tends to involve multiple joints, and as a result we wanted to examine the outcome of cohorts with subjects that had multiple knees revised versus cohorts that were comprised of subjects who only had a single knee revised:

- Is there a difference between the multiple and single knee cohorts in the percentage of subjects that attain E/G postoperatively?
- Is there a difference between the multiple and single knee cohorts in the preoperative HSS or KS scores or the score increases?

Finally we considered the entire data set of studies in order to assess the rates of complication following TKAR.

## METHODS

### Literature Search

We performed a computerized literature search using Medline to identify all citations concerning prosthetic knee procedures published from 1966 through 2000 using the MeSH terms “knee”, “prosthesis” and “replacement”. We obtained a copy of the abstracts for each identified English-language citation. We then used a multistage assessment similar to Callahan et al.^24^ to identify articles relevant to our questions. At the first stage, two study investigators (KS and TG) each reviewed the abstracts to determine which articles 1) reported any postoperative outcomes 2) reported on revision knee procedures and 3) had a study sample greater than five subjects. At the second stage, these articles were then extracted and reviewed. The bibliography sections in all review articles were examined and missed citations were retrieved. At the third stage of assessment the same investigator excluded any study articles that did not report results using a global knee rating scale.

### Data Abstraction

Data entry was carried out by two trained data abstractors (AR and RS). We analyzed variables that were reported across the majority of studies. Difficulties in abstracting data came from non-reported information or data that were reported on only a subset of the studies. Variables that were not consistently reported included: race, weight, medical comorbidities, previous numbers of surgeries on the index knee, time elapsed since the previous knee replacement, method of anesthesia, operative techniques (such as exposure, component removal, cement use, type of prosthesis, treatment of cruciate ligaments and allograft or metal augmentation), perioperative antibiotics, thrombosis prophylaxis, and postoperative rehabilitation course. Studies also showed variability in reporting complication rates; hence local complications including delayed wound healing, wound drainage, hematoma, knee effusions, and pressure sores could not be evaluated. Systemic complications including cardiac, gastrointestinal, neurologic, urologic, also could not be analyzed. Variables such as prosthetic design and source of research funding also were not consistently reported. Finally, the specifics of score administration methodology were not consistently reported.

### Data Analysis

For both KS (functional, clinical and averaged) and HSS scales, the preoperative and postoperative scores and the mean differences between preoperative and postoperative scores, were meta-analyzed to provide overall estimates for these values. Similar meta-analyses were carried out on the number of years of followup, age of patients, and other variables.

These meta-analyses were all “fixed effects”^25^ carried out under the assumption that the variances of each individual measurement are identical across studies. This assumption, also made by Callahan et al.^24^ is needed since information on variances is usually not given in these studies. Improving on the methodology of Callahan et al.,^24^ the variance of the overall estimate was derived under this model using the between-study variability, leading to a 95% confidence interval (CI) on each overall estimate.

This analysis calculates a weighted average of the values in each study, where the weights are the study sizes, as in Callahan et al.^24^ Study size was taken to be the reported number of subjects in each study minus the number reported as lost to followup. In some studies it was not clear if the size of study used in calculating the mean was the original number enrolled or the number minus those lost to followup. Therefore we also carried out the majority of the analyses using the total enrolled to see if this affected the overall answers. No changes of any importance occurred as a result.

Many studies also contained a classification into excellent/good (E/G) results versus satisfactory/poor (S/P) results, and a fixed effects meta-analysis of these E/G proportions (corrected for zero counts) was also carried out. The variances in this context were estimated using binomial methods, again allowing estimation of a 95% CI.

For further analysis the studies were divided into two groups: those with the “number of knees” reported as greater than the number of subjects, and those with the same number of subjects and knees reported. These groups were analyzed separately for each of the variables above. The hypothesis that the groups were different was tested, using single sample t-tests on the meta-analyzed values.

The dependence of the results on the number of years of followup was investigated. After consideration of the data, separate regressions were fitted to the studies that carried out followup for less than 60 months versus those that had longer followup periods. These results are exploratory, since this cut-off was subjective and accordingly we could not formally test the hypothesis that the periods were different.

Temporal trends in the data were analyzed against the mid-year of the stated study period to assess changes in results as newer methods were introduced. There were limited data to carry out this investigation, but there was no evidence of any secular trend in any of the measured scores. Studies also were grouped into those where all patients were treated because of infection and compared to those where < 10% were treated because of infection, and the proportions scoring E/G were compared. There were too few articles to allow a meaningful comparison for the KSS and HS scores. Finally, complications were tabulated and categorized into systemic and mechanical failure requiring re-revision.

## RESULTS

### Literature Description

A total of 2780 abstracts were identified in the literature using the above MeSH terms. Two hundred eighty-seven proceeded to the second stage after the abstracts were retrieved and examined. We then obtained a copy of the 287 articles and the bibliographies were reviewed for additional citations. The bibliographic review resulted in the addition of two studies to the candidate pool of articles. Fifty-eight of the 289 articles passed through the final filter and became the final data set.

These 58 articles from thirty-one different academic institutions were published from 1973 through 1994 (Appendix E-1). Pre- and postoperative KS scores were reported in fifteen studies (Table E-1), and HSS scores in seventeen (Table E-2). Two of these studies reported both KS and HSS data. Thirty-five studies reported a pre- and postoperative categorical outcome data that were stratified into four groups as: excellent, good, satisfactory, and poor (Table E-3). Overall, 46 unique patient cohorts from 42 articles had sufficient data to enable analysis of KS scores, HSS scores, or categorical E/G outcome data. The remainder had a variety of other global scores, with not enough of any one to support systematic analysis.

Table E-1. Fifteen studies reporting Knee Society (KS) scores

Paper | Number of Subjects | Number of Knees | Mean Age, years (range) | Average Followup (months) | Preoperative Clinical (or combined ♦) KS Score | Postoperative Clinical (or combined ♦) KS Score | Preoperative Functional KS Score | Postoperative Functional KS Score
Barrack et al., 1998 | 15 | 15 | 69.6 (NR) | NR | ♦ 79 | ♦ 125 | NR | NR
Barrack et al., 1998 | 51 | 51 | 71.3 (NR) | NR | ♦ 97 | ♦ 138 | NR | NR
Bradley, 2000 | 21 | 19 | 69 (43–89) | 33 | ♦ 60 | ♦ 147 | NR | NR
Elia et al., 1991 | 38 | 40 | 64.5 (22–91) | 41 | 41 | 77.6 | 43 | 56
Hanssen et al., 1994 | 86 | 89 | 68 (28–85) | 52 | 32.3 | 77 | 27.6 | 56
Hartford et al., 1998 | 16 | 16 | NR | 60 | 38 | 85 | 24 | 58
Kraay et al., 1992 | 7 | 7 | 74 (NR) | 44 | ♦ 71 | ♦ 83 | NR | NR
Lai et al., 1993 | 45 | 48 | 64 (45–84) | 65 | 41 | 80 | 47 | 74
Murray et al., 1994 | 35 | 40 | 67.2 (47–92) | 58.2 | 38 | 83.7 | 46.6 | 64.8
Pagnano et al., 1998 | 25 | 25 | 65 (NR) | 37.2 | 45 | 90 | 42 | 75
Partington et al., 1999 | 99 | 107 | 68 (52–80) | 44.4 | ♦ 86 | ♦ 131 | NR | NR
Rand 1991 | 19 | 21 | 65 (56–71) | 48 | 21 | 71 | 11 | 56
Takahashi et al., 1994 | 36 | 39 | 70.8 (56–91) | 24 | 50.5 | 82.7 | 35.9 | 56.1
Van Loon et al., 1999 | 18 | 18 | 61 (38–79) | 34.1 | 44.8 | 80.9 | 28.8 | 44.7
Whiteside et al., 1998 | 63 | 63 | 71 (57–91) | 108 | 3.3 | 48.2 | 5 | 41.1
| 574 | 598 | 67.7 (22–92) | 53.1 (44.5–61.7)* | 32.8 (25.5–40.0)* | 74.9 (68.6–80.8)* | 30.4 (22.8–37.9)* | 57.4 (51.6–62.7)*

* weighted values (95% CI)

NR = not reported in article

Table E-2. Seventeen studies reporting Hospital for Special Surgery (HSS) scores

Paper | Number of Subjects | Number of Knees | Mean Age (range) | Average Followup (months) | Preoperative HSS | Post-operative HSS
Donaldson et al., 1988 | 14 | 14 | 68 (56–82) | NR | 44.8 | 51.2
Engh et al., 1997 | 26 | 26 | 68.8 (31–87) | NR | 54 | 86
Fehring et al., 1998 | 36 | 36 | 64 (45–84) | 56 | 59 | 82
Fehring et al., 1998 | 27 | 27 | 62 (38–79) | 44 | 62 | 88
Gustilo et al., 1996 | 51 | 56 | 68 (50–84) | 99.6 | 54.7 | 79.3
Haas et al., 1995 | 76 | 78 | 54 (28–73) | 42 | 49 | 76
Hanssen et al., 1988 | 53 | 53 | NR | 37 | 58 | 82
Insall et al., 1982 | 72 | 72 | 62 (22–88) | NR | 49 | 83
Jackson et al., 1994 | 23 | 24 | 74 (38–90) | 46 | 52 | 70
Kim, 1987 | 14 | 14 | NR | 50.4 | 58 | 81
Knight et al., 1997 | 12 | 12 | 65 (26–85) | 27 | 56 | 86
Lai et al., 1993 | 45 | 48 | NR | 64.8 | 57 | 82
Mow et al., 1994 | 16 | 17 | 65 (56–71) | 72 | 52 | 87
Peters et al., 1997 | 55 | 57 | 69 | 62 | 47 | 82
Rand, 1991 | 19 | 21 | NR | 48 | 41 | 73
Rand et al., 1998 | 51 | 54 | 62.3 (36–74) | 57.6 | 52 | 81
Rosenberg et al., 1991 | 42 | 43 | 65 | NR | 36 | 74
| 632 | 652 | 65.2 (22–90) | 55.2 (47.4–63.0)* | 51.5 (48.9-54.1)* | 79.8 (76.4–83.1)*

* weighted values (95% CI)

NR = not reported in article

Table E-3. Studies reporting pre- and postoperative GKS and stratifying subjects categorically as excellent / good / satisfactory / poor

Paper | Adjusted Numberof subjects | Adjusted Number of Knees | Postoperative Number Excellent/Good | Postoperative Number Satisfactory/Poor | Postoperative Excellent/Good Proportion
Cameron et al., 1981 | 62 | 62 | 22 | 38 | 0.367
Chotivichit et al., 1991 | 18 | 18 | 14 | 4 | 0.778
Donaldson et al., 1988 | 14 | 14 | 7 | 2 | 0.778
Dorr et al., 1986 | 14 | 14 | 7 | 0 | 1
Elia et al., 1991 | 38 | 40 | 30 | 10 | 0.75
Engh et al., 1997 | 26 | 26 | 22 | 4 | 0.846
Fehring et al., 1998 | 20 | 20 | 14 | 6 | 0.7
Fehring et al., 1998 | 27 | 27 | 18 | 3 | 0.857
Goldman et al., 1996 | 60 | 64 | 46 | 18 | 0.719
Gustilo et al., 1996 | 51 | 56 | 50 | 6 | 0.893
Hartford et al., 1998 | 16 | 16 | 13 | 1 | 0.929
Hirakawa et al., 1998 | 54 | 55 | 31 | 10 | 0.756
Insall et al., 1982 | 72 | 72 | 64 | 8 | 0.889
Jacobs et al., 1989 | 9 | 9 | 5 | 4 | 0.556
Karpinski et al., 1987 | 51 | 52 | 12 | 40 | 0.231
Knight et al, 1997 | 10 | 10 | 9 | 1 | 0.9
Lachiewicz et al., 1996 | 21 | 21 | 20 | 1 | 0.952
Lai et al., 1993 | 45 | 48 | 39 | 9 | 0.813
Nicholls et al., 1990 | 12 | 13 | 5 | 8 | 0.385
Otte et al., 1997 | 28 | 29 | 20 | 9 | 0.69
Padgett et al., 1991 | 17 | 19 | 16 | 3 | 0.842
Pagnano et al., 1998 | 25 | 25 | 0 | 2 | 0
Pagnano et al., 1995 | 32 | 32 | 16 | 1 | 0.941
Peters et al., 1997 | 55 | 57 | 45 | 12 | 0.789
Rand et al., 1987 | 20 | 20 | 16 | 5 | 0.762
Rooser et al., 1987 | 55 | 69 | 29 | 11 | 0.725
Rosenberg et al., 1991 | 35 | 36 | 25 | 10 | 0.714
Wilde et al., 1988 | 13 | 13 | 7 | 4 | 0.636
Wilde et al., 1990 | 10 | 12 | 9 | 3 | 0.75
| 910 | 949 | 611 | 233 | 77.7 (75.2–80.2)*

* weighted value (95% CI)

### Patient Characteristics

For the 58 studies extracted there were a total of 1965 patients. A subgroup of 42 papers with 1,515 patients was used in the main analyses (Appendix E-1). The mean patient age across these 42 papers was 66.6 years. Approximately 61% of the enrolled subjects were women (based on thirty-seven studies who reported the gender data). This ranged from a minimum of 28% to a maximum of 82%. Osteoarthritis was the primary reason for the index knee replacement. The average number of months of followup for the studies reporting KS was 53.1 (95% CI 44.5–61.7) and for HSS was 55.2 (95% CI 47.4–63.0); this difference was not statistically significant (p>0.1). The patients' race and socio-economic status were not systematically reported.

### Summary of Findings

Is there a significant increase from the preoperative GKS to the postoperative GKS?

The preoperative combined mean KS score was 35.4 (95% CI 30.7–39.9) and there was a highly significant increase of 30.8 (95% CI 26.6–35.0) points to 66.2 (95% CI 61.8–70.2) points postoperatively (p<0.0001). The preoperative functional mean KS score was 30.4 (95% CI 22.8–37.9) with a highly significant increase of 27.0 (95% CI 21.8–32.2) points to 57.4 (95% CI 51.6–62.7) points postoperatively (p<0.0001); the preoperative clinical mean KS score was 32.8 (95% CI 25.5–40.0) with a highly significant increase of 42.1 (95% CI 39.2–45.0) points to 74.9 (95% CI 68.6–80.8) points postoperatively (p<0.0001). Note that the latter two subscales were on a subset of the 15 studies on which combined results could be calculated. The preoperative mean HSS score was 51.5 (95% CI 48.9–54.1) and there was a highly significant increase of 28.3 (95% CI 25.3–31.2) points to 79.8 (95% CI 76.4–83.1) points postoperatively (p < 0.0001).

Is there correlation between preoperative GKS and the increase in the postoperative scores?

There is no significant correlation between the preoperative score and the amount of improvement in either the overall KS (r = -0.09, p > 0.7) or the HSS (r = -0.263, p > 0.3) studies.

Is there a difference in the preoperative scores between the multiple and single knee cohorts?

Although there was no difference in age or gender between the multiple and single knee reports, there was a significant difference in preoperative HSS scores, multiple knee (49.5, 95% CI 45.9–53.2) and the single knee (54.5, 95% CI 51.4–57.5) studies (p<0.1). The preoperative combined mean KS score in the multiple knees group was, in contrast, higher (77.0, 95% CI 64.2–89.8) than the single knee group (59.85, 95% CI 45.2–74.5), which is just significant (p>0.1) in the other direction. This result is, however, heavily influenced by a preoperative combined score of only 4.2 in one fairly large study. These results indicate that the multiple knee cohorts may be more severe preoperatively then their counterparts, although this is not conclusive.

Is there a difference in the increase in KS or HSS scores between the multiple and single knee groups?

The meta-analyzed averaged KS mean difference between pre- and postoperative scores was statistically not significant between the multiple knee (60.0, 95% CI 49.4–70.5) and single knee (64.4, 95% CI 50.3–78.5) studies. The meta-analyzed HSS mean difference between pre- and postoperative scores was statistically not significant between the multiple knee (28.9, 95% CI 25.5–32.3) and single knee (27.2, 95% CI 22.5–32.0) studies.

Does the increase in HSS or KS scores vary with the length of followup?

On an exploratory basis, the mean difference increases on both GKS scores up to around 60 months, thereafter KS (Figure E-1) and the HSS score marginally declines (Figure E-2).

Figure E-1. Mean increase in Knee Society scores (postoperative less preopertive Scores) as a function of postoperative followup (months)

Figure E-2. Mean increase in Hospital Special Surgery scores (postoperative less preopertive scores) as a function of postoperative followup (months)

What proportion of TKAR subjects attains excellent/good (E/G) results on the GKS postoperatively, and what proportion attains satisfactory/poor results?

The percentage of subjects attaining an excellent/good postoperatively was 77.7% (95% CI 75.2–80.2).

Is there a difference in the percentage of subjects that attain E/G ratings postoperatively on the GKS between the multiple and single knee cohorts?

The percentage of subjects attaining E/G was 72.7% (95% CI 69.5–76.3) in studies reporting on cohorts where some subjects had both knees revised, compared to 82.6% (95% CI 79.1–86.3) in studies reporting on cohorts where no subjects were reported to have had multiple knees revised. This difference is significant (p < 0.05). Those patients in whom single revision knee replacements were performed had better postoperative scores.

Does the proportion of E/G vary with the length of followup?

On an exploratory basis, the percentage of E/G subjects increase up to around 60 months (Figure E-3).

Does the proportion of E/G vary with the presence of infection as a proximate cause for revision?

Figure E-3. Proportion of subjects rated as excellent or good as a function of postoperative followup (months)

There was a significant difference in the proportion of E/G outcomes between those articles in which a higher percentage of patients with infection as the proximate cause for revision as compared to those in which fewer patients were infected. (p < 0.05) Uninfected patient series do better with the proportion of E/G outcomes equal to 78.5% (95% CI 74.7%–82.3%). The greater proportion of infected patient series have worse outcomes with the proportion E/G equal to 67.5% (95% CI 61.5%–73.4%).

What is the complication rate following TKAR?

Forty-four of 46 (95.7%) cohorts reported complication data on 1,683 subjects who incurred 443 complications (26.3%). It was not possible to determine which or how many complications occurred in any given patient or patient subset (Table E-4). There were a total of 217 knee complications in 1,683 subjects necessitating re-revision (12.9%). Callahan et al. found a 30% overall complication rate and a 7.2% revision rate in 18 bicompartmental knee arthroplasty reports which 884 enrolled patients and an 18.5 overall complication rate and a 9.2% revision rate in 46 unicompartmental knee arthroplasty reports which 2,391 enrolled patients.^27^

Table E-4. Complications

Description of Complication | Number of Studies Reporting Complication | Number of Knees in Reporting Studies | Number of Complications (%)
Prosthesis fracture, tibial | 1 | 23 | 5 (21.7)
Failed patellar component | 5 | 171 | 19 (11.1)
Deep vein thrombosis | 5 | 154 | 16 (10.4)
Arterial injury | 3 | 39 | 4 (10.3)
Wound, retained foreign body | 7 | 321 | 30 (9.3)
Other complications | 34 | 1182 | 97 (8.2)
Bone graft, nonunion | 2 | 26 | 2 (7.7)
Unstable total knee | 7 | 254 | 19 (7.5)
Unexplained pain | 7 | 271 | 20 (7.4)
Fracture proximal tibia | 1 | 14 | 1 (7.1)
Wound infection, deep | 25 | 1258 | 84 (6.7)
Wound infection, superficial | 12 | 504 | 24 (4.8)
Urinary tract infection | 7 | 286 | 13 (4.5)
Wound hematoma | 8 | 324 | 14 (4.3)
Gastrointestinal bleed | 2 | 79 | 3 (3.8)
Cardiac arrhythmia | 1 | 28 | 1 (3.6)
Implant loosening, F+T | 3 | 140 | 5 (3.6)
Dislocation, patella | 2 | 142 | 5 (3.5)
Septicemia | 3 | 118 | 4 (3.4)
Wound dehiscence | 3 | 145 | 5 (3.4)
Dislocation | 5 | 213 | 7 (3.3)
Fracture, femur, undisplaced | 5 | 192 | 6 (3.1)
Pulmonary embolus | 4 | 161 | 5 (3.1)
Implant loosening, tibia | 8 | 338 | 10 (3.0)
Patellar tendon rupture | 10 | 400 | 12 (3.0)
Fracture, femur, displaced | 4 | 210 | 6 (2.9)
Bone graft, resorption | 1 | 40 | 1 (2.5)
Fracture, patella | 7 | 417 | 10 (2.4)
Stroke | 1 | 43 | 1 (2.3)
Implant loosening, femur | 5 | 225 | 5 (2.2)
Pneumonia | 2 | 92 | 2 (2.2)
Implant loosening, patella | 1 | 48 | 1 (2.1)
Peroneal nerve injury | 3 | 140 | 3 (2.1)
Ligament rupture | 2 | 117 | 2 (1.7)
Modular component dissociation | 1 | 78 | 1 (1.3)
| | | 443 (26.3)

F = Femoral component

T = Tibial component

## DISCUSSION

Ideally, clinical information is gathered through large, carefully controlled and randomized prospective studies. However, such studies are technically and logistically complex, expensive, and often impractical or impossible. Meta-analysis, which is less complex, specifically increased the statistical power of our study and reduced the chance of type II statistical errors.^24^ In this situation, the results produced meaningful information that was not apparent on the basis of the smaller studies alone. It is not always the case that there is perfect concordance between the results of meta-analyses and subsequent randomized controlled trials.^26^ However, this technique is helpful in allowing an investigator to better design and appropriately power subsequent clinical trials.

In the case of TKAR, epidemiological studies have clearly demonstrated a rapidly growing demand for this surgery.^7^ However, knowledge regarding its outcomes has been lacking. In this communication, we report the results of a systematic review of the literature concerning patient outcomes following TKAR. Although TKAR is among the most technically challenging orthopaedic procedures, it is clear from these results that patients attain favorable outcomes following this procedure.

The majority of patients reported significant improvement in GKS following TKA. Patients reported mean postoperative KS and HSS scores which were 87.3% and 49.2% greater than their respective preoperative values, with slightly greater than three-quarters (77.7%) of patients reporting “excellent” or “good” outcomes. While this study supports the common belief that revision arthroplasty surgery is generally less successful than primary procedures, these data compare favorably with those reported in meta-analyses of primary knee replacement outcomes. Using literature synthesis data, Callahan et al. reported mean improvements in global rating scale scores of 63%, 93%, and 100%, and good or excellent outcomes in 80%, 73%, and 90% of patients following primary unicompartmental,^27^ bicompartmental^2^, and tricompartmental knee arthroplasty,^24^ respectively. Cohorts consisting exclusively of single-knee TKAR subjects had significantly higher proportions of subjects reporting E/G outcomes than those that included subjects with bilateral TKAR. However, although patients in the bilateral knee cohorts had slightly lower mean preoperative HSS scores and slightly higher mean preoperative KS scores, we found no significant difference in the degree to which patients improved following single-knee TKAR or revision surgery of both knees. This finding, which has not been previously observed, is consistent with our general finding that preoperative GKS does not appear to affect the magnitude of the reported success of the procedures. A thorough assessment of any clinical procedure must weigh the benefits of the procedure against its complications.

There was insufficient data reported to analyze the rates of preoperative or postoperative mortality. However, the majority (95.7%) of studies included in this analysis reported at least some complication data, with an overall complication rate of 26.3%. While the rates of most TKAR complications were consistent with those reported for primary TKA, an unusually high incidence of patellar component failure (11.1%), arterial injuries (10.3%), fracture of the proximal tibia (7.1%), and deep wound infection (6.7%) was identified in this study. This effect may have been falsely inflated secondary to our study-rule that assumes all complications were not screened for and only reported when they arose, artificially deflating the denominator and increasing the rate. The subgroup of patients with infection as a proximate cause for revision appears particularly challenging as their likelihood of achieving excellent or good outcomes is reduced.

Certain limitations are inherent to meta-analysis methodology. The results of data synthesis from multiple publications is limited by the quality and quantity of data reported in the included studies. In this analysis, we discovered considerable variation in the existing TKAR literature with respect to study size and design, followup period, and the authors' style of reporting many salient variables. As in previous meta-analyses, insufficient data were present to assess the impact of patient demographic characteristics, socio-economic status, implant characteristics, details of the surgical procedures, or postoperative care regimens on the outcome of TKAR. Accordingly, although we demonstrate significant overall favorable outcomes following TKAR surgery, we are unable to identify those particular factors that lead to improvement in postoperative

Scores. Similarly, complication data were only variably reported and particular complications were seldom attributable to particular patients.

## CONCLUSION

TKAR appears to be an effective treatment for most patients facing the painful, disabling and clinically challenging effects of failed knee arthroplasty. Clearly, the existing literature regarding outcome of TKAR is deficient, in experimental methodology and longer-term results. Future studies investigating the results of TKAR should utilize better experimental design, including validated assessment tools, independent assessment of outcomes, larger patient samples, and longer followup. Additionally, future reports must adhere to improved reporting standards, including better reporting of loss to followup information, surgical and implant details, outcome measures, complications and patient characteristics including socioeconomic status, comorbidity, proximate cause for revision, and extent of local disease at the time of revision.

## Appendix E-1 58 Articles identified in the literature search which were included in the final Meta-analytic data set

A1 Bargar W L, Cracchiolo A III, Amstutz H C. Results with the constrained total knee prosthesis in treating severely disabled patients and patients with failed total knee replacements. Journal of Bone & Joint Surgery - American Volume. 1980;62:504-512.
A2 Barrack, R. L., Matzkin, E., Ingraham, R., Engh, G., and Rorabeck, C.: Revision knee arthroplasty with patella replacement versus bony shell. Clinical Orthopaedics & Related Research.139–143, 1998.
A3 Barrack, R. L., Rorabeck, C., Burt, M., and Sawhney, J.: Pain at the end of the stem after revision total knee arthroplasty. Clin. Orthop.216–225, 1999.
A4 Barrett W P, Scott R D. Revision of failed unicondylar unicompartmental knee arthroplasty. Journal of Bone & Joint Surgery - American Volume. 1987;69:1328-1335.
A5 Bradley, G. W.: Revision total knee arthroplasty by impaction bone grafting. Clinical Orthopaedics & Related Research.113–118, 2000.
A6 Cameron H U, Hunter G A, Welsh R P, Bailey W H. Revision of total knee replacement. Canadian Journal of Surgery. 1981;24:418-420.
A7 Chakrabarty G, Newman J H, Ackroyd C E. Revision of unicompartmental arthroplasty of the knee. Clinical and technical considerations. J Arthroplasty. 1998;13:191-196. [pmid: 9526213].
A8 Chotivichit A L, Cracchiolo A III, Chow G H, Dorey F. Total knee arthroplasty using the total condylar III knee prosthesis. Journal of Arthroplasty. 1991;6:341-350. [pmid: 1770371].
A9 Donaldson W F III, Sculco T P, Insall J N, Ranawat C S, Tew M, Forster I W, Rand J A, Chao E Y, Stauffer R N. Total condylar III knee prosthesis. Long-term followup study effect of knee replacement on flexion deformity Kinematic rotating-hinge total knee arthroplasty. Clinical Orthopaedics & Related Research. 1988;69:21-28.
A10 Dorr, L. D., Ranawat, C. S., Sculco, T. A., McKaskill, B., and Orisek, B. S.: Bone graft for tibial defects in total knee arthroplasty. Clinical Orthopaedics & Related Research.153–165, 1986.
A11 Elia, E. A. and Lotke, P. A.: Results of revision total knee arthroplasty associated with significant bone loss. Clinical Orthopaedics & Related Research.114–121, 1991.
A12 Engh G A, Herzwurm P J, Parks N L. Treatment of major defects of bone with bulk allografts and stemmed components during total knee arthroplasty. Journal of Bone & Joint Surgery - American Volume. 1997;79:1030-1039.
A13 Fehring, T. K. and Griffin, W. L.: Revision of failed cementless total knee implants with cement. Clin. Orthop.34–38, 1998.
A14 Gill, T., Schemitsch, E. H., Brick, G. W., and Thornhill, T. S.: Revision total knee arthroplasty after failed unicompartmental knee arthroplasty or high tibial osteotomy. Clinical Orthopaedics & Related Research.10–18, 1995.
A15 Goldberg, V. M., Figgie, M. P., Figgie, H. E., III, and Sobel, M.: The results of revision total knee arthroplasty. Clinical Orthopaedics & Related Research.86–92, 1988.
A16 Goldman, R. T., Scuderi, G. R., and Insall, J. N.: 2-stage reimplantation for infected total knee replacement. Clinical Orthopaedics & Related Research.118–124, 1996.
A17 Gustilo T, Comadoll J L, Gustilo R B. Long-term results of 56 revision total knee replacements. Orthopaedics (Thorofare., NJ). 1996;19:99-103. [pmcid: 26554]. [pmid: 15339621].
A18 Haas S B, Insall J N, Montgomery W III, Windsor R E. Revision total knee arthroplasty with use of modular components with stems inserted without cement. Journal of Bone & Joint Surgery - American Volume. 1995;77:1700-1707.
A19 Hanssen A D, Rand J A. A comparison of primary and revision total knee arthroplasty using the kinematic stabilizer prosthesis. Journal of Bone & Joint Surgery - American Volume. 1988;70:491-499.
A20 Hanssen, A. D., Rand, J. A., and Osmon, D. R.: Treatment of the infected total knee arthroplasty with insertion of another prosthesis. The effect of antibiotic-impregnated bone cement. Clinical Orthopaedics & Related Research.44–55, 1994.
A21 Hartford J M, Goodman S B, Schurman D J, Knoblick G. Complex primary and revision total knee arthroplasty using the condylar constrained prosthesis: an average 5-year followup. Journal of Arthroplasty. 1998;13:380-387. [pmid: 9645517].
A22 Hirakawa K, Stulberg B N, Wilde A H, Bauer T W, Secic M. Results of 2-stage reimplantation for infected total knee arthroplasty. J Arthroplasty. 1998;13:22-28. [pmid: 9493534].
A23 Ikezawa Y, Gustilo R B. Clinical outcome of revision of the patellar component in total knee arthroplasty. A 2- to 7-year followup study. J Orthop. Sci. 1999;4:83-88. [pmid: 10199985].
A24 Insall, J. N. and Dethmers, D. A.: Revision of total knee arthroplasty. Clinical Orthopaedics & Related Research.123–130, 1982.
A25 Jackson M, Sarangi P P, Newman J H, Hanssen A D, Rand J A, Osmon D R. Revision total knee arthroplasty. Comparison of outcome following primary proximal tibial osteotomy or unicompartmental arthroplasty. Journal of Arthroplasty. 1994;9:539-542. [pmid: 7807113].
A26 Jacobs, M. A., Hungerford, D. S., Krackow, K. A., and Lennox, D. W.: Revision total knee arthroplasty for aseptic failure. Clinical Orthopaedics & Related Research.78–85, 1988.
A27 Jacobs, M. A., Hungerford, D. S., Krackow, K. A., and Lennox, D. W.: Revision of septic total knee arthroplasty. Clinical Orthopaedics & Related Research.159–166, 1989.
A28 Karpinski, M. R. and Grimer, R. J.: Hinged knee replacement in revision arthroplasty. Clinical Orthopaedics & Related Research.185–191, 1987.
A29 Kim, Y. H.: Salvage of failed hinge knee arthroplasty with a Total Condylar III type prosthesis. Clin. Orthop.272–277, 1987.
A30 Knight J L, Atwater R D, Guo J. Early failure of the porous coated anatomic cemented unicompartmental knee arthroplasty. Aids to diagnosis and revision. Journal of Arthroplasty. 1997;12:11-20. [pmid: 9021496].
A31 Kraay M J, Goldberg V M, Figgie M P, Figgie H E III. Distal femoral replacement with allograft/prosthetic reconstruction for treatment of supracondylar fractures in patients with total knee arthroplasty. Journal of Arthroplasty. 1992;7:7-16. [pmid: 1564468].
A32 Lachiewicz P F, Falatyn S P, Greis P E, Steadman J R. Clinical and radiographic results of the Total Condylar III and Constrained Condylar total knee arthroplasty revision of failed prosthetic anterior cruciate ligament reconstruction. [Review] [34 refs]. Journal of Arthroplasty. 1996;11:916-922. [pmid: 8986569].
A33 Lai, C. H. and Rand, J. A.: Revision of failed unicompartmental total knee arthroplasty. Clinical Orthopaedics & Related Research.193–201, 1993.
A34 Mnaymneh, W., Emerson, R. H., Borja, F., Head, W. C., and Malinin, T. I.: Massive allografts in salvage revisions of failed total knee arthroplasties. Clinical Orthopaedics & Related Research.144–153, 1990.
A35 Mow, C. S. and Wiedel, J. D.: Noncemented revision total knee arthroplasty. Clinical Orthopaedics & Related Research.110–115, 1994.
A36 Murray, P. B., Rand, J. A., and Hanssen, A. D.: Cemented long-stem revision total knee arthroplasty. Clinical Orthopaedics & Related Research.116–123, 1994.
A37 Nicholls D W, Dorr L D. Revision surgery for stiff total knee arthroplasty. Journal of Arthroplasty. 1990;5(Suppl):S73-S77. [pmid: 2243220].
A38 Otte K S, Larsen H, Jensen T T, Hansen E M, Rechnagel K. Cementless AGC revision of unicompartmental knee arthroplasty. Journal of Arthroplasty. 1997;12:55-59. [pmid: 9021502].
A39 Padgett D E, Stern S H, Insall J N. Revision total knee arthroplasty for failed unicompartmental replacement. Journal of Bone & Joint Surgery - American Volume. 1991;73:186-190.
A40 Pagnano, M. W., Hanssen, A. D., Lewallen, D. G., and Stuart, M. J.: Flexion instability after primary posterior cruciate retaining total knee arthroplasty. Clin. Orthop.39–46, 1998.
A41 Pagnano, M. W., Trousdale, R. T., and Rand, J. A.: Tibial wedge augmentation for bone deficiency in total knee arthroplasty. A followup study. Clinical Orthopaedics & Related Research.151–155, 1995.
A42 Palmer, S. H., Morrison, P. J., and Ross, A. C.: Early catastrophic tibial component wear after unicompartmental knee arthroplasty. Clinical Orthopaedics & Related Research.143–148, 1998.
A43 Partington, P. F., Sawhney, J., Rorabeck, C. H., Barrack, R. L., Moore, J., Shaw, J. A., and Chung, R.: Joint line restoration after revision total knee arthroplasty Febrile response after knee and hip arthroplasty. Clinical Orthopaedics & Related Research.165–171, 1999.
A44 Peters C L, Hennessey R, Barden R M, Galante J O, Rosenberg A G. Revision total knee arthroplasty with a cemented posterior-stabilized or constrained condylar prosthesis: a minimum 3-year and average 5-year followup study. Journal of Arthroplasty. 1997;12:896-903. [pmid: 9458255].
A45 Rand J A. Revision total knee arthroplasty using the total condylar III prosthesis. Journal of Arthroplasty. 1991;6:279-284. [pmid: 1940934].
A46 Rand J A, Bryan R S. Results of revision total knee arthroplasties using condylar prostheses. A review of fifty knees. Journal of Bone & Joint Surgery - American Volume. 1988;70:738-745.
A47 Rand J A, Chao E Y, Stauffer R N. Kinematic rotating-hinge total knee arthroplasty. Journal of Bone & Joint Surgery - American Volume. 1987;69:489-497.
A48 Ritter M A, Carr K D, Keating E M, Faris P N, Bankoff D L, Ireland P M. Revision total joint arthroplasty: does Medicare reimbursement justify time spent?. Orthopaedics (Thorofare, NJ). 1996;19:137-139. [pmcid: 26554]. [pmid: 15339621].
A49 Rooser, B., Boegard, T., Knutson, K., Rydholm, U., and Lidgren, L.: Revision knee arthroplasty in rheumatoid arthritis. Clinical Orthopaedics & Related Research.169–173, 1987.
A50 Rosenberg, A. G., Verner, J. J., and Galante, J. O.: Clinical results of total knee revision using the Total Condylar III prosthesis. Clinical Orthopaedics & Related Research.83–90, 1991.
A51 Shaw J A, Balcom W, Greer R B III. Total knee arthroplasty using the kinematic rotating hinge prosthesis. Orthopaedics (Thorofare, NJ). 1989;12:647-654. [pmcid: 26554]. [pmid: 15339621].
A52 Shin, D. S., Weber, K. L., Chao, E. Y., An, K. N., and Sim, F. H.: Reoperation for failed prosthetic replacement used for limb salvage. Clin. Orthop.53–63, 1999.
A53 Takahashi, Y. and Gustilo, R. B.: Nonconstrained implants in revision total knee arthroplasty. Clinical Orthopaedics & Related Research.156–162, 1994.
A54 van Loon C J, Wijers M M, Waal Malefijt M C, Buma P, Veth R P. Femoral bone grafting in primary and revision total knee arthroplasty. Acta Orthop. Belg. 1999;65:357-363.
A55 Waal Malefijt M C, van Kampen A, Slooff T J. Bone grafting in cemented knee replacement. 45 primary and secondary cases followed for 2–5 years. Acta Orthop. Scand. 1995;66:325-328.
A56 Whiteside, L. A. and Bicalho, P. S.: Radiologic and histologic analysis of morselized allograft in revision total knee replacement. Clinical Orthopaedics & Related Research.149–156, 1998.
A57 Wilde, A. H. and Ruth, J. T.: Two-stage reimplantation in infected total knee arthroplasty. Clinical Orthopaedics & Related Research.23–35, 1988.
A58 Wilde A H, Schickendantz M S, Stulberg B N, Go R T. The incorporation of tibial allografts in total knee arthroplasty. Journal of Bone & Joint Surgery - American Volume. 1990;72:815-824.

## References, Appendix E

1 Elders M J. The increasing impact of arthritis on public health. J Rheumatol Suppl. 2000;60:6-8. [pmid: 11032095].
2 Acheson R M, Collart A B. New Haven survey of joint diseases. XVII. Relationship between some systemic characteristics and osteoarthrosis in a general population. Ann Rheum Dis. 1975;34(5):379-387. [pmid: 1221922]. [pmcid: 1006437].
3 Peyron JG. Osteoarthritis. The epidemiologic viewpoint. Clin Orthop 1986;(213): 13–19.
4 Simon L S. Osteoarthritis: a review. Clin Cornerstone. 1999;2(2):26-37. [pmid: 10689542].
5 Felson DT. Epidemiology of Osteoarthritis: Prevalence and Risk Factors. 1995. American Academy of Orthopaedic Surgeons.
6 AHCPR 2001, Center for Organization and Delivery Studies, Health Care Cost and Utilization Project. : Statistics for 1996 HUP Nationwide Inpatient Sample, by Multilevel CCS Procedure. Table 2
7 National Center for Health Statistics. American Academy and American Association of Orthopaedic Surgeons Bulletin 1999; 47(3):14.
8 March L M, Cross M J, Lapsley H, Brnabic A J, Tribe K L, Bachmeier C J, et al. Outcomes after hip or knee replacement surgery for osteoarthritis. A prospective cohort study comparing patients' quality of life before and after surgery with age-related population norms. Med J Aust. 1999;171(5):235-238. [pmid: 10495753].
9 Schroder H M, Kristensen P W, Petersen M B, Nielsen P T. Patient survival after total knee arthroplasty. 5-year data in 926 patients. Acta Orthop Scand. 1998;69(1):35-38. [pmid: 9524515].
10 Gottlob CA, Pellissier JM, Chang RW, Wixson RL, Stern SH, Stulberg SD. Long-term cost effectiveness of total knee arthroplasty for the treatment of osteoarthritis. Presented at the American Academy of Orthopaedic Surgeons 63rd Annual Meeting, Atlanta, GA. 1996.
11 Current estimates from the National Health Interview Survey, 1988. Vital and Health Statistics Series 10[173, DHHS Pub No. (PHS) 89–1501], 89–1501. 2001. Hyattsville, MD, Public Health Service. 10-1-0089.
12 Rorabeck C H, Murray P. Cost effectiveness of revision total knee replacement. Instructional Course Lectures. 1997;46:237-240. [pmid: 9143968].
13 Saleh K J, Wood K C, Gafni A, Gross A E. Immediate surgery versus waiting list policy in revision total hip arthroplasty. An economic evaluation. J Arthroplasty. 1997;12(1):1-10. [pmid: 9021495].
14 Iorio R, Healy W L, Richards J A. Comparison of the hospital cost of primary and revision total hip arthroplasty after cost containment. Orthopaedics. 1999;22(2):185-189.
15 Praemer A, Furner S, Rice D. Musculoskeletal conditions in the United States. 1992. American Academy of Orthopaedic Surgeons.
16 Insall JN, Dethmers DA. Revision of total knee arthroplasty. Clinical Orthopaedics & Related Research 1982;(170):123–130.
17 Mendenhall S. Get the lowdown on orthopaedic implants. Mater Manag Health Care. 1996;5(4):30-32. [pmid: 10157554].
18 Coyte P C, Young W, Williams J I. Devolution of hip and knee replacement surgery?. Can J Surg. 1996;39(5):373-378. [pmid: 8857984].
19 Heck D A, Melfi C A, Mamlin L A, Katz B P, Arthur D S, Dittus R S, et al. Revision rates after knee replacement in the United States. Med Care. 1998;36(5):661-669. [pmid: 9596057].
20 Johanson N, Michaels S, Burrows B. Results of revision knee replacement with standard, modular and constrained devices. In: Lotke T, Garino J, editors. Revision total knee arthroplasty. Philadelphia: Lippincott-Raven, 1999: 355–370.
21 Haas S B, Insall J N, Montgomery W III, Windsor R E. Revision total knee arthroplasty with use of modular components with stems inserted without cement. Journal of Bone & Joint Surgery - American Volume. 1995;77(11):1700-1707.
22 Healy W L, Finn D. The hospital cost and the cost of the implant for total knee arthroplasty. A comparison between 1983 and 1991 for one hospital. J Bone Joint Surg Am. 1994;76(6):801-806. [pmid: 8200886].
23 Lavernia CJ, Drakeford MK, Tsao AK, Gittelsohn A, Krackow KA, Hungerford DS. Revision and primary hip and knee arthroplasty. A cost analysis. Clin Orthop 1995;(311):136–141.
24 Callahan C M, Drake B G, Heck D A, Dittus R S, Ritter M A, Faris P M, et al. Patient outcomes following tricompartmental total knee replacement. A meta-analysis Postoperative alignment of total knee replacement. Its effect on survival. JAMA. 1994;271(17):1349-1357. [pmid: 8158821].
25 Cooper H, Hedges LV. The handbook of research synthesis. New York: Russell Sage Foundation, 1994.
26 LeLorier J, Gregoire G, Benhaddad A, Lapierre J, Derderian F. Discrepancies between meta-analyses and subsequent large randomized, controlled trials. N Engl J Med. 1997;337(8):536-542. [pmid: 9262498].
27 Callahan CM, Drake BG, Heck DA, Dittus RS. Patient outcomes following unicompartmental or bicompartmental knee arthroplasty. A meta-analysis. J Arthroplasty 1995; 10(2):141–150.