# Appendix D. Abstracting Form

ASSESSMENT OF STUDY QUALITY (based on "Systems to Rate the Strength of Scientific Evidence, AHRQ Publication No. 02-E016, April 2002)

Score each domain on a scale of 0 (poor, not defined) to 5 (excellent, clearly defined)

Outcome Scores: If more than one followup is reported, record and note each time interval.

Postop (Postoperative) Followup: please indicate years, or months