# Appendix C. Exact Search Strings

## Search Strings for Total Knee Arthroplasty (TKA) Outcomes

The literature search was done using the following combination of MeSH headings, keywords, and publication types:

(arthroplasty, replacement, knee [mh] OR

knee prosthesis [mh] OR

“knee replacement” OR

“knee implant” OR

((TKAR OR prosthesis design [mh]) AND

(knee [mh] OR knee injuries [mh] OR knee joint [mh])))

AND

(meta-analysis [pt] OR

clinical trial [pt] OR

controlled clinical trial [pt] OR

randomized controlled trial [pt] OR

review [pt] OR

review literature [pt] OR

review, multicase [pt] OR

multicenter study [pt] OR

guideline [pt] OR

practice guideline [pt] OR

consensus development conference [pt] OR

evaluation studies [pt] OR

validation studies [pt] OR

clinical trials [mh] OR

controlled clinical trials [mh] OR

cohort studies [mh] OR

retrospective studies [mh] OR

prospective studies [mh] OR

followup studies [mh] OR

cross-sectional studies [mh] OR

double-blind method [mh] OR

comparative stud y[mh] OR

questionnaires [mh] OR

outcome assessment (health care) [mh] OR

treatment outcome [mh] OR

statistics [mh] OR

small-area analysis [mh] OR

cross-cultural comparison [mh] OR

cross-over studies [mh] OR

epidemiologic studies [mh] OR

longitudinal studies [mh] OR

multicenter studies [mh] OR

nursing evaluation research [mh] OR

multivariate analysis [mh] OR

psychometrics [mh] OR

evaluation studies [mh] OR

empirical research [mh] OR

data collection [mh] OR

“systematic review*” OR

“systematic literature review*” OR

meta-analysis OR

meta-analysis OR

meta-analyses OR

evidence-based OR

“case series”)

## Search Strings for Total Knee Arthroplasty Access

The literature search was done via PubMed using the following combination of MeSH headings and keywords:

knee prosthesis/ut

OR

((arthroplasty, replacement, knee [mh] OR

knee prosthesis [mh])

AND

(gender OR

race OR

bias OR

prejudice OR

disparity OR

physician's practice pattern [mh]))

## Search Strings for Total Knee Arthroplasty Revisions

The search consisted of the following combination of MeSH headings and keywords:

((arthroplasty, replacement, knee[mh] OR

knee prosthesis[mh])

AND

(reoperation [mh] OR

revision, joint [mh])).