# Appendix B. Technical Expert Panel Members and Reviewers

## Evidence Based Practice Center (EPC) - Total Knee Arthroplasty Technical Expert Panel Members

We are indebted to the Technical Expert Panel Members for providing both consultation during the development of this project and feedback on the initial draft.

Chris Callahan, MD

Indiana University School of Medicine

Regenstrief Institute

Indianapolis, IN

John Fitzgerald, MD

UCLA Medical Center

Los Angeles, CA

Richard Iorio, MD (Abstractor)

Lahey Clinic

Burlington MA

William Macaulay, MD (Abstractor)

Orthopaedic Surgery

Columbia University

New York, NY

John Melvin, MD

Department of Rehabilitation Medicine

Jefferson Medical College of Thomas Jefferson University

Philadelphia, PA

Patrick Murray, MD

MetroHealth Medical Center

Case Western Reserve University

Cleveland, OH

Charles. Nelson, MD (Abstractor)

Orthopaedic Surgery

University of Pennsylvania

Philadelphia PA

Cecil Rorabeck, MD

President, Knee Society

London, Ontario

CANADA

Roby Thompson, MD

University of Minnesota Medical School

Minneapolis, MN

Peter Tugwell, MD

Centre for Global Health

University of Ottawa

Ottawa, Ontario

CANADA

## Evidence Based Practice Center (EPC) - Total Knee Arthroplasty Reviewers

We are grateful for the constructive feedback provided by the following individuals who reviewed the initial draft of this report. Acknowledgements are made with the explicit statement that this does not constitute endorsement of the report.

David Atkins, MD

Agency for Health Care Policy and Research

Rockville, MD

Kevin Bozic, MD

University of California, San Francisco

San Francisco, CA

David Heck, MD

Indiana University

Indianapolis, IN

E. Anthony Rankin, MD

Providence Hospital

Washington, DC

Aaron Rosenberg, MD

Rush Presbyterian Medical College, Chicago

Chicago, IL