# Appendix A. Measurement Scales

## The Hospital for Special Surgery (HSS)

## Knee Society Score (KS)

## Western Ontario and MacMaster University (WOMAC) Osteoarthritis Index