# Appendixes

Appendix A. Measurement Scales

Appendix B. Technical Expert Panel Members and Reviewers

Appendix C. Exact Search Strings

Appendix D. Abstracting Form

Appendix E. Functional Outcome Following Total Knee Arthroplasty Revision: A Meta-analysis

Appendix F. Evidence Tables