# Supplement Appendix. Interview Guides

## Guides for Focus Groups

[underlined: Brain injury or stroke patients with no HBOT experience (February 23, 2002)]

Introduction of study personnel

Purpose of focus group and importance of their roles

Signing the consent forms

Introductions: name, their injury (what it was, date, outcome)

Ground rules: all discussion voluntary, no criticism, confidentiality assured, try to represent peers

Exercise: write down the five worst things about their episode's aftermath; five positive things?

Go around and list them

List? What outcomes do they desire? Describe a really good outcome

Which are most important? Make up a scale and rate them (really important, moderately or less)

How important is duration of each outcome? For what outcomes would you be willing to accept only short-term outcomes?

What might your caregiver say?

Inconveniences and discomforts

Imagine that there is a therapy that can be delivered in a submarine that is perfectly safe. How would you feel about entering the submarine? On a daily or weeky basis?

Let me summarize what we've learned today: Have we missed anything?

[underlined: Brain injury or stroke patients/caregivers with HBOT experience (March 11, 2002)]

Signing the consent forms

Introduction of study personnel

Purpose of focus group and importance of their roles

Ground rules: all discussion voluntary, no criticism, confidentiality assured, try to represent peers

Introductions: name, their injury (what it was, date, outcome), therapies besides HBOT they've tried

Exercise: write down the five worst things about their situation; five positive things?

Go around and list them

List? What outcomes do they desire? Describe a really good outcome

What outcomes did HBOT produce?

Which are most important? Make up a scale and rate them (really important, moderately or less)

Outcome if short term Importance 1 to 3

Outcome if long term Importance 1 to 3

How important is duration of each outcome? For what outcomes would you be willing to accept only short-term outcomes?

What might your child say?

Inconveniences and discomforts

Let me summarize what we've learned today: Have we missed anything?

[underlined: Clinicians with HBOT experience (March 15, 2002)]

Signing the consent forms

Introduction of study personnel

Purpose of focus group and importance of their roles

Ground rules: all discussion voluntary, no criticism, confidentiality assured, try to represent peers

Introductions: name, their background that led to interest in HBOT

How did interest develop?

Upsides and downsides

- The good and bad for each condition
- Inconveniences and discomforts

What outcomes do they desire? Describe a really good outcome

What outcomes did HBOT produce? Listen for coordination, weakness, walking, cognition

Which are most important? Make up a scale and rate them (really important, moderately or less)

Outcome if short term Importance 1 to 3

Outcome if long term Importance 1 to 3

How important is duration of each outcome? For what outcomes would you or patients or caregivers be willing to accept only short term outcomes?

The SPECT scan issue

Focus on CP and stroke issues

Future research suggestions

Let me summarize what we've learned today: Have we missed anything?

## Guide for Individual Interviews

(This is a generic guide; these questions were always covered, but more specific questions and probing questions were also asked in addition to these.)

Introductions

Discuss the consent form

Purpose of project and interview

Can you start out by telling me what led up to your/his/her first HBO treatment?

Had you heard about HBO before? How did you hear about it?

What was the course of treatment like? How many? Kind of chamber? Did caregiver accompany? Feelings about it?

What difference did you notice and at what point in treatment? What was the most exciting breakthrough, if any?

Were there any discomforts or inconveniences?

What other therapies were you undergoing at the same time? Prior to HBO?

One of the things we're trying to find out is how people value the outcomes of HBO. What good does it do and what is it worth to you? To your caregiver or child?

Let me summarize what we've learned today: have we missed anything?