# Abbreviations and Acronyms

ATA = Atmospheres absolute

ATM = Atmosphere

BI = Brain injury

CDER = Center for Drug Evaluation and Research

CDRH = Center for Devices and Radiological Health

CINAHL = Cumulative Index to Nursing & Allied Health

CNS = Central nervous system

CP = Cerebral palsy

CT = Computerized tomography

DARE = Database of Abstracts of Reviews of Effectiveness

EEG = Electroencephalogram

EIAB = Extra-intracranial arterial bypass

FIM = Functional Independence Measure

GCS = Glasgow Coma Scale

GMFM = Gross Motor Function Measure

GOS = Glasgow Outcomes Scale

HBOT = Hyperbaric oxygen therapy

HealthSTAR = Health Service Technology, Administration and Research

ICP = Intracranial pressure

ICU = Intensive Care Unit

IND = Investigational New Drug Application

IRB = Institutional Review Board

JCAHO = Joint Commission on Accreditation of Healthcare Organizations

LOS = Length of stay

MANTIS = Manual, Alternative and Natural Therapy

MRI = Magnetic resonance imaging

NRCT = Nonrandomized controlled trial

NS = Nonsignificant

PEDI = Pediatric Evaluation of Disabilities Inventory

RCT = Randomized controlled trial

SPECT = Single Photon Emission Computed Tomography

TBI = Traumatic brain injury

TEAG = Technical Expert Advisory Group

TIA = Transient ischemic attack