# Bibliography

Hyperbaric oxygenation for cerebral palsy - (multiple letters). Lancet 2001;357:2052–2054.
Abbott D F. Slow recovery from carbon monoxide poisoning. Postgrad Med J. 1972;48(564):639-642. [pmid: 5079183].
Ackerman W E. Hyperbaric oxygen therapy as treatment for carbon monoxide poisoning. J Ky Med Assoc. 1985;83(8):401-403. [pmid: 3928784].
Adams H P Jr, Brott T G, Crowell R M, et al. Guidelines for the management of patients with acute ischemic stroke. A statement for healthcare professionals from a special writing group of the Stroke Council, American Heart Association. Stroke. 1994;25(9):1901-1914. [pmid: 8073477].
Akimov G A, Lobzin V S, Sapov I A, et al. Assessment of the efficiency of hyperbaric oxygenation therapy in early forms of cerebrovascular disorders. Neurosci Behav Physiol. 1985;15(1):13-17. [pmid: 4000466].
Akman M N, Loubser P G, Fife C E, et al. Hyperbaric oxygen therapy: implications for spinal cord injury patients with intrathecal baclofen infusion pumps. Case report. Paraplegia. 1994;32(4):281-284. [pmid: 8022638].
Albers G W, Amarenco P, Easton J D, et al. Antithrombotic and thrombolytic therapy for ischemic stroke. Chest. 2001;119(1 Suppl):300S-320S. [pmid: 11157656].
Albert T W, Smith J D, Everts E C, et al. Dacron mesh tray and cancellous bone in reconstruction of mandibular defects. Arch Otol Head Neck Surg. 1986;112(1):53-59.
Albin M S. Air embolism. Anesth Clin N Amer. 1993;11(1):1-24.
Alexander E Jr. Medical management of closed head injuries. Clin Neurosurg. 1972;19:240-250. [pmid: 4637553].
Alexander J, Takeda D, Sanders G, et al. Fatal necrotizing fasciitis following suction-assisted lipectomy. Ann Plast Surg. 1988;20(6):562-565. [pmid: 3389707].
Alvis H J. What hyperbaric medicine has to offer the industrial physician. J Occup Med. 1967;9(6):304-307. [pmid: 4290742].
Amonic R S, Cockett A T, Lorhan P H, et al. Hyperbaric oxygen therapy in chronic hemorrhagic shock. JAMA. 1969;208(11):2051-2054. [pmid: 5305672].
Anand A, Anand N, Anand A, et al. Rhinocerebral mucormycosis: Cure without surgery?. Arch Int Med. 1996;156(19):2262-2269. [pmid: 8885828].
Anand I S. Letter from the Siachen Glacier. High Alt Med Biol. 2001;24(4):553-557. [pmid: 11809097].
Anand V K, Alemar G, Griswold J A Jr. Intracranial complications of mucormycosis: an experimental model and clinical review. Laryngoscope. 1992;102(6):656-662. [pmid: 1602914].
Anderson B Jr, Heyman A, Whalen R E, et al. Migraine-like phenomena after decompression from hyperbaric environment. Neurology. 1965;15(11):1035-1040. [pmid: 5892409].
Anderson B Jr, Saltzman H A. Hyperbaria, hybaroxia, and the retinal and cerebral vessels. Headache. 1965;5(3):73-77. [pmid: 5829845].
Anderson D C, Bottini A G, Jagiella W M, et al. A pilot study of hyperbaric oxygen in the treatment of human stroke. Stroke. 1991;22(9):1137-1142. [pmid: 1926256].
Anderson D C, Slater G E, Sherman R, et al. Evoked potentials to test a treatment of chronic multiple sclerosis. Arch Neurol. 1987;44(12):1232-1236. [pmid: 3675257].
Anderson V A, Catroppa C, Haritou F, et al. Predictors of acute child and family outcome following traumatic brain injury in children. Pediatr Neurosurg. 2001;34(3):138-48. [pmid: 11359102].
Andrews P J, Sleeman D H, Statham P F, et al. Predicting recovery in patients suffering from traumatic brain injury by using admission variables and physiological data: a comparison between decision tree analysis and logistic regression. J Neurosurg. 2002;97(2):326-36. [pmid: 12186460].
Anegawa S, Hayashi T, Torigoe R, et al. Magnetic resonance imaging of fat embolism syndrome--case report. Neurol Med Chir. 1991;31(6):359-361.
Anonymous. Hyperbaric oxygen and senile psychosis. Lancet 1969;2(7634):1348.
Anonymous. Hyperbaric oxygen therapy. Med Letter Drugs Therap 1971;13(8):29–32.
Anonymous. Late sequelae of carbon monoxide poisoning. Lancet 1984;2(8403):637–638.
Anonymous. Brain resuscitation. Heart Lung 1986;15(5):537–538.
Anonymous. Complications of hyperbaric oxygenation in the treatment of head and neck disease. Otolaryngol Head Neck Surg 1987;96(2):211–219.
Anonymous. Hyperbaric oxygen in the treatment of osteoradionecrosis: a review of its use and efficacy. Oral Surg Oral Med Oral Pathol 1987;64(4):413–416.
Anonymous. Some defenders of hyperbaric oxygen. Chest 1988;94(2):414–421.
Anonymous. Hyperbaric oxygen in experimental and clinical cerebral ischemia. Presented at: International Society of Hyperbaric Medicine 5th Symposium. Word Meeting of Hyperbaric Medicine; Capri, Italy; 1991.
Anonymous. Stroke treatment. Lancet 1991;337(8757):1601.
Anonymous. Cerebral amino acids and acute hyperbaric oxygen toxicity. Undersea Hyperb Med 1992;19:158.
Anonymous. Economic costs of birth defects and cerebral palsy -- United States, 1992. MMWR 1995;44(37):694–9.
Anonymous. Horizons. Hyperbaric oxygen and relief of migraine and cluster headache. J Neurosci Nurs 1995;27(4):261.
Anonymous. Assessment of brain SPECT. Report of the Therapeutics and Technology Assessment Subcommittee of the American Academy of Neurology. Neurology 1996;46(1):278–285.
Anonymous. The International Stroke Trial (IST): a randomised trial of aspirin, subcutaneous heparin, both, or neither among 19435 patients with acute ischaemic stroke. International Stroke Trial Collaborative Group. Lancet 1997;349(9065):1569–1581.
Anonymous. New products. Clin Nurs Spec 1998;12(6):256.
Anonymous. Brain injury improves with hyperbaric oxygen. Life Extension 1999:71.
Anonymous. Hyperbaric oxygen therapy for wound healing - part III. Technologica MAP Suppl 1999:11–14.
Anonymous. Present status of hyperbaric oxygen therapy for the treatment of cerebral palsy. American Academy for Cerebral Palsy and Developmental Medicine. 1999.
Anonymous. Rehabilitation of persons with traumatic brain injury. Report of the NIH Consensus Development Conference. Bethesda, MD: National Institutes of Health. National Institute of Child Health and Development. 1999.
Anonymous. Hyperbaric oxygen preconditioning induces neuroprotection against ischemia in transient not permanent middle cerebral artery occlusion rat model. Chin Med J 2000;113(9):836–839.
Anonymous. Hyperbaric oxygen therapy: its use and appropriateness. Dallas, TX: Office of Inspector General, Department of Health and Human Services. 2000. Report Number OEI 06-99-00090.
Anonymous. Hyperbaric oxygenotherapy in Quebec - systematic review. Agence d'Evaluation des Technologies et des Modes d'Intervention en Sante. 2000.
Anonymous. Hyperbaric oxygen chambers (project). Israeli Center for Technology Assessment in Health Care. 2001.
Anonymous. Hyperbaric oxygen therapy. Medicare Services Advisory Committee. 2001.
Anonymous. 2002. Doctor shows courage in beating cancer. Lilia's Good Health. http://www.clickondetroit.com/det/health/lilasgoodhealth/stories/lilasgoodhealth-155734620020712-230745.html Available:2002
Anonymous. A review of the scientific evidence on the treatment of traumatic brain injuries and strokes with hyperbaric oxygen. Brain Inj 2003;17(3):225–36.
Aoki N, Uchinuno H, Tanikawa T, et al. Superior sagittal sinus thrombosis treated with combined local thrombolytic and systemic anticoagulation therapy. Acta Neurochir. 1997;139(4):332-335.
Armon C, Deschamps C, Adkinson C, et al. Hyperbaric treatment of cerebral air embolism sustained during an open-heart surgical procedure. Mayo Clin Proc. 1991;66(6):565-571. [pmid: 2046394].
Arness M K. Scuba decompression illness and diving fatalities in an overseas military community. Aviat Space Environ Med. 1997;68(4):325-333. [pmid: 9096830].
Artru F, Chacornac R, Deleuze R. Hyperbaric oxygenation for severe head injuries: preliminary results of a controlled study. Eur Neurol. 1976;14(4):310-318. [pmid: 782888].
Artru F, Philippon B, Gau F, et al. Cerebral blood flow, cerebral metabolism and cerebrospinal fluid biochemistry in brain-injured patients after exposure to hyperbaric oxygen. Eur Neurol. 1976;14(5):351-364. [pmid: 7459].
Ash JS, Gorman PN, Lavelle M, et al. Multiple perspectives on physician order entry. Proc AMIA Symp 2000:27–31.
Ashamalla H L, Thom S R, Goldwein J W. Hyperbaric oxygen therapy for the treatment of radiation-induced sequelae in children: the University of Pennsylvania experience. Cancer. 1996;77(11):2407-2412. [pmid: 8635114].
Aslam M. Medical scenario underwater. J Coll Phys Surg Pakistan. 2001;11(7):411-413.
Asola M R. A diver unconscious after gastroenteritis. Lancet. 1995;346(8986):1338. [pmid: 7475775].
Atkins H L, Chang C H. Recent advances in radiation therapy of intracranial malignancy. Clin Neurosurg. 1965;13:156-180. [pmid: 5331762].
Auer R N. Non-pharmacologic (physiologic) neuroprotection in the treatment of brain ischemia. Ann NY Acad Sci. 2001;939:271-282. [pmid: 11462780].
Badr A E, Yin W, Mychaskiw G, et al. Dual effect of HBO on cerebral infarction in MCAO rats. Am J Physiol Regul Integrat Compar Physiol. 2001;280(3):R766-R770.
Baethmann A, Lanksch W, Schmiedek P. Formation and treatment of cerebral edema. Neurochirurgia. 1974;17(2):37-47. [pmid: 4838721].
Balzan M, Cacciottolo J M, Casha A. Intestinal infarction following carbon monoxide poisoning. Postgrad Med J. 1993;69(810):302-303. [pmid: 8321796].
Balzan M V, Agius G, Galea D A. Carbon monoxide poisoning: easy to treat but difficult to recognise. Postgrad Med J. 1996;72(850):470-473. [pmid: 8796209].
Barach A L. Oxygen inhalation in obliterative arterial disease, including its use in senility. J Am Geriatr Soc. 1970;18(9):708-713. [pmid: 5458753].
Baraka A. Anaesthetic problems during the tragic civil war in Lebanon. Mid East J Anaesthesiol. 1978;5(1):7-19.
Barker R A, Dick D J, Cochius J I. Delayed postanoxic encephalopathy and pseudodeficiency of arylsulphatase A. J Neurol. 1999;246(11):1103-1104. [pmid: 10631649].
Barrett K, Harch P, Masel B, et al. Cognitive and cerebral blood flow improvements in chronic stable traumatic brain injury induced by 1.5 ATA hyperbaric oxygen. Undersea Hyperb Med 1998;25(9).
Barrett KF, Corson KP and Mader JT. Pediatric cerebral palsy treatment by 1.5 ATA hyperbaric oxygen - a pilot study [abstract]. 2001.
Bartsch P. Treatment of high altitude diseases without drugs. Int J Sports Med 1992;13:Suppl-4.
Bateman A, Culpan F J, Pickering A D, et al. The effect of aerobic training on rehabilitation outcomes after recent severe brain injury: a randomized controlled evaluation. Arch Phys Med Rehab. 2001;82(2):174-82.
Bateman C. Spending good money on thin air. S Afr Med J. 2001;91(6):453-454. [pmid: 11847911].
Baum WK. Oral history for the local historical society. Blue Ridge Summit, PA: Alta Mira Press; 1987.
Baumgartner R W, Frick A, Kremer C, et al. Microembolic signal counts increase during hyperbaric exposure in patients with prosthetic heart valves. J Thorac Cardiovasc Surg. 2001;122(6):1142-1146. [pmid: 11726888].
Bax M. Terminology and classification of cerebral palsy. Dev Med Chil Neurol. 1964;57:153-158.
Bell M D D, Cope T, Harrison J. The use of hyperbaric oxygen in the management of severe anaemia in a Jehovah's Witness (multiple letters). Anaesthesia. 2000;55(3):293-294. [pmid: 10744564].
Belokurov M. HBO in the combined therapy of comatose states in children. Pediatria 1988.
Belokurov MI. Hyperbaric oxygenation in the combined therapy of comatose states in children. Pediatria 1988(2):84–87.
Bembridge M, MacDonald R, Lyons G. Spinal anaesthesia with hyperbaric lignocaine for elective Caesarean section. Anaesthesia. 1986;41(9):906-909. [pmid: 3777394].
Ben Yishai Y, Diller L. Changing of atmospheric environment to improve mental and behavioral function. Applications in treatment of senescence. NY State J Med. 1973;73(24):2877-2880.
Ben Yishay Y, Diller L, Reich T, et al. Can oxygen reverse symptoms of senility?. NY State J Med. 1978;78(6):914-919.
Ben Yishay Y, Diller L, Warga C, et al. The alleviation of cognitive and functional impairments in senility by hyperbaric, oxygenation combined with systematic cuing. In: Trapp WG, Bannister EW, Davison AJ, et al., editors. Fifth International Hyperbaric Conference. Fifth International Hyperbaric Conference. Burnaby, Canada: Simon Fraser University Press; 1974. p. 424–431.
Benton P J, Woodfine J D, Westwood P R. Arterial gas embolism following a 1-meter ascent during helicopter escape training: a case report. Aviat Space Environ Med. 1996;67(1):63-64. [pmid: 8929206].
Berg BL. Qualitative research methods for the social sciences, 4th edition. Boston: Allyn & Bacon; 2001.
Bergo G W, Tyssebotn I. Cerebral blood flow and systemic hemodynamics during exposure to 2 kPa CO2-300 kPa O2 in rats. J Appl Physiol. 1995;78(6):2100-2108. [pmid: 7665406].
Bergo G W, Tyssebotn I. Repeated exposure to 5 bar normoxic He-N2 changes cerebral blood flow distribution in rats. J Appl Physiol. 1995;78(6):2109-2114. [pmid: 7665406].
Bergo G W, Tyssebotn I. Cardiovascular effects of hyperbaric oxygen with and without addition of carbon dioxide. Eur J App Physiol Occup Physiol. 1999;80(4):264-275.
Bernhardt T L, Goldmann R W, Thombs P A, et al. Hyperbaric oxygen treatment of cerebral air embolism from orogenital sex during pregnancy. Crit Care Med. 1988;16(7):729-730. [pmid: 3371050].
Berry G H. A clinical appraisal of hyperbaric oxygen in head and neck cancer. Br J Radiol. 1978;51(602):150.
Berry G H, Dixon B. The Leeds result for radiotherapy in HBO for carcinoma of the head and neck. Clin Radiol. 1979;30(5):591-592. [pmid: 466964].
Bertelli A, Giovannini L, Mian M, et al. Protective action of propionyl-L-carnitine on toxicity induced by hyperbaric oxygen. Drug Exp Clin Res. 1990;16(10):527-530.
Beuerlein M, Nelson R N, Welling D B. Inner and middle ear hyperbaric oxygen-induced barotrauma. Laryngoscope. 1997;107(10):1350-1356. [pmid: 9331312].
Bischof F. Hyperbaric oxygen therapy in cerebral palsy. S Afr Med J. 2001;91(3):182. [pmid: 11291406].
Bitterman H, Melamed Y. Delayed hyperbaric treatment of cerebral air embolism. Isr J Med Sci. 1993;29(1):22-26. [pmid: 8454441].
Bloom H J. Combined modality therapy for intracranial tumors. Cancer. 1975;35(1):111-120. [pmid: 162849].
Blum D, Viart P, Szliwowski H B, et al. Exchange transfusion and hyperbaric oxygen in the treatment of children with acute hepatic failure. Helv Paediatr Acta. 1972;27(4):425-436. [pmid: 4644278].
Boelaert J R. Mucormycosis (zygomycosis): Is there news for the clinician?. J Infect. 1994;28(SUPPL.1):1-6. [pmid: 8077686].
Bohlega S, McLean D R. Hemiplegia caused by inadvertent intra-carotid infusion of total parenteral nutrition. Clin Neurol Neurosurg. 1997;99(3):217-219. [pmid: 9350405].
Bohmer D. Treating tinnitus with hyperbaric oxygenation. Int Tinnitus J. 1997;3(2):137-140. [pmid: 10753376].
Bot H, Bruggemans E F, Delemarre B J, et al. Microembolic signals under increased ambient pressure. Stroke. 1998;29(5):1069-1070. [pmid: 9596262].
Boudewyns A, Claes J. Acute cochleovestibular toxicity due to topical application of potassium iodide. Eur Arch Oto Rhino Laryng. 2001;258(3):109-111.
Boussuges A, Thirion X, Blanc P, et al. Neurologic decompression illness: a gravity score. Undersea Hyperb Med. 1996;23(3):151-155. [pmid: 8931282].
Bove A A, Clark J M, Simon A J, et al. Successful therapy of cerebral air embolism with hyperbaric oxygen at 2.8 ATA. Undersea Biomed Res. 1982;9(1):75-80. [pmid: 7090084].
Boyle C A, Yeargin-Allsopp M, Doernberg N S, et al. Prevalence of selected developmental disabilities in children 3–10 years of age: the Metropolitan Atlanta Developmental Disabilities Surveillance Program, 1991. MMWR. 1996;45(2):1-14.
Boyle E, Aparicio A, Canosa F, et al. Hyperbaric oxygen and acetazolamide in the treatment of senile cognitive functions. In: Trapp WG, Bannister EW, Davison AJ, et al., editors. Fifth International Hyperbaric Conference. Burnaby, Canada: Simon Fraser University Press; 1974. p. 432–438.
Branger A B, Lambertsen C J, Eckmann D M. Cerebral gas embolism absorption during hyperbaric therapy: theory. J Appl Physiol Respir Environ Exercise Physiol. 2001;90(2):593-600.
Braun R, Krishel S. Environmental emergencies. Emerg Med Clin N Am. 1997;15(2):451-476.
Brink T L. The battle against senility. MH. 1977;61(2):11. [pmid: 593151].
Bristow J H, Kassar B, Sevel D. Gas gangrene panophthalmitis treated with hyperbaric oxygen. Br J Ophthamol. 1971;55(2):139-142.
Broome J R, Dick E J Jr. Neurological decompression illness in swine. Aviat Space Environ Med. 1996;67(3):207-213. [pmid: 8775397].
Broome J R, Smith D J. Pneumothorax as a complication of recompression therapy for cerebral arterial gas embolism. Undersea Biomed Res. 1992;19(6):447-455. [pmid: 1304671].
Brown D B, Golich F C, Tappel J J, et al. Severe carbon monoxide poisoning in the pediatric patient: a case report. Aviat Space Environ Med. 1996;67(3):262-265. [pmid: 8775406].
Brown J A, Preul M C, Taha A. Hyperbaric oxygen in the treatment of elevated intracranial pressure after head injury. Pediatr Neurosci. 1988;14(6):286-290. [pmid: 3270048].
Bruce D A, Raphaely R C, Goldberg A I, et al. Pathophysiology, treatment and outcome following severe head injury in children. Childs Brain. 1979;5(3):174-191. [pmid: 456099].
Brunet LW, Morrissey CY and Gorry GA. Oral history and information technology: human voices of assessment. Organ Comput 1991(1):251–274.
Bubenik G A, Blask D E, Brown G M, et al. Prospects of the clinical utilization of melatonin. Biol Signals Recept. 1998;7(4):195-219. [pmid: 9730580].
Buchan A M. Can pure oxygen prevent stroke damage?. Crit Care Med. 2000;28(8):3101-3102. [pmid: 10966313].
Buechler C M, Blostein P A, Koestner A, et al. Variation among trauma centers' calculation of Glasgow Coma Scale score: results of a national survey. J Trauma Inj Infect Crit Care. 1998;45(3):429-32.
Bulger E M, Nathens A B, Rivara F P, et al. Management of severe head injury: Institutional variations in care and effect on outcome. Crit Care Med. 2002;30(8):1870-6. [pmid: 12163808].
Bullock R M, Chesnut R, Clifton G L, et al. Management and prognosis of severe traumatic brain injury, part 1: Guidelines for the management of severe traumatic brain injury. J Neurotrauma. 2000;17:451-553.
Buonanno F, Toole J F. Management of patients with established (“completed”) cerebral infarction. Stroke. 1981;12(1):7-16. [pmid: 7013163].
Burkhart K K, Kulig K W. The diagnostic utility of flumazenil (a benzodiazepine antagonist) in coma of unknown etiology. Ann Emerg Med. 1990;19(3):319-321. [pmid: 1977339].
Burm A G, Van Kleef J W, Galdines M P. Plasma concentrations of lidocaine and bupivacaine after subarachnoid administration. Anesthesiology. 1983;59(3):191-195. [pmid: 6881583].
Busse E W. Biologic and sociologic changes affecting adaptation in mid and late life. Ann Int Med. 1971;75(1):115-120. [pmid: 5091551].
Butler C S, Barnett R J, Wilson M. An unusual presentation of pulmonary tuberculosis. Med J Aust. 1998;168(3):119-120. [pmid: 9484329].
Butler F K Jr. Diving and hyperbaric ophthalmology. Surv Ophthamol. 1995;39(5):347-366.
Cable G G, Keeble T, Wilson G. Pulmonary cyst and cerebral arterial gas embolism in a hypobaric chamber: a case report. Aviat Space Environ Med. 2000;71(2):172-176. [pmid: 10685592].
Calverley R K, Dodds W A, Trapp W G, et al. Hyperbaric treatment of cerebral air embolism: a report of a case following cardiac catheterization. Can Anaesth Soc J. 1971;18(6):665-674. [pmid: 5119806].
Calvert J W, Yin W, Patel M, et al. Hyperbaric oxygenation prevented brain injury induced by hypoxia-ischemia in a neonatal rat model. Brain Res. 2002;951(1):1-8. [pmid: 12231450].
Caplan LR. Caplan's Stroke: a clinical approach. Boston: Butterworth and Heinemann; 2000.
Carter R, Wilson C. Newspaper hype. BMJ. 1996;312(7039):1163. [pmid: 8688796].
Catron P W, Dutka A J, Biondi D M, et al. Cerebral air embolism treated by pressure and hyperbaric oxygen. Neurology. 1991;41(2: Pt 1):1-5. [pmid: 1992383].
Centers for Medicare and Medicaid. Transmittal 164. National Coverage Determinations (NCDs)
Hyperbaric Oxygen Therapy. In: Medicare Coverage Issues Manual; 2002. p. 10–13.
Chang C H. Hyperbaric oxygen and radiation therapy in the management of glioblastoma. N Cancer Inst Monog. 1977;46:163-169.
Chavdarov I. The effects of hyperbaric oxygenation on psycho-motor functions by children with cerebral palsy. Presented at: Proceedings of the 2nd International Symposium on Hyperbaric Oxygenation in Cerebral Palsy and the Brain-injured Child; 2002.
Chen C F, Fang H S. Influence of age on hyperoxic resistance. J Formosan Med Assoc. 1980;79(5):460-463.
Chen C F, Jia H Y, Zhao X Y, et al. Auditory P300, CT scans and cognitive state in Binswanger's Disease. Chin J Physiol. 1997;40(1):19-24. [pmid: 9170551].
Cheng T. Effect of vasopressin and oxytocin on the reactions of rats to hyperbaric oxygen exposure. Chin J Physiol Sci. 1990;6(3):211-217.
Chesire WP and Ott MC. Headache in divers. Headache 2001(41(2)):235–247.
Chesnut R, Carney N, Maynard H, et al. Rehabilitation for traumatic brain injury. Rockville, MD: Agency for Health Care Policy and Research Report Number 2. 1999.
Chesnut R M, Marshall L F, Klauber M R, et al. The role of secondary brain injury in determining outcome from severe head injury. J Trauma. 1993;34(2):216-222. [pmid: 8459458].
Chew H E, Hanson G C, Slack W K. Hyperbaric oxygenation. Br J Dis Chest. 1969;63(3):113-139. [pmid: 4894365].
Chuba P J, Aronin P, Bhambhani K, et al. Hyperbaric oxygen therapy for radiation-induced brain injury in children. Cancer. 1997;80(10):2005-2012. [pmid: 9366305].
Chuba P J, Zamarano L, Hamre M, et al. Permanent I-125 brain stem implants in children. Childs Nerv Syst. 1998;14(10):570-577. [pmid: 9840381].
Chung MM, Strauss MB, Nation PA, et al. Clinical outcomes of carbon monoxide poisoned comatose patients. Undersea Hyperb Med Suppl 1996;23(May 12–26):89.
Cianci P, Posin J P, Shimshak R R, et al. Air embolism complicating percutaneous thin needle biopsy of lung. Chest. 1987;92(4):749-751. [pmid: 3652765].
Cianci P, Sato R. Adjunctive hyperbaric oxygen therapy in the treatment of thermal burns: a review. Burns. 1994;20(1):5-14. [pmid: 8148076].
Cirafisi C, Verderame F. Radiation-induced rhombencephalopathy. Ital J Neurol Sci. 1999;20(1):55-58. [pmid: 10933486].
Clark D E, Ryan L M. Concurrent prediction of hospital mortality and length of stay from risk factors on admission. Health Serv Res. 2002;37(3):631-45. [pmid: 12132598]. [pmcid: 1434655].
Clarke D. Hyperbaric oxygen therapy. Am J Emerg Med. 1993;11(4):436-437. [pmid: 8216536].
Clements K S, Vrabec J T, Mader J T. Complications of tympanostomy tubes inserted for facilitation of hyperbaric oxygen therapy. Arch Otol Head Neck Surg. 1998;124(3):278-280.
Clenney T L, Lassen L E. Recreational scuba diving injuries. Am Fam Phys. 1996;53(5):1761-1766.
Clifton G L. Hypothermia and hyperbaric oxygen as treatment modalities for severe head injury. New Horiz Sci Pract Acute Med. 1995;3(3):474-478.
Clifton G L, Miller E R, Choi S C, et al. Lack of effect of induction of hypothermia after acute brain injury. New Engl J Med. 2001;344(8):556-63. [pmid: 11207351].
Coe J E, Hayes T M. Treatment of experimental brain injury by hyperbaric oxygenation. Am Surg. 1966;32:493-495. [pmid: 5938626].
Cohen R J, McNeal J E, Susman M, et al. Sarcomatoid renal cell carcinoma of papillary origin: a case report and cytogenic evaluation. Arch Path Lab Med. 2000;124(12):1830-2. [pmid: 11100068].
Collet J P, Vanasse M, Marois P, et al. Hyperbaric oxygen for children with cerebral palsy: a randomised multicentre trial. Lancet. 2001;357:582-586. [pmid: 11558483].
Connolly K M, McGuirt W F Jr. Elective extracorporeal membrane oxygenation: an improved perioperative technique in the treatment of tracheal obstruction. Ann Otol Rhin Laryng. 2001;110(3):205-209.
Conzen M, Ebel H, Swart E, et al. Long-term neuropsychological outcome after severe head injury with good recovery. Brain Inj. 1992;6(1):45-52. [pmid: 1739852].
Cordoba-Cabeza T and al e. Hyperbaric oxygenation and neurological recovery in children with organic brain damage. Rev Neurol 1998;(158):571–574.
Coric V, Oren D A, Wolkenberg F A, et al. Carbon monoxide poisoning and treatment with hyperbaric oxygen in the subacute phase. J Neurol Neurosurg Psychiatry. 1998;65(2):245-247. [pmid: 9703180].
Couch L, Theilen F, Mader J T. Rhinocerebral mucormycosis with cerebral extension successfully treated with adjunctive hyperbaric oxygen therapy. Arch Otol Head Neck Surg. 1988;114(7):791-794.
Crabtree BF and Miller WL. Doing qualitative research. Newbury Park: Sage; 1992.
Cramer F S. Oxygen and acceleration. Mil Med. 1991;156(11):608-611. [pmid: 1771009].
Cranton E M, Frackelton J P. Free radical pathology in age-associated diseases: treatment with EDTA chelation nutrition, and antioxidants. J Holistic Med. 1984;6(1):6-37.
Cronje F. Hyperbaric oxygen therapy for children with cerebral palsy. S Afr Med J. 2001;91(8):615-616. [pmid: 11584767].
Cronje F, Bever Donker S C, Venter A. Hyperbaric oxygen therapy for children with cerebral palsy. S Afr Med J. 1999;89(4):359-361. [pmid: 10341811].
Crosby L J, Parsons L C. Cerebrovascular response of closed head-injured patients to a standardized endotracheal tube suctioning and manual hyperventilation procedure. J Neurosci Nurs. 1992;24(1):40-49. [pmid: 1532011].
Curran S. Pharmacological treatment of Alzheimer's disease. Presented at: 10th European College of Neuropsychopharmacology Congress; Vienna, Austria; 1997.
Dang Y, Xia C, Brown O R. Effects of oxygen on 3-hydroxyanthranilate oxidase of the kynurenine pathway. Free Radic Biol Med. 1998;25(9):1033-1043. [pmid: 9870556].
Dauman R. Sudden hearing loss: a comparative randomized study of 2 modalities of hyperbaric oxygen therapy in association with Naftidrofuryl. Rev Laryngol Otol Rhinol. 1993;114(1):53-58.
Davis F M, Glover P W, Maycock E. Hyperbaric oxygen for cerebral arterial air embolism occurring during caesarean section. Anaesth Intensive Care. 1990;18(3):403-405. [pmid: 2221336].
Davis J C. Hyperbaric oxygen therapy. J Intens Care Med. 1989;4:55-57.
Davis JC, Dunn JM and Heimbach RD. Hyperbaric medicine: patient selection, treatment procedures, and side-effects. In: Davis JC and Hunt TK, editors. Problem wounds: the role of oxygen. New York: Elsevier; 1988. p. 225–235.
De La Paz M A, Patrinely J R, Marines H M, et al. Adjunctive hyperbaric oxygen in the treatment of bilateral cerebro-rhino-orbital mucormycosis. Am J Ophthamol. 1992;114(2):208-211.
De Reuck J, Decoo D, Lemahieu I, et al. A positron emission tomography study of patients with acute carbon monoxide poisoning treated by hyperbaric oxygen. J Neurol. 1993;240(7):430-434. [pmid: 8410085].
Dean B S, Verdile V P, Krenzelok E P. Coma reversal with cerebral dysfunction recovery after repetitive hyperbaric oxygen therapy for severe carbon monoxide poisoning. Am J Emerg Med. 1993;11(6):616-618. [pmid: 8043054].
Dean J B, Mulkey D K. Continuous intracellular recording from mammalian neurons exposed to hyperbaric helium, oxygen, or air. J Appl Physiol. 2000;89(2):807-822. [pmid: 10926669].
Dearden N M. Management of raised intracranial pressure after severe head injury. Br J Hosp Med. 1986;36(2):94-103. [pmid: 3091130].
Deckel A W. Carbon monoxide poisoning and frontal lobe pathology: two case reports and a discussion of the literature. Brain Inj. 1994;8(4):345-356. [pmid: 8081349].
Delaney J S, Montgomery D L. How can hyperbaric oxygen contribute to treatment?. Physician Sportsmed. 2001;29(3):77-84.
Dembert M L. Scuba diving accidents. Am Fam Phys. 1977;16(2):75-80.
Dempsey L C, O'Donnell J J, Hoff J T. Carbon monoxide retinopathy. Am J Ophthamol. 1976;82(5):692-693.
Denays R, Makhoul E, Dachy B, et al. Electroencephalographic mapping and 99mTc HMPAO single-photon emission computed tomography in carbon monoxide poisoning. Ann Emerg Med. 1994;24(5):947-952. [pmid: 7978570].
Dewhurst A T, Tighe S Q M, Charters P. Hyperbaric oxygen therapy (multiple letters). Br J Anaesth. 2000;85(4):656-658. [pmid: 11064630].
Dexter F, Hindman B J. Recommendations for hyperbaric oxygen therapy of cerebral air embolism based on a mathematical model of bubble absorption. Anesth Analg. 1997;84(6):1203-1207. [pmid: 9174293].
Di Sabato F, Fusco B M, Pelaia P, et al. Hyperbaric oxygen therapy in cluster headache. Pain. 1993;52(2):243-245. [pmid: 8455970].
Di Sabato F, Giacovazzo M, Cristalli G, et al. Effect of hyperbaric oxygen on the immunoreactivity to substance P in the nasal mucosa of cluster headache patients. Headache. 1996;36(4):221-223. [pmid: 8675426].
Di Sabato F, Rocco M, Martelletti P, et al. Hyperbaric oxygen in chronic cluster headaches: influence on serotonergic pathways. Undersea Hyperb Med. 1997;24(2):117-122. [pmid: 9171470].
Dinman B D. The management of acute carbon monoxide intoxication. J Occup Med. 1974;16(10):662-664. [pmid: 4443836].
Dobbins K R B, Saul R F. Transient visual loss after licorice ingestion. J Neuroophthalmol. 2000;20(1):38-41. [pmid: 10770507].
Dolan M C. Carbon monoxide poisoning. CMAJ. 1985;133(5):392-399. [pmid: 4027805]. [pmcid: 1346532].
Dollberg S, Nachum Z, Klar A, et al. Haemophilus influenzae type b purpura fulminans treated with hyperbaric oxygen. J Infect. 1992;25(2):197-200. [pmid: 1431173].
Dolmierski R, Maslowski J, Matousek M, et al. EEG changes measured by spectrum analysis under hyperbaric conditions. Aviat Space Environ Med. 1990;61(1):33-37. [pmid: 2302124].
Douze J M. Carbon monoxide poisoning is not obsolete: a form of cerebral oedema in internal medicine. Netherl J Med. 1977;20(45):157-161.
Down J. Treatment studies: efficacy vs. effectiveness. J Neurosurg. 1994;80(5):956. [pmid: 8169649].
Dressendorfer R H, Hong S K, Morlock J F, et al. Hana kai ii: a 17-day dry saturation dive at 18.6 ATA. V. Maximal oxygen uptake. Undersea Biomed Res. 1977;4(3):283-296. [pmid: 910318].
Droghetti L, Giganti M, Memmo A, et al. Air embolism: diagnosis with single-photon emission tomography and successful hyperbaric oxygen therapy. Br J Anaesth. 2002;89(5):775-8. [pmid: 12393781].
Ducasse J. Brain disease after circulatory arrest and hyperbaric oxygen therapy. Med Aeronaut Spatiale. 1980;73(19):78-79.
Ducasse J L, Celsis P, Marc-Vergnes J P. Non-comatose patients with acute carbon monoxide poisoning: hyperbaric or normobaric oxygenation?. Undersea Hyperb Med. 1995;22(1):9-15. [pmid: 7742714].
Ducasse J L, Genestal M, Hugot B, et al. Hyperbaric oxygenotherapy effects on cerebral arterio-venous differences in anoxic comas. Med Sub Hyperb. 1982;1(3):103-110.
Duim W, Cronje F J. The use of hyperbaric oxygen in acute and sub-acute stroke - a correlation of stroke type, pathophysiology and treatment response in fifteen patients. J Neurosurg. 2001;187(Suppl. 1):2001.
Dunbar E M, Fox R, Watson B, et al. Successful late treatment of venous air embolism with hyperbaric oxygen. Postgrad Med J. 1990;66(776):469-470. [pmid: 2216998].
Dunn JE and Connolly JM. Effects of hypobaric and hyperbaric oxygen on experimental brain injury. Hyperb Med 1966:447–454.
Duplechain J K, White J A. Mucormycosis of the head and neck. J La State Med Soc. 1989;141(3):9-13. [pmid: 2649623].
Durnin C. Carbon monoxide poisoning presenting with focal epileptiform seizures. Lancet. 1987;1(8545):1319. [pmid: 2890029].
Dutka A. Hyperbaric oxygen and stroke. Pressure. 1998;27(1):6.
Dutka A J. A review of the pathophysiology and potential application of experimental therapies for cerebral ischemia to the treatment of cerebral arterial gas embolism. Undersea Biomed Res. 1985;12(4):403-421. [pmid: 4082344].
Ebner R, Slamovits T L, Friedland S, et al. Visual loss following treatment of sphenoid sinus carcinoma. Surv Ophthamol. 1995;40(1):62-68.
Edwards A E, Hart G M. Hyperbaric oxygenation and the cognitive functioning of the aged. J Am Geriatr Soc. 1974;22:376-379. [pmid: 4852322].
Eicke B M, Tettenborn B. Hyperbaric Oxygen Therapy in Neurological Disorders. Headache. 2000;40(1):60-67.
Eisner D A. Can hyperbaric oxygenation improve cognitive functioning in the organically impaired elderly?: a critical review. J Geriatr Psychiatry. 1975;8(2):173-188. [pmid: 765391].
Ekbom K. Treatment of cluster headache: clinical trials, design and results. Cephalalgia 1995;15:Suppl-6.
el Toukhy E, Szal M, Levine M R, et al. Osteomyelitis of the orbit. Ophthalm Plast Recons Surg. 1997;13(1):68-71.
Elf K, Nilsson P, Enblad P. Outcome after traumatic brain injury improved by an organized secondary insult program and standardized neurointensive care. Crit Care Med. 2002;30(9):2129-34. [pmid: 12352052].
Eltorai I M, Strauss M B, Hart G B, et al. Carbon monoxide neural toxicity with report of a clinical case. Ariz Med. 1984;41(11):729-734. [pmid: 6097202].
Elwood M. Critical Appraisal of epidemiological studies and clinical trials. 2nd ed. New York: Oxford University Press; 1998.
Ely E W, Moorehead B, Haponik E F. Warehouse workers' headache: emergency evaluation and management of 30 patients with carbon monoxide poisoning. Am J Med. 1995;98(2):145-155. [pmid: 7847431].
Emerson G M, Oxer H F. Unusual causes of convulsions in a hyperbaric chamber. Undersea Hyperb Med. 1998;25(2):128-129. [pmid: 9670440].
Emerson T S, Keiler J. Pattern shift visual evoked potential screening for HBO2 in mild-to-moderate carbon monoxide poisoning. Undersea Hyperb Med. 1998;25(1):27-32. [pmid: 9566084].
Enkin M W, Jadad A R. Using anecdotal information in evidence-based health care: heresy or necessity?. Ann Oncol. 1998;9(9):963-6. [pmid: 9818068].
Epifanova N. Some clinico-biochemical aspects of hyperbaric oxygenation effect in the treatment of opium poisoning. J Eur Coll Neuropharmacol 1999.
Epifanova N, Romasenko M and and E, I. Hyperbaric oxygenation effect and the mechanisma of action in alcohol abuse and drug addiction. Presented at: 9th Congress of the Association of European Psychiatrists; Copenhagen, Denmark; 1998.
Epifanova N, Romasenko M, Koukchina A, et al. The role of hyperbaric oxygenation in treatment of alcohol abuse and drug addiction [abstract]. Presented at: 11th European College of Neuropsychopharmacology Congress; Paris, France; 1998.
Ernsting J. Hyperbaric oxygen therapy: physiological considerations. Proc R Soc Med. 1971;64(9):873. [pmid: 5114277]. [pmcid: 1812803].
Essex C. Hyperbaric oxygen and cerebral palsy: no proven benefit and potentially harmful. Dev Med Child Neurol. 2003;45(3):213-5. [pmid: 12613780].
Ewing B. Postviral syndrome (II). J R Soc Med. 1990;83(10):675-676. [pmid: 2286983].
Faglia E, Favales F, Aldeghi A, et al. Change in major amputation rate in a center dedicated to diabetic foot care during the 1980s: prognostic determinants for major amputation. J Diabetes Complications. 1998;12(2):96-102. [pmid: 9559487].
Fandino J, Stocker R, Prokop S, et al. Cerebral oxygenation and systemic trauma related factors determining neurological outcome after brain injury. J Clin Neurosci. 2000;7(3):226-33. [pmid: 10833621].
Fann W E, Wheless J C, Richman B W. Psychopharmacological treatment of disorders of senescence. No Carol Med J. 1974;35(11):672-677.
Fasano VA, De Nunno T, Urciolo R, et al. First observation on the use of oxygen under high pressure for the treatment of traumatic coma. In: Boerema I, Brummelkamp WH and Meigne NG, editors. Clinical application of hyperbaric oxygen. Amsterdam: Elsevier; 1964. p. 168–173.
Fattore L, Strauss R A. Hyperbaric oxygen in the treatment of osteoradionecrosis: a review of its use and efficacy. Oral Surg Oral Med Oral Pathol. 1987;63(3):280-286. [pmid: 3473354].
Faust D S, Brady L W, Croll M N, et al. Evaluation of the use of regional oxygenation technics to enhance the localization of radioisotopes in tumors. Radiology. 1966;87(2):285-290. [pmid: 5950332].
Faust D S, Brady L W, Croll M N, et al. Regional oxygenation techniques as a means to enhance localization of radioisotopes in brain tumors. Radiol Clin Belg. 1967;36(2):112-120.
Feinsilver O. Oxygen therapy in surgical patients. Surg Clin N Am. 1969;49(3):657-664. [pmid: 5769786].
Felber S R, Aichner F T, Sauter R, et al. Combined magnetic resonance imaging and proton magnetic resonance spectroscopy of patients with acute stroke. Stroke. 1992;23(8):1106-1110. [pmid: 1636186].
Felberg R A, Burgin W S, Grotta J C. Neuroprotection and the ischemic cascade. CNS Spectrum. 2000;5(3):52-58.
Feldmeier J J, Hampson N B. A systematic review of the literature reporting the application of hyperbaric oxygen prevention and treatment of delayed radiation injuries: an evidence based approach. Undersea Hyperb Med. 2002;29(1):4-30. [pmid: 12507182].
Ferguson B J. Mucormycosis of the nose and paranasal sinuses. Otolaryngol Clin N Am. 2000;33(2):349-365.
Ferguson B J, Mitchell T G, Moon R, et al. Adjunctive hyperbaric oxygen for treatment of rhinocerebral mucormycosis. Rev Infect Dis. 1988;10(3):551-559. [pmid: 3393782].
Ferrier D, Wallace C J, Fletcher W A, et al. Magnetic resonance features in carbon monoxide poisoning. Can Assoc Radiol J. 1994;45(6):466-468. [pmid: 7982110].
Finkelstein R, Nachum Z, Reissman P, et al. Anaerobic osteomyelitis in patients with Gaucher's disease. Clin Inf Dis. 1992;15(5):771-773.
Fischer B H, Marks, et al. Hyperbaric-oxygen treatment of multiple sclerosis: a randomized, placebo-controlled, double-blind study. New Engl J Med. 1983;308:181-186. [pmid: 6336824].
Fitch W. Anaesthesia for carotid artery surgery. Br J Anaesth. 1976;48(8):791-796. [pmid: 779816].
Fledelius H C, Jansen E C, Thorn J. Refractive change during hyperbaric oxygen therapy: a clinical trial including ultrasound oculometry. Acta Ophthal Scand. 2002;80(2):188-90.
Fontanesi J, Golden E and Heideman R. Treatment of radiation induced CNS radiation necrosis with hyperbaric oxygen therapy (HBOT). Underse Hyperb Med Suppl 1993;7 – 10(Jul):20–23.
Foreman C and Weitershausen J. Regulation of hyperbaric chambers as medical devices. In: Workman WT, editor. Hyperbaric facility safety: a practical guide. Flagstaff, AZ: Best Publishing Company; 1999. p. 135–147.
Foster J H. Hyperbaric oxygen therapy: contraindications and complications. J Oral Maxillofac Surg. 1992;50(10):1081-1086. [pmid: 1356147].
Frank L, Massaro D. Oxygen toxicity. Am J Med. 1980;69(1):117-126. [pmid: 6992575].
Frederiksen J W, Smith J, Brown P, et al. Arterial helium embolism from a ruptured intraaortic balloon. Ann Thor Surg. 1988;46(6):690-692.
Furie K. Brain Infarction. In: Gilchrist JM, editor. Prognosis in neurology. Boston: Butterworth-Heinemann; 1998. p. 83–86.
Furutani S. Hyperbaric oxygenation for the ischemic cerebral damage due to cardiac arrest during spinal and epidural anesthesia. J Intens Care Med. 1986;10:845-850.
Gabb G, Robin E D. Hyperbaric oxygen: a therapy in search of diseases. Chest. 1987;92(6):1074-1082. [pmid: 3315479].
Galizia V J. Pharmacotherapy of memory loss in the geriatric patient. Drug Intell Clin Pharm. 1984;18(10):784-791. [pmid: 6149111].
Gallerani M, La Cecilia O, Serra A, et al. Parkinsonian syndrome after acute carbon monoxide poisoning. Am J Emerg Med. 2000;18(7):833-834. [pmid: 11103740].
Gamba J L, Woodruff W W, Djang W T, et al. Craniofacial mucormycosis: assessment with CT. Radiology. 1986;160(1):207-212. [pmid: 3715034].
Gaziev D, Baronciani D, Galimberti M, et al. Mucormycosis after bone marrow transplantation: report of four cases in thalassaemia and review of the literature. Bone Marr Transplant. 1996;17(3):409-414.
Gelety JE, Neubauer RA and Mcgeehe FO. Treatment of chronic vegetative coma with hyperbaric oxygen. Presented at: Eighth Annual Conference on the Clinical Applications of Hyperbaric Oxygen; Long Beach, CA; 1983.
Giebfried J W, Lawson W, Biller H F. Complications of hyperbaric oxygen in the treatment of head and neck disease. Otolaryngol Head Neck Surg. 1986;94(4):508-512. [pmid: 3086814].
Giitter M F, Henderson L T, Afsari K K, et al. Adjunctive hyperbaric oxygen therapy in the treatment of rhinocerebral mucormycosis. Infect Med. 1996;13(2):130-136.
Gill W. Trauma. J R Coll Surg Edinb. 1977;22(1):72-80. [pmid: 839489].
Gillespie N D, Hallhead G, James P B, et al. Severe parkinsonism secondary to carbon monoxide poisoning. J R Soc Med. 1999;92(10):529-530. [pmid: 10692906]. [pmcid: 1297394].
Ginsberg M D. Carbon monoxide intoxication: clinical features, neuropathology and mechanisms of injury. J Toxicol Clin Toxicol. 1985;23(46):281-288. [pmid: 4057319].
Girkin C A, Comey C H, Lunsford L D, et al. Radiation optic neuropathy after stereotactic radiosurgery. Ophthalmology. 1997;104(10):1634-1643. [pmid: 9331204].
Gismondi A, Michalelle F, Metrangolo C, et al. Treatment of cerebral ischemia with hyperbaric oxygen therapy. Minn Med. 1980;72:1417-1420.
Glaser BG and Strauss AL. The discovery of grounded theory: strategies for qualitative research. Chicago, IL: Aldine; 1967.
Goetz C and Pappert E. Textbook of clinical neurology. Philadelphia, PA: WB Saunders; 1999.
Golden Z L, Neubauer R, Golden C J, et al. Improvement in cerebral metabolism in chronic brain injury after hyperbaric oxygen therapy. Int J Neurosci. 2002;112(2):119-31. [pmid: 12325401].
Goldenberg I, Shupak A, Shoshani O, et al. Left ventriculography complicated by cerebral air embolism. Cathet Cardiovasc Diagn. 1995;35(4):331-334. [pmid: 7497506].
Goldfarb A I, Hochstadt N J, Jacobson J H, et al. Hyperbaric oxygen treatment of organic mental syndrome in aged persons. J Gerontol. 1972;27(2):212-217. [pmid: 5060724].
Golish J A, Pena C M, Mehta A C. Massive air embolism complicating Nd-YAG laser endobronchial photoresection. Lasers Surg Med. 1992;12(3):338-342. [pmid: 1508030].
Goodnick P, Gershon S. Chemotherapy of cognitive disorders in geriatric subjects. J Clin Psych. 1984;45(5 I):196-209.
Gordon P. Molecular approaches to the drug enhancement of deteriorated functioning in the aged. Adv Gerontol Res. 1971;3:199-248. [pmid: 4938682].
Gordon W A, Haddad L, Brown M, et al. The sensitivity and specificity of self-reported symptoms in individuals with traumatic brain injury. Brain Inj. 2000;14(1):21-33. [pmid: 10670659].
Gottlieb SF, Neubauer RA, Harch PG, et al. Hyperbaric oxygen in acute and chronic deficits of stroke; imagining as a therapeutic guide. Presented at: Undersea and Hyperbaric Medical Society Gulf Coast Chapter Annual Scientific Meeting; Ft. Lauderdale, FL; 1993.
Goulon M, Levy-Alcover M A, Nouailhat F, et al. The EEG in hyperbaric oxygen therapy. Electroenceph Clin Neurophysiol. 1968;25(1):90. [pmid: 4174821].
Graupera B B. Osteoradionecrosis of the mandible. Radiolog Tech. 1977;49(2):139-142.
Gray D S. Slow-to-recover severe traumatic brain injury: a review of outcomes and rehabilitation effectiveness. Brain Inj. 2000;14:1003-1014. [pmid: 11104140].
Gray D S, Burnham R S. Preliminary outcome analysis of a long-term rehabilitation program for severe acquired brain injury. Arch Phys Med Rehab. 2000;81(11):1447-56.
Gray R C, Coppel D L. Surgery of violence III: intensive care of patients with bomb blast and gunshot injuries. BMJ. 1975;1(5956):502-504. [pmid: 1125592]. [pmcid: 1672596].
Green J, Britten N. Qualitative research and evidence based medicine. BMJ. 1998;316:1230-3. [pmid: 9583929]. [pmcid: 1112988].
Green M O, Brannen A L. Hyperbaric oxygen therapy for beta-radiation-induced scleral necrosis. Ophthalmology. 1995;102(7):1038-1041. [pmid: 9121750].
Grim P, Gottlieb L J, Boddie A, et al. Hyperbaric oxygen therapy. JAMA. 1990;263(16):2216-2220. [pmid: 2181162].
Grube B J, Marvin J A, Heimbach D M. Therapeutic hyperbaric oxygen: help or hindrance in burn patients with carbon monoxide poisoning?. J Burn Care Rehab. 1988;9(3):249-252.
Guida R A, Finn D G, Buchalter I H, et al. Radiation injury to the temporal bone. Am J Otol. 1990;11(1):6-11. [pmid: 2305861].
Guo H, Chen L and Li W. The evaluation of the effect of HBO therapy by digital symbol test. In: Marroni A, Oriani G and Wattel F, editors. Proceedings of the International Joint Meting on Hyperbaric and Underwater Medicine, XXII Annual meeting of the EUBS, XII International congress on Hyperbaric Medicine, III Consensus conference of the ECHM, Milano, Italy. Bolgna: Grafica Victoria; 1996. p. 181.
Gupta D, Chugh K, Sachdev A, et al. ICU management of severe malaria. Indian J Ped. 2001;68(11):1057-1061.
Guy J, Schatz N J. Hyperbaric oxygen in the treatment of radiation-induced optic neuropathy. Ophthalmology. 1986;93(8):1083-1088. [pmid: 3763158].
Hackett P H, Roach R C. High-altitude illness. New Engl J Med. 2001;345(2):107-114. [pmid: 11450659].
Hadeishi H, Suzuki E, Suzuki A, et al. Hyperbaric oxygenation therapy for cerebral ischemia. Undersea Biomed Res Suppl 1990;17(Aug 11–18):121.
Haffty B G, Hurley R A, Peters L G. Carcinoma of the larynx treated with hypofractionated radiation and hyperbaric oxygen: long-term tumor control and complications. Int J Radiat Oncol Biol Physic. 1999;45(1):13-20.
Hall A H, Kulig K W, Rumack B H. Suspected cyanide poisoning in smoke inhalation: complications of sodium nitrite therapy. J Toxicol Clin Exp. 1989;9(1):3-9. [pmid: 2746547].
Hall K M, Bushnik T, Lakisic-Kazazic B, et al. Assessing traumatic brain injury outcome measures for long-term follow-up of community-based individuals. Arch Phys Med Rehab. 2001;82(3):367-74.
Halliday P, Anderson D N, Davidson A I, et al. Management of cerebral air embolism secondary to a disconnected central venous catheter. Br J Surg. 1994;81(1):71. [pmid: 8313127].
Halpern N A, Pastores S M, Price J B, et al. The many causes of acute hearing loss in the ICU. J Crit Illn. 1999;14(7):398-402.
Halpern P, Greenstein A, Melamed Y, et al. Arterial air embolism after penetrating lung injury. Crit Care Med. 1983;11(5):392-393. [pmid: 6839793].
Hamilton K, Laliberte M F, Fowler B. Dissociation of the behavioral and subjective components of nitrogen narcosis and diver adaptation. Undersea Hyperb Med. 1995;22(1):41-49. [pmid: 7742709].
Hammond F M, Grattan K D, Sasser H, et al. Long-term recovery course after traumatic brain injury: a comparison of the functional independence measure and disability rating scale. J Head Trauma Rehab. 2001;16(4):318-29.
Hampson N B, Dunford R G, Kramer C C, et al. Selection criteria utilized for hyperbaric oxygen treatment of carbon monoxide poisoning. J Emerg Med. 1995;13(2):227-231. [pmid: 7775795].
Hampson N B, Norkool D M. Carbon monoxide poisoning in children riding in the back of pickup trucks. JAMA. 1992;267(4):538-540. [pmid: 1370334].
Hampson N B, Simonson S G, Kramer C C, et al. Central nervous system oxygen toxicity during hyperbaric treatment of patients with carbon monoxide poisoning. Undersea Hyperb Med. 1996;23(4):215-219. [pmid: 8989851].
Harch PG. The dosage of hyperbaric oxygen in chronic brain injury. Proceedings of the 2nd International Symposium on Hyperbaric Oxygenation in Cerebral Palsy and the Brain-injured Child 2002:31.
Harch PG, Deckoff-Jones J and Neubauer RA. Low pressure hyperbaric oxygen therapy for pediatric brain injury, a minimal risk medical treatment. Pediatrics 2001;Eletter(http://pediatrics.aappublications.org/cgi/eletters/106/6/e80#145).
Harch P G, Meter V, Gottlieb S. HMPAO SPECT brain imaging and low pressure HBOT in the diagnosis and treatment of chronic traumatic, ischemic, hypoxic and anoxic encephalopathies. Undersea Hyperb Med Suppl. 1994;21:30.
Harch PG and Neubauer RA. Hyperbaric oxygen therapy in global cerebral ischemia/anoxia and coma, Chapter 18. In: Jain KK, editor. Textbook of hyperbaric medicine. 3rd rev. ed. Seattle, WA: Hogrefe and Huber Publishers; 1999.
Harch PG, Neubauer RA, Uszler JM, et al. Functional Imaging. In: Jain KK, editor. Textbook of hyperbaric medicine. 3rd rev. ed. Seattle, WA: Hogrefe & Huber; 1999.
Hardy K R. Diving-related emergencies. Emerg Med Clin N Am. 1997;15(1):223-240.
Hardy P, JP C, J G, et al. Neuropsychological effects of hyperbaric oxygen therapy in cerebral palsy. Dev Med Child Neurol 2002;44:436–446.
Harries P G, Fagan J J. Minerva. BMJ. 1999;318(7187):884. [pmid: 9933224]. [pmcid: 1115308].
Harris R P, Helfand M, Woolf S H, et al. Methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
Hart G B, Mainous E G. The treatment of radiation necrosis with hyperbaric oxygen (OHP). Cancer. 1976;37(6):2580-2585. [pmid: 949677].
Hart GB and SD L. The treatment of chronic cerebral ischemia with hyperbaric oxygen: Naval Hospital, Long Beach, CA. In: 5th International Hyperbaric Congress Proceedings. Burnaby, BC Canada: Simon Fraser University; 1973. p. 409–413.
Hart GB and Strauss MB. Central nervous system oxygen toxicity in a clinical setting. In: Bove AA, editor. Proceedings of the Ninth International Symposium on Underwater and Hyperbaric Physiology. Bethesda, MD: Undersea and Hyperbaric Medical Society; 1987. p. 695–699.
Hart G B, Strauss M B, Lennon P A, et al. Treatment of smoke inhalation by hyperbaric oxygen. J Emerg Med. 1985;3(3):211-215. [pmid: 4093574].
Hart G B, Thompson R E. The treatment of cerebral ischemia with hyperbaric oxygen (OHP). Stroke. 1971;2(3):247-250. [pmid: 5165167].
Harvey W R, Hutton P. Carbon monoxide: Chemistry, role, toxicity and treatment. Curr Anaesth Crit Care. 1999;10(3):158-163.
Harvey W R, Lee C J, Koch S M, et al. Delayed presentation of cerebral arterial gas embolism following proven intraoperative venous air embolism. J Neurosurg Anesthesiol. 1996;8(1):26-29. [pmid: 8719189].
Hattori K, Yabe M, Matsumoto M, et al. Successful hyperbaric oxygen treatment of life-threatening hemorrhagic cystitis after allogeneic bone marrow transplantation. Bone Marr Transplant. 2001;27(12):1315-1317.
Hawkins M, Harrison J, Charters P. Severe carbon monoxide poisoning: outcome after hyperbaric oxygen therapy. Br J Anaesth. 2000;84(5):584-586. [pmid: 10844833].
Hayakawa T. Hyperbaric oxygen treatment in neurology and neurosurgery. TIT J Life Sci. 1974;4(1):1-25. [pmid: 4822688].
Hayakawa T, Kanai N, Kuroda R, et al. Response of cerebrospinal fluid pressure to hyperbaric oxygenation. J Neurol Neurosurg Psychiatry. 1971;34(5):580-586. [pmid: 5122387].
Hayashi N. The brain hypothermia therapy for prevention of vegetation after severe brain injury. Nippon Geka Gakkai Zasshi. 1999;100(7):443-8. [pmid: 10766580].
He K M, Guan L X, Zhang J. Effect of hyperbaric oxygen on neonatal hypoxic-ischmia encephalopathy (32 cases). Chin J Contemp Ped. 2000;2(5):345-346.
Heckmann J G, Lang C J, Kindler K, et al. Neurologic manifestations of cerebral air embolism as a complication of central venous catheterization. Crit Care Med. 2000;28(5):1621-1625. [pmid: 10834723].
Heimbach R D. Hyperbaric medicine--demonstration cases. Transact Assoc Life Ins Med DIrect Am. 1985;67:126-134.
Heng M C Y. Topical hyperbaric therapy for problem skin wounds. J Dermatol Surg Oncol. 1993;19(8):784-793. [pmid: 8349920].
Henk J M. Progress of clinical trials of hyperbaric oxygen in head and neck cancer [abstract]. Br J Radiol. 1976;49(588):1060-1.
Henk J M. Hyperbaric oxygen: controlled trials in head and neck cancer [abstract]. Br J Radiol. 1978;51(601):67.
Henk J M. Update of clinical trials of fractionation and hyperbaric oxygen in radiotherapy of head and neck cancer [abstract]. Br J Radiol. 1984;57(675):278.
Henk J M. Late results of a trial of hyperbaric oxygen and radiotherapy in head and neck cancer: a rationale for hypoxic cell sensitizers?. Int J Radiat Oncol Biol Physics. 1986;12(8):1339-1441.
Heppner F. New technologies to combat malignant tumours of the brain. Anticancer Res. 1982;2(12):101-109. [pmid: 6287907].
Herman L Y. Carbon monoxide poisoning presenting as an isolated seizure. J Emerg Med. 1998;16(3):429-432. [pmid: 9610972].
Herman L Y. To the editor. Ped Neurol. 2001;24(3):245.
Heuser G, Uszler J M. Hyperbaric oxygenation for cerebral palsy. [letter; comment]. [erratum appears in Lancet 2001 Nov 24;358(9295):1820]. Lancet. 2001;357(9273):2053-2054. [pmid: 11441858].
Heyman A, Saltzman HA and Whalen RE. The use of hyperbaric oxygenation in the treatment of cerebral ischemia and infarction. Circulation 1966;33(5:Suppl):Suppl-7.
Hill R K Jr. Clearing an oxygen confusion [letter; comment]. Diabetes Care. 1989;12(9):661. [pmid: 2791829].
Hill S, Main A. Therapeutic progress - review XXIII: are we making progress in the treatment of acute stroke?. J Clin Hosp Pharm. 1986;11(6):427-441. [pmid: 3546385].
Hinkle D A, Raizen D M, McGarvey M L, et al. Cerebral air embolism complicating cardiac ablation procedures. Neurology. 2001;56(6):792-794. [pmid: 11274320].
Hoidal C R, Hall A H, Robinson M D. Hydrogen sulfide poisoning from toxic inhalations of roofing asphalt fumes. Ann Emerg Med. 1986;15(7):826-830. [pmid: 3729106].
Holbach K and H W. Extra-intracranial anastomosis operation associated with hyperbaric oxygenation in the treatment of completed stroke. In: Peerless SJ and McCormick CW, editors. Microsurgery for cerebral ischemia. New York, Heidelberg, Berlin: Springer; 1980. p. 286–291.
Holbach K, Wassman H, Kolberg T. Improved reversibility of traumatic mid-brain syndrome following the use of hyperbaric oxygen. Neurol Neurosurg Exerpt Med. 1975;1975:494.
Holbach K and Wassmann H. Neurological and EEG analytical findings in the treatment of cerebral infarction with repetitive hyperbaric oxygenation. In: Smith G, editor. Proceedings of the Sixth International Congress on Hyperbaric Medicine. Aberdeen, Scotland: Aberdeen University Press; 1977. p. 205–210.
Holbach K H, Caroli A, Wassmann H. Cerebral energy metabolism in patients with brain lesions of normo- and hyperbaric oxygen pressures. J Neurol. 1977;217(1):17-30. [pmid: 75249].
Holbach K H, Schroder F K, Datene G, et al. Hyperbaric oxygenation: a treatment in neurosurgery. J Neurol Neurosurg Psychiatry. 1970;33(5):717. [pmid: 5478964].
Holbach K H, Schroder F K, Koster S. Alterations of cerebral metabolism in cases with acute brain injuries during spontaneous respiration of air, oxygen and hyperbaric oxygen. Eur Neurol. 1972;8(1):158-160. [pmid: 5052137].
Holbach K H, Wassmann H. Advantage of using hyperbaric oxygenation (HO) in combination with extra-intracranial arterial bypass (EIAB) in the treatment of completed stroke. Acta Neurochir Suppl. 1979;28(1):309.
Holbach KH, Wassmann H and Bonatelli AP. A method to identify and treat reversible ischemic alterations of brain tissue. In: Schmiedek P, editor. Microsurgery for stroke. New York: Springer-Verlag; 1977.
Holbach K H, Wassmann H, Hoheluchter K L, et al. Differentiation between reversible and irreversible post-stroke changes in brain tissue: its relevance for cerebrovascular surgery. Surg Neurol. 1977;7(6):325-331. [pmid: 882903].
Holbach K H, Wassmann H, Linke D. The use of hyperbaric oxygenation in the treatment of spinal cord lesions. Eur Neurol. 1977;16(16):213-221. [pmid: 615712].
Holbach K H, Wassmann H, Sanchez F. EEG analysis for evaluating chronic cerebral ischemia treated by hyperbaric oxygenation and microneurosurgery. J Neurol. 1978;219(4):227-240. [pmid: 84056].
Holbach K H, Wassmann H W, Hoheluchter K L. Reversibility of the chronic post-stroke state. Stroke. 1976;7(3):296-300. [pmid: 1273908].
Hollin S A, Espinosa O E, Sukoff M H, et al. The effect of hyperbaric oxygenation on cerebrospinal fluid oxygen. J Neurosurg. 1968;29(3):229-235. [pmid: 5684405].
Holt J A. The principles of hyperbaric and anoxic radiotherapy. Br J Radiol. 1975;48(574):819-826. [pmid: 811296].
Hsu L H, Wang J H. Treatment of carbon monoxide poisoning with hyperbaric oxygen. Chin Med J. 1996;58(6):407-413.
Huang K L, Wu J N, Lin H C, et al. Prolonged exposure to hyperbaric oxygen induces neuronal damage in primary rat cortical cultures. Neurosci Letters. 2000;293(3):159-62.
Huber S, Rigler B, Machler H E, et al. Successful treatment of massive arterial air embolism during open heart surgery. Ann Thor Surg. 2000;69(3):931-933.
Hultcrantz E. Clinical treatment of vascular inner ear diseases. Am J Otolaryng Head Neck Med Surg. 1988;9(6):317-322.
Imai Y. Hyperbaric oxygen (OHP) therapy in memory disturbances. In: Trapp WG, Bannester EW, Davison AJ, et al., editors. Fifth International Hyperbaric Conference. Burnaby, Canada: Simon Fraser University Press; 1974. p. 402–408.
Ingvar H D, Lassen N A. Treatment of focal cerebral ischemia with hyperbaric oxygen. Acta Neurol Scand. 1965;41:92-95. [pmid: 14274097].
Interagency Gray Literature Working Group. Gray Information Functional Plan; 1995.
Isakov YV, Ananyev GV, A, K.B., et al. Use of hyperbaric oxygenation in some complications of craniocerebral trauma in the acute period. Zh Vopr Neirokhir 1981;4:15–18.
Isakov YV, Pravdenkova SV, Ananiev GV, et al. Hyperbaric oxygenation in acute period of cerebral stroke and craniocerebral injury. In: Abstracts of the Seventh International Congress on HBO Medicine. Moscow; 1981. p. 295–296.
Ishihara H, Matsui H, Kitagawa H, et al. Prediction of the surgical outcome for the treatment of cervical myelopathy by using hyperbaric oxygen therapy. Spinal Cord. 1997;35(11):763-767. [pmid: 9392048].
Iwa T, Fell E H, Weinberg M J. Effects of hyperbaric oxygen therapy on cerebral air embolism. Chest. 1960;50:333.
Jacobs E A, Alvis H J, Small S M. Hyperoxygenation: a central nervous system activator?. J Geriatr Psychiatry. 1972;5(2):107-136. [pmid: 4584068].
Jacobs E A, Small S M, Winter P M, et al. Hyperbaric oxygen effect on cognition and behavior in the aged. Curr Psych Ther. 1971;11:100-106.
Jacobs E A, Winter P M, Alvis H J, et al. Hyperoxygenation effect on cognitive functioning in the aged. New Engl J Med. 1969;281:753-757. [pmid: 4897016].
Jaeger K, Juttner B, Sommer C, et al. [Effects of repetitive exposure to hyperbaric oxygen (HBO) on leukocyte function]. Anasthesiol Intensivemed Notfallmed Schmerzther. 2002;37(1):24-8.
Jagger J A, Bobovsky J. Nonpharmacologic therapeutic modalities. CCQ. 1983;5(4):31-43.
Jain K, editor. Textbook of hyperbaric medicine. 3rd rev. ed. Kirkland, WA: Hogrefe & Huber Publishers, Inc.; 1999.
Jain K K. Effect of hyperbaric oxygenation on spasticity in stroke patients. J Hyperb Med. 1989;4:55-61.
Jain K K. Neuroprotection in cerebrovascular disease. Expert Opin Invest Drug. 2000;9(4):695-711.
Jain K K, Fischer B. New aspects of the use of hyperbaric oxygenation for rehabilitation of stroke patients. Geriatr Rehab. 1988;1:45.
Jain KK, Fischer B, Dickreiter B, et al. Hyperbaric oxygen therapy in the rehabilitation of stroke patients. In: Second Swiss Symposium on Hyperbaric Medicine, 2nd European Conference on Hyperbaric Medicine. Basel, Switzerland: Foundation for Hyperbaric Medicine; 1990. p. 341–345.
Jain KK, Klausenbach F and Fischer B. Effect of hyperbaric oxygen (HBO) on spasticity in stroke patients. Undersea Biomed Res Suppl 1989;16(June 6–11):25.
James L S. Onset of breathing and resuscitation. Pediatr Clin N Am. 1966;13(3):621-634.
James P. Hyperbaric oxygenation for multiple sclerosis. Spums J. 1984;14:16-18.
James P B. Evidence for subacute fat embolism as the cause of multiple sclerosis. Lancet. 1982;1(8268):380-386. [pmid: 6123655].
James P B. Hyperbaric oxygenation, carbon monoxide, and cerebral edema. BMJ Clin Res. 1988;296(6620):500-501.
James P B. The treatment of decompression sickness. Schweiz Z Sportmed. 1989;37(2):109-114. [pmid: 2678462].
James P B. Dysbarism: The medical problems from high and low atmospheric pressure. J R Coll Phys Lond. 1993;27(4):367-374.
James PB. New horizons in hyperbaric oxygenation. Adv Exper Med Biol 1997;428(pp 129–133):133.
James P B. Hyperbaric oxygenation for cerebral palsy. Lancet. 2001;357(9273):2052-2053. [pmid: 11747914].
Jarvik M E, Gritz E R, Schneider N G. Drugs and memory disorders in human aging. Behav Biol. 1972;7(5):643-668. [pmid: 4403945].
Jarvis R M, Neufeld M V, Westfall C T. Brown recluse spider bite to the eyelid. Ophthalmology. 2000;107(8):1492-1496. [pmid: 10919896].
Jennelle R, Gladson C, Palmer C, et al. Paradoxical labeling of radiosurgically treated quiescent tumors with Ki67, a marker of cellular proliferation. Stereotact Func Neurosurg. 1999;72(SUPPL.1):45-52.
Jennett B, Bond M R. Assessment of outcome after severe brain damage. Lancet. 1975;1:480-4. [pmid: 46957].
Jennett W B. Experimental studies on the cerebral circulation: clinical aspects. Proc R Soc Med. 1968;61(6):606-610. [pmid: 5662215]. [pmcid: 1902571].
Jia S J, Zhang J K, Qu Z K. Experience on the clinical use of HBO treatment in cerebral thrombus: a report of 104 cases. J Hyperb Med. 1986;1(3):187.
Jiang J, Yu M, Zhu C. Effect of long-term mild hypothermia therapy in patients with severe traumatic brain injury: 1-year follow-up review of 87 cases. J Neurosurg. 2000;93(4):546-9. [pmid: 11014530].
Jiang J Y, Gao G Y, Li W P, et al. Early indicators of prognosis in 846 cases of severe traumatic brain injury. J Neurotrauma. 2002;19(7):869-74. [pmid: 12184856].
Jianhua N, Xijiu L, Cuixia C, et al. Curative effect analysis of combined treatment of child cerebritis sequel with high pressure oxygen. In: Proceedings of the Eleventh International Congress on Hyperbaric Medicine. Flagstaff, AZ: Best Publishing Company; 1995. p. 214–217.
Jianhui C and Shaohua L. Effect of hyperbaric oxygen in the treatment of patients with brain stem injury. In: Book for 13th International Proceedings. 2000. p. 35–37.
Jinnai D, Mogami H, Ioko M, et al. Effect of hyperbaric oxygenation on cerebral edema. Neurol Med Clin. 1967;9:260-261.
Johnson T E. Fungal disease of the orbit. Ophthalmol Clin N Am. 2000;13(4):643-656.
Johnston MV, Hall K, Carnevale G, et al. Functional assessment and outcome evaluation in traumatic brain injury rehabilitation. In: Horn LJ and Zasler ND, editors. Medical rehabilitation of traumatic brain injury. Philadelphia: Mosby; 1996. p. 197–226.
Jorgensen H S, Nakayama H, Raaschou H O, et al. Outcome and time course of recovery in stroke. Part II: Time course of recovery. The Copenhagen Stroke Study. Arch Phys Med Rehab. 1995;76(5):406-412.
Juan M. Management of hyperbaric oxygen (HBO) for anoxic encephalopathy after open heart surgery done under extracorporeal circulation: a report of four cases. Undersea Biomed Res Suppl 1992;19(Jun 23 – 27):100.
Juurlink DN, Stanbrook MB and McGuigan MA. Hyperbaric oxygen for carbon monoxide poisoning. Cochrane Lib 2001(1).
Kaasik A E, Dmitriev K K, Tomberg T A. Hyperbaric oxygenation in the treatment of patients with ischemic stroke. Zh Nevropatol Psikhiatr Im S S Korsakova. 1988;88(9):38-43. [pmid: 3232453].
Kanai N, Hayakawa T, Mogami H. Blood flow changes in carotid and vertebral arteries by hyperbaric oxygenation. Neurology. 1973;23(2):159-163. [pmid: 4734510].
Kanno T, Nagata J, Nonomura K, et al. New approaches in the treatment of hypertensive intracerebral hemorrhage. Stroke 1993;24(12:Suppl):Suppl-100.
Kanno T, Nonomura K. Hyperbaric oxygen therapy to determine the surgical indication of moderate hypertensive intracerebral hemorrhage. Minim Invasive Neurosurg. 1996;39(2):56-59. [pmid: 8811658].
Kapp J. Hyperbaric oxygen after circulatory arrest: Modivication of postischemic encephalopathy. Neurosurg. 1982;11(4):496-499.
Kapp J P. Hyperbaric oxygen as an adjunct to acute revascularization of the brain. Surg Neurol. 1979;12(6):457-461. [pmid: 534562].
Kapp J P. Neurological response to hyperbaric oxygen--a criterion for cerebral revascularization. Surg Neurol. 1981;15(1):43-46. [pmid: 6277026].
Kapp JP. Cerebral ischemia and revascularization. Presented at: Seventh Annual Conference on Clinical Applications of HBO; 1982.
Kapp J P. The role of hyperbaric oxygen in the management of cerebral infarction. Geriatr Med Today. 1984;3(4):78-84.
Kapp J P, Routh A, Cotton D. Hyperbaric oxygen as a radiation sensitizer in the treatment of brain tumors. Surg Neurol. 1982;17(3):233-235. [pmid: 7079944].
Kapp JP, RR S, MR M, et al. The effect of hyperbaric oxygenation on post-ischemic encephalopathy. Presented at: Annual Meeting, Gulf Coast Chapter, Undersea Medical Society; New Orleans, LA; 1982.
Kaps M, Hansen J, Weiher M, et al. Clinically silent microemboli in patients with artificial prosthetic aortic valves are predominantly gaseous and not solid. Stroke. 1997;28(2):322-325. [pmid: 9040683].
Karz S C, Thompson R E, Depenbusch F L, et al. Hyperbaric oxygen treatment of gangrene in pneumococcemia. JAMA. 1971;217(7):962-963. [pmid: 4397951].
Katsurada K, Minami T and Onji Y. Effect of hyperbaric oxygenation on DSF Po2 in patients with head injury, Department of Traumatology, Osaka University Hospital, Osaka, Japan. In: 5th International Hyperbaric Congress Proceedings. Burnaby, BC Canada: Simon Fraser University; 1974. p. 362–369.
Katz D I. Neuropathology and neurobehavioral recovery from closed head injury. J Head Trauma Rehab. 1992;27:602-606.
Katz DI. Brain injury. In: Gilchrist JM, editor. Prognosis in neurology. Boston: Butterworth-Heinemann; 1998. p. 31–38.
Kawamura S, H. O, Yasui N, et al. Effects of hyperbaric oxygenation in patients with subarachnoid hemorrhage evaluated with somatosensory evoked potentials. In: Proceedings of the Eighth International Congress on Hperbaric Medicine, August 20 – 22, 1984. Flagstaff, AZ: Best Publishing Company; 1987. p. 159–163.
Kawamura S, H. O, Yasui N, et al. Effects of hyperbaric oxygenation in patients with subarachnoid hemorrhage. J Hyperb Med 1988;3(4):243–255.
Kazantseva N. Mechanisms of curative effect of minimized hyperbaric treatment in cerebral ischemia. In: Proceedings of the 2nd International Symposium on Hyperbaric Oxygenation for Cerebral Palsy and the Brain-Injured Child. 2002. p. 199–212.
Kazantseva N. A new method of treating brain-injured children in a barochamber. In: Proceedings of the 2nd International Symposium on Hyperbaric Oxygenation in Cerebral Palsy and the Brain-Injured Child. 2002. p. 197–198.
Kearney K R, Smith M D, Xie G Y, et al. Massive air embolus to the left ventricle: diagnosis and monitoring by serial echocardiography. J Am Soc Echocard. 1997;10(9):982-987.
Keim L, Aita J, Hankins J, et al. Quantitative spect. scanning in the assessment of patients with ischemic/traumatic brain injury treated with HBO. Chest. 1997;112(3S):91.
Kellogg R H. Oxygen and carbon dioxide in the regulation of respiration. Fed Proc. 1977;36(5):1658-1663. [pmid: 14849].
Kemper J, Kuijper E J, Mirck P G, et al. Recovery from rhinocerebral mucormycosis in a ketoacidotic diabetic patient: a case report. J Laryngol Otol. 1993;107(3):233-235. [pmid: 8509703].
Kent H. Customers lining up for high-cost hyperbaric therapy. CMAJ. 1999;160(7):1043. [pmid: 10906905]. [pmcid: 1230207].
Keogh A J. Clostridial brain abscess and hyperbaric oxygen. Postgrad Med J. 1973;49(567):64-66. [pmid: 4354408].
Kerley T R, Mader J T, Hulet W H, et al. The effect of adjunctive hyperbaric oxygen on bone regeneration in mandibular osteomyelitis: report of case. J Oral Surg. 1981;39(8):619-623. [pmid: 6940972].
Keyser-Marcus L A, Bricout J C, Wehman P, et al. Acute predictors of return to employment after traumatic brain injury: a longitudinal follow-up. Arch Phys Med Rehab. 2002;83(5):635-41.
Khalil S N, Madan V, Rigor B M, et al. Systemic air embolism following induction of artificial pneumothorax under anaesthesia, with successful management. Br J Anaesth. 1979;51(5):461-464. [pmid: 375955].
Kharbanda K, Dinda A K, Sarkar C, et al. A correlative study of in vivo and in vitro labeling index using bromodeoxyuridine in human brain tumors. J Neurooncol. 1995;23(3):185-190. [pmid: 7673980].
Khatri S. Cerebral artery gas embolism (CAGE) following fine needle aspiration biopsy of the lung. Austral NZ J med. 1997;27(3):338.
Kidd P M. Multiple sclerosis, an autoimmune inflammatory disease: prospects for its integrative management. Alt Med Rev. 2001;6(6):540-566.
Kim C H, Choi H, Chun Y S, et al. Hyperbaric oxygenation pretreatment induces catalase and reduces infarct size in ischemic rat myocardium. Pflugers Archiv. 2001;442(4):519-525. [pmid: 11510883].
Kim R Y, Langford K H, Roth R E. Adjuvant therapy in the treatment of malignant glioma. J Med Assoc State Ala. 1977;47(4):39-41. [pmid: 200689].
Kindwall E P. Massive surgical air embolism treated with brief recompression to six atmospheres followed by hyperbaric oxygen. Aerosp Med. 1973;44(6):663-666. [pmid: 4513563].
Kindwall EP. Acute cerebral edema: evidence for the efficacy of hyperbaric oxygen and comparison to other modalities. A critical review. In: Camporesi EM and Barker AC, editors. Hyperbaric oxygen: a critical review. Bethesda, MD: Undersea & Hyperbaric Medical Society; 1991. p. 141–147.
Kindwall E P. Compressed air tunneling and caisson work decompression procedures: development, problems, and solutions. Undersea Hyperb Med. 1997;24(4):337-345. [pmid: 9444066].
Kindwall EP. The multiplace chamber. In: Kindwall EP and Whelan HT, editors. Hyperbaric Medicine Practice. 2nd. Flagstaff, AZ: Best Publishing; 1999.
Kindwall EP and Whelan HT, ed. Hyperbaric medicine practice. Flagstaff, AZ: Best Publishing Company; 1999.
Kinsella J, Findlay J. Carbon monoxide poisoning. Care Crit Ill. 1991;7(5):182-184.
Kizer K W. Dysbaric cerebral air embolism in Hawaii. Ann Emerg Med. 1987;16(5):535-541. [pmid: 3631666].
Klawans H L, Genovese N. Pharmacology of dementia. Neurol Clin. 1986;4(2):459-467. [pmid: 2872586].
Kleen M, Messmer K. Toxicity of high PaO2. Minerva Anestesiol. 1999;65(6):393-396. [pmid: 10394808].
Knisely M H, Reneau D D Jr, Bruley D F. The development and use of equations for predicting the limits of the rates of oxygen supply to the cells of living tissues and organs. A contribution to the biophysics of health and disease. Angiology. 1969;20(11 Suppl):56. [pmid: 4906592].
Kodama K, Koseki K, Hanazawa H, et al. A case of “interval” form of acute carbon monoxide poisoning: Brain MRI and therapeutic effect of hyperbaric oxygenation. Clin Neurol. 1990;30(4):420-426.
Kohshi K, Imada H, Nomoto S, et al. Successful treatment of radiation-induced brain necrosis by hyperbaric oxygen therapy. J Neurolog Sci. 2003;209(12):115-7.
Kohshi K, Kinoshita Y, Imada H, et al. Effects of radiotherapy after hyperbaric oxygenation on malignant gliomas. Br J Cancer. 1999;80(12):236-241. [pmid: 10390002].
Kohshi K, Yokota A, Konda N, et al. Intracranial pressure responses during hyperbaric oxygen therapy. Neurol Med Chir. 1991;31(9):575-581.
Kohshi K, Yokota A, Konda N, et al. Hyperbaric oxygen therapy adjunctive to mild hypertensive hypervolemia for symptomatic vasospasm. Neurol Med Chir. 1993;33(2):92-99.
Kol S, Ammar R, Weisz G, et al. Hyperbaric oxygenation for arterial air embolism during cardiopulmonary bypass. Ann Thor Surg. 1993;55(2):401-403.
Komisar A, Silver C, Kalnicki S. Osteoradionecrosis of the maxilla and skull base. Laryngoscope. 1985;95(1):24-28. [pmid: 3917520].
Kondratenko VI, Pilinoga VG and Gyulyameryants VA. Hyperbaric oxygenation in neurosurgery [abstract]. In: Abstracts Seventh International Congress on Hyperbaric Medicine. Moscow; 1981. p. 300.
Kong Y, Lunzer S, Heyman A, et al. Protective effects of acetazolamide and hyperbaric oxygenation on experimentally induced syncope. Stroke. 1970;1(2):69-76. [pmid: 5522907].
Kopelman M D, Lishman W A. Pharmacological treatments of dementia (non-cholinergic). Br Med Bull. 1986;42(1):101-105. [pmid: 2420407].
Koren G, Sharav T, Pastuszak A, et al. A multicenter, prospective study of fetal outcome following accidental carbon monoxide poisoning in pregnancy. Reproduc Toxicol. 1991;5(5):397-403.
Koskinen P J, Nuutinen H M, Laaksonen H, et al. Importance of storing emergency serum samples for uncovering murder with insulin. Forensic Sci Int. 1999;105(1):61-66. [pmid: 10605076].
Krasney J A. A neurogenic basis for acute altitude illness. Med Sci Sports Exerc. 1994;26(2):195-208. [pmid: 8164537].
Kronish J W, McLeish W M. Eyelid necrosis and periorbital necrotizing fasciitis. Report of a case and review of the literature. Ophthalmology. 1991;98(1):92-98. [pmid: 2023741].
Krushinskii L V, Efuni S N, Demurov E A. Protective action of hyperbaric oxygenation for acute circulatory disorders in different-aged rats. Dokl Biol Sci. 1981;255(16):601-603.
Kulig K. Cyanide antidotes and fire toxicology. New Engl J Med. 1991;325(25):1801-1802. [pmid: 1944486].
Kunisaki T A, Augenstein W L. Drug- and toxin-induced seizures. Emerg Med Clin N Am. 1994;12(4):1027-1056.
Kushner D S. Mild traumatic brain injury. Arch Int Med. 1998;158:1617-24. [pmid: 9701095].
Langham M R Jr, Krummel T M, Bartlett R H, et al. Mortality with extracorporeal membrane oxygenation following repair of congenital diaphragmatic hernia in 93 infants. J Pediatr Surg. 1987;22(12):1150-1154. [pmid: 3440902].
Lannoo E, Colardyn E, Jannes C, et al. Course of neuropsychological recovery from moderate-to-severe head injury: a 2-year follow-up. Brain Inj. 2001;15:1-13. [pmid: 11201310].
Lantsev EA. Hyperbaric oxygenation in complex treatment of newborn infants with asphyxia delivered by Caesarian section. In: Abstracts Seventh International Congress on HBO Medicine. Moscow; 2002. p. 368–369.
Lapawsky M. Extension of left fronto-parietal cerebral infarct during exposure to complimentary hyperbaric oxygen at 1.6+ ATA. Presented at: The Twenty-Seventh Pacific Coast Chapter Meeting of the UHMS; San Francisco, CA; 2000.
Laszlo J, Obenour W Jr, Saltzman H A. Effects of hyperbaric oxygenation on sickle syndromes. South Med J. 1969;62(4):453-456. [pmid: 4975931].
Layon A J. Hyperbaric oxygen treatment for cerebral air embolism - where are the data?. Mayo Clin Proc. 1991;66(6):641-646. [pmid: 2046404].
Layon A J, Mahla M E, Modell J H, et al. Closed head injury and the treatment of sequelae after a motor vehicle accident. J Clin Anesth. 1994;6(5):437-449. [pmid: 7986520].
Leach R M, Rees P J, Wilmshurst P. ABC of oxygen: Hyperbaric oxygen therapy. BMJ. 1998;317(7166):1140-1143. [pmid: 9784458]. [pmcid: 1114115].
Lebedev V and et. [Effect of hyperbarixc oxygenation on the clinical course and complications of the acute period of ischemic stroke]. Shurnal Vopr Neirokhirnry 1983;3:37–42.
Leber KA, Eder HG, Kovac H, et al. Treatment of cerebral radionecrosis by hyperbaric oxygen therapy. Stereotact Func Neurosurg 1998;70:Suppl-36.
Ledingham I, Davidson J. Hazards in hyperbaric medicine. BMJ. 1969;3:324-327. [pmid: 5800341]. [pmcid: 1989046].
Ledingham I M. Hyperbari oxygen in shock. Int Anesthesiol Clin. 1969;7(4):819-839. [pmid: 4922177].
Ledingham I M, McBride T I, Jennett W B, et al. Fatal brain damage associated with cardiomyopathy of pregnancy, with notes on Caesarean section in a hyperbaric chamber. BMJ. 1968;4(626):285-287. [pmid: 5693910]. [pmcid: 1912284].
Lee C T. Cerebral arterial gas embolism in air force ground maintenance crew - a report of two cases. Aviat Space Environ Med. 1999;70(7):698-700. [pmid: 10417001].
Lee H C, Niu K C, Chen S H, et al. Hyperbaric oxygen therapy in clinical application: a report of a 12-year experience. Chin Med J. 1989;43(5):307-316.
Lee H F, Mak S C, Chi C S, et al. Hyperbaric oxygen for carbon monoxide poisoning-induced delayed neuropsychiatric sequelae. Chin Med J. 2001;64(5):310-314.
Lee M S, Marsden C D. Neurological sequelae following carbon monoxide poisoning clinical course and outcome according to the clinical types and brain computed tomography scan findings. Mov Disord. 1994;9(5):550-558. [pmid: 7990850].
Leitch D R, Green R D. Pulmonary barotrauma in divers and the treatment of cerebral arterial gas embolism. Aviat Space Environ Med. 1986;57(10:Pt 1):t-8. [pmid: 3800823].
Leitch D R, Greenbaum L J Jr, Hallenbeck J M. Cerebral arterial air embolism: III. Cerebral blood flow after decompression from various pressure treatments. Undersea Biomed Res. 1984;11(3):249-263. [pmid: 6506338].
Leitch D R, Greenbaum Jr L J, Hallenbeck J M. Cerebral arterial air embolism: IV. Failure to recover with treatment, and secondary deterioration. Undersea Biomed Res. 1984;11(3):265-274. [pmid: 6506338].
Leitch D R, Greenbaum L J Jr, Hallenbeck J M. Cerebral arterial air embolism: I. Is there benefit in beginning HBO treatment at 6 bar?. Undersea Biomed Res. 1984;11(3):221-235. [pmid: 6506338].
Leitch D R, Greenbaum L J Jr, Hallenbeck J M. Cerebral arterial air embolism: II. Effect of pressure and time on cortical evoked potential recovery. Undersea Biomed Res. 1984;11(3):237-248. [pmid: 6506338].
Levin HS. Preface. In: H.S. L, Benton AL, Muizelaar JP, et al., editors. Catastrophic brain injury. New York: Oxford University Press; 1996. p. v–vi.
Levin HS, Gary HE, Jr, Eisenberg HM, et al. Neurobehavioral outcome one year after severe head injury: experience of the Traumatic Coma Data Bank. J Neurosurg 1990(73):699–709.
Levin H S, Goldstein F C, Norcross K, et al. Neurobehavioral and magnetic resonance imaging findings in two cases of decompression sickness. Aviat Space Environ Med. 1989;60(12):1204-1210. [pmid: 2604678].
Levin H S, Peters B H. Hyperbaric oxygenation in the treatment of postencephalitic amnesic syndrome. Aviat Space Environ Med. 1977;48(7):668-671. [pmid: 883939].
Levine ER and Heyworth E. Hyperbaric treatment of coma of hypoxic origin [abstract]. In: Abstracts Seventh International Congress on HBO Medicine. Moscow; 1981. p. 337.
Levy S L, Burnham W M, Bishai A, et al. The anticonvulsant effects of vitamin E: a further evaluation. Can J Neurol Sci. 1992;19(2):201-203. [pmid: 1623446].
Lewin W, Marshall T F, Roberts A H. Long-term outcome after severe head injury. BMJ. 1979;2(6204):1533-1538. [pmid: 119567]. [pmcid: 1597452].
Lhermitte F, Roullet E, Lyon-Caen O. [Hyperbaric oxygen treatment of chronic multiple sclerosis: results of a placebo-controled double-blind study in 49 patients]. Rev Neurol (Paris). 1986;142:201-206. [pmid: 2879344].
Li H K, Dejean B J, Tang R A. Reversal of visual loss with hyperbaric oxygen treatment in a patient with Susac syndrome. Ophthalmology. 1996;103(12):2091-2098. [pmid: 9003343].
Li W-R. Cerebral thrombosis treated by hyperbaric oxygenation, A Report of 490 Cases Fujiian Provincial Hospital, Fuzhou, China. In: Proceedings of the Ninth International Congress on Hyperbaric Medicine, March 1–4, 1987, Sydney, Australia. Flagstaff AZ: Best Publishing Company; 1998. p. 115–117.
Lianbi X. The effect of hyperbaric oxygen treatment on the brain-injured child is immediate and long term. In: Joiner JT, editor. Proceedings of the 2nd International Symposium on Hyperbaric Oxygenation in the Brain-Injured Child. Flagstaff, AZ: Best Publishing; 2002. p. 129–129.
Liang B C, Weil M. Locoregional approaches to therapy with gliomas as the paradigm. Curr Opin Oncol. 1998;10(3):201-206. [pmid: 9619355].
Liebelt E L. Hyperbaric oxygen therapy in childhood carbon monoxide poisoning. Curr Opin Ped. 1999;11(3):259-264.
Lim J, Lim W K, Yeo T T, et al. Management of haemorrhagic stroke with hyperbaric oxygen therapy - a case report. Singapore Med J. 2001;42(5):220-223. [pmid: 11876375].
Linstone HA. Multiple perspectives for decision making: bridging the gap between analysis and action. New York: North Holland Publishing; 1984.
Litovitz T L, Larkin R F, Myers R A M. Cyanide poisoning treated with hyperbaric oxygen. Am J Emerg Med. 1983;1(1):94-101. [pmid: 6680611].
Litscher G, Friehs G, Maresch H, et al. Electroencephalographic and evoked potential monitoring in the hyperbaric environment. J Clin Monitor. 1990;6(1):10-17.
Litscher G, Schwarz G, Ratzenhofer-Komenda B, et al. Transcranial cerebral oximetry in the hyperbaric environment. Biomed Tech. 1997;42(3):38-41.
Liu M S, Liu Q R, Mei F J, et al. Treatment and prevention of cadiomuscular ischemia resulted from cerebral ischemia. J Hebei Med Univ. 1997;18:328-329.
Liu P K, Robertson C S, Valadka A. The association between neuronal nitric oxide synthase and neuronal sensitivity in the brain after brain injury. Ann NY Acad Sci. 2002;962:226-41. [pmid: 12076978].
Lobov MA. Hyperbaric oxygenation in treatment of cerebral palsy in childhood. In: Joiner JT, editor. Proceedings of the 2nd International Symposium on Hyperbaric Oxygenation for Cerebral Palsy and the Brain-Injured Child. Flagstaff, AZ: Best Publishing; 2002. p. 119–121.
Long D. Assessment of hyperbaric oxygen for treatment of acute cerebral edema. Pub Health Serv 1984;148.
Lord W D. Burns management in children. Baillieres Clin Anaesth. 1997;11(3):407-426.
Luria AR. Restoration of function after brain injury. New York, Oxford: Pergamon Press; 1963.
Lyle D M, Pierce J P, Freeman E A, et al. Clinical course and outcome of severe head injury in Australia. J Neurosurg. 1986;65(1):15-18. [pmid: 3712023].
MacFarlane C. Hyperbaric oxygen and surgery. S Afr J Surg. 2001;39(4):117-121. [pmid: 11820141].
Machado JJ. Reduction of spasticity, clinically observed in patients with neurological diseases, submitted to hyperbaric oxygen-therapy specially children with cerebral palsy. Presented at: Annual Meeting of the Undersea and Hyperbaric Medicine; 1989.
Machin D, Stenning S P, Parmar M K, et al. Thirty years of Medical Research Council randomized trials in solid tumours. Clin Onc (R Coll Radiol). 1997;9(2):100-114.
Macleod M A, Francis T J R, Smith D J. Enhancing ‘idling’ neurons. Lancet. 1990;335(8693):860-861. [pmid: 1969588].
Mader J T, Hulet W H. Delayed hyperbaric treatment of cerebral air embolism: report of a case. Arch Neurol. 1979;36(8):504-505. [pmid: 508163].
Mader J T, Shirtliff M E, Bergquist S C, et al. Antimicrobial treatment of chronic osteomyelitis. Clin Orthop. 1999;360:47-65. [pmid: 10101310].
Maeda H. Intermittent form of carbon monoxide (CO) poisoning. Japan J Clin Radiol. 1993;38(9):1065-1068.
Mainous E G, Boyne P J, Hart G B. Hyperbaric oxygen treatment of mandibular osteomyelitis: report of three cases. J Am Dent Assoc. 1973;87(7):1426-1430. [pmid: 4518568].
Makishima K, Yoshida M, Kuroda Y, et al. Hyperbaric oxygenation as a treatment for facial palsy. Adv Oto Rhin Laryng. 1998;54:110-118.
Manfre L, Lo C A, Tortorici M, et al. Imaging of ‘malignant’ external otitis. Rev Neuroradiol. 1997;10(4):447-454.
Mansfield W, Brauer R W, Gillen H W, et al. Changes in CNS responses to high pressure during maturation of newborn mice. J Appl Physiol Respir Environ Exercise Physiol. 1980;49(3):390-397.
Manzoni G C, Micieli G, Zanferrari C, et al. Cluster headache. Recent developments in clinical characterization and pathogenesis. Acta Neurol. 1991;13(6):506-513.
Marano P, Pallotta R, Longobardi P, et al. Use of TRH-T during HBO and physiotheraphy treatments of stroke. Undersea Biomed Res Suppl 1991;18(19–23 Jun):34.
Markou K, Lalaki P, Barbetakis N, et al. The efficacy of medication on tinnitus due to acute acoustic trauma. Scand Audiol Suppl. 2001;30(52):180-184. [pmid: 11318462].
Marks J E. Radiation treatment of brain tumors: concepts and strategies. Crit Rev Neurobiol. 1989;5(2):93-112. [pmid: 2561905].
Marler J R, Tilley B C, Lu M, et al. Early stroke treatment associated with better outcome: the NINDS rt-PA stroke study. Neurology. 2000;55(11):1649-1655. [pmid: 11113218].
Marmarou A, Anderson RL, Ward JD, et al. Impact of ICP instability and hypotension on outcome in patients with severe head trauma. J Neurosurg 1991(75):S59–S66.
Marois P. 1998. The use of hyperbaric oxygen therapy in children with cerebral palsy: A pilot study - preliminary results. www.hyperbaric-solutions.com/library Available:1998
Marroni A. Hyperbaric oxygen therapy at 1.5 or 2.0 ATA as an adjunct to the rehabilitation of stabilized stroke patients. A controlled study. In: Proceedings of the Ninth international Congress on Hyperbaric Medicine. Sydney, Australia; 1987. p. 123–129.
Marroni A. Hyperbaric oxygen and in-water rehabilitation in complete stroke. J Hyperbar Med. 1988;3(1):15-27.
Marshall LF, Gautill T, Klauber MR, et al. The outcome of severe closed head injury. J Neurosurg 1991(75):S28–S36.
Martindale L G. Carbon monoxide poisoning: the rest of the story. J Emerg Nurs. 1989;15(2 Part 1):101-104. [pmid: 2649708].
Maslowski J, Dolmierski R, Droszcz J, et al. Results of examinations of the hyperbaric pressure influence on the bioelectric activity of brain in divers during simulated saturated diving to the depth of 20 meters. Bull Inst Marit Trop Med Gdynia. 1986;37(34):239-245. [pmid: 3440167].
Mason R. Reversing nerve damage: the brain therapeutics medical clinic. Alt Complim Ther. 2001;7(5):277-283.
Mathieu D, Nolf M, Durocher A, et al. Acute carbon monoxide poisoning. Risk of late sequelae and treatment by hyperbaric oxygen. J Toxicol Clin Toxicol. 1985;23(46):315-324. [pmid: 4057322].
Mathieu D, Wattel F, Gosselin B, et al. Hyperbaric oxygen in the treatment of posthanging cerebral anoxia. J Hyperb Med. 1987;2(2):63-67.
Mathieu D, Wattel F, Gosselin C, et al. Hyperbaric oxygen therapy in unsuccessful hangings. Presented at: Seventh Annual Conference on Clinical Applications of HBO; 2002.
Matjasko J. Lessons learned. J Neurosurg Anesthesiol. 1996;8(1):1-2. [pmid: 8719184].
Matsuda M, Nakayama H, Arita H, et al. Physiological responses to head-out immersion in water at 11 ATA. Undersea Biomed Res. 1978;5(1):37-52. [pmid: 636073].
Matsuoka S. Theta rhythms: state of consciousness. Brain Topog. 1990;3(1):203-208.
Matsuoka S and Tokuda H. EEG analysis for evaluating chronic cerebral ischemia treated by hyperbaric oxygenation and microsurgery. In: Shiraki K and Matsuoka S, editors. Hyperbaric medicine and underwater physiology. Kitakyushu, Japan: Fukuoka Printing Co, Ltd.; 1983. p. 303–314.
Matthew H, Proudfoot A T. Coal gas and the brain. BMJ. 1968;1(592):638. [pmid: 5637580].
Mazaux J M, Croze P, Quintard B, et al. Satisfaction of life and late psycho-social outcome after severe brain injury: a nine-year follow-up study in Aquitaine. Acta Neurochir Suppl. 2002;79:49-51. [pmid: 11974987].
McArthur D, Kraus J. Epidemiologic aspects of brain injury. Neurol Clin. 1996;14(2):435-450. [pmid: 8827181].
McCrea M, Kelly J P, Randolph C, et al. Immediate Neurocognitive Effects of Concussion. Neurosurg. 2002;50:1032-1042.
McDowall D G, Jennett W B, Bloor K, et al. The effect of hyperbaric oxygen on the oxygen tension of the brain during chloroform anesthesia. Surg Gynecol Obstet. 1966;122(3):545-549. [pmid: 5908664].
McElwain T J, Peckham M J. Blood and neoplastic diseases: management of solid tumours-surgery, radiotherapy, and chemotherapy. BMJ. 1974;4(5945):645-647. [pmid: 4374290]. [pmcid: 1612948].
McGrath B J, Zimmerman J E, Williams J F, et al. Carbon dioxide embolism treated with hyperbaric oxygen. Can J Anaesth. 1989;36(5):586-589. [pmid: 2529050].
Mcgraw C, Wagoner R, Buonanno F, et al. Effect of hyperbaric oxygen on cerebral infarction. Acta Neurol Scand Suppl 1979;(72)(60):470–471.
McHugh D, Moseley R P, Uttley D. Clostridium perfringens brain infection following a penetration wound of the orbit. J Neurol Neurosurg Psychiatry. 1987;50(2):241. [pmid: 2883262].
McLean C. Waking up sleeping cells. Alberta Rep 2000;26(48).
McNamara J O, Appel S H. Biochemical approaches to dementia. Contemp Neurol Ser. 1977;15:155-168. [pmid: 144584].
McSherry CK, Patterson RH and Lamphier EH. Effect of hyperbaric oxygen and hypothermia on cerebral ischemia. In: Brown IW and Cox BG, editors. Proceedings of the Third International Conference on Hyperbaric Medicine. Washington, DC: National Academy of Sciences; 1966. p. 374–380.
Mehta S R, Niyogi M, Kasthuri A S, et al. Carbon monoxide poisoning. J Assoc Phys India. 2001;49:622-625.
Meltzer R M, Engel E D, Turf R. Postoperative gas gangrene. J Foot Surg. 1983;22(2):126-133. [pmid: 6863834].
Mertin J, McDonald W I. Hyperbaric oxygen for patients with multiple sclerosis. BMJ Clin Res. 1984;288(6422):957-960.
Messier L D, Myers R A. A neuropsychological screening battery for emergency assessment of carbon-monoxide-poisoned patients. J Clin Psychol. 1991;47(5):675-684. [pmid: 1939714].
Meulemans A I, Vanderwegen L M, Sabbe M B. Carbon monoxide poisoning and the emergency physician. JEUR. 1993;6(3):124-133.
Meyer J S, Takashima S, Obara K. Wolff's vascular theory of headache, 50 years later. Headache Q. 1993;4(3):222-235.
Mialon P, Barthelemy L. The influence of one hyperbaric oxygen-induced sizure on brain eicosanoid content. Mol Chem Neuropath. 1991;15(1):1-11.
Milby T H, Baselt R C. Health hazards of hydrogen sulfide: current status and future directions. Environ Epidem Toxicol. 1999;1(34):262-269.
Miljkovic-Lolic M, Silbergleit R, Fiskum G, et al. Neuroprotective effects of hyperbaric oxygen treatment in experimental focal cerebral ischemia are associated with reduced brain leukocyte myeloperoxidase activity. Brain Res. 2003;971(1):90-4. [pmid: 12691841].
Miller A R, Zwaigenbaum L. New provincial initiatives for childhood disabilities: the imperative for research. CMAJ. 2001;164(12):1704-1705. [pmid: 11450214]. [pmcid: 81158].
Miller G. Cerebral palsy: an overview. Boston: Butterworth-Heinemann; 1998.
Miller J D. The management of cerebral oedema. Br J Hosp Med. 1979;21(2):152. [pmid: 465850].
Miller J D, Ledingham I M. Reduction of increased intracranial pressure: comparison between hyperbaric oxygen and hyperventilation. Arch Neurol. 1971;24:210-216. [pmid: 5544630].
Miller J D, Sullivan H G. Severe intracranial hypertension. Int Anesthesiol Clin. 1979;17(23):19-75. [pmid: 387614].
Millis S R, Rosenthal M, Novack T A, et al. Long-term neuropsychological outcome after traumatic brain injury. J Head Trauma Rehab. 2001;16(4):343-55.
Ming-zheng H, Su-ying Y, Yan W, et al. An outline for treatment of cerebrovascular disease with hyperbaric oxygen in China. In: Proceedings of the Eleventh International Congerss on Hyperbaric Medicine. Flagstaff, AZ: Best Publishing Company; 1995.
Mitchell S J, Benson M, Vadlamudi L, et al. Cerebral arterial gas embolism by helium: an unusual case successfully treated with hyperbaric oxygen and lidocaine. Ann Emerg Med. 2000;35(3):300-303. [pmid: 10692202].
Mitton C and Hailey D. Hyperbaric oxygen treatment in Alberta. Alberta Heritage Foundation for Medical Research. 1998.
Mitton C, Hailey D. Health technology assessment and policy decisions on hyperbaric oxygen treatment. Int J Tech Assess Health Care. 1999;15(4):661-70.
Mogami H, Hayakawa T, Kanai N, et al. Clinical application of hyperbaric oxygenation in the treatment of acute cerebral damage. J Neurosurg. 1969;31(6):636-643. [pmid: 5359209].
Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352:609-613. [pmid: 9746022].
Molnar G E. Cerebral palsy: prognosis and how to judge it. Pediatr Ann. 1979;8(10):596-605. [pmid: 492784].
Montgomery D, Goldberg J, Amar M, et al. Effects of hyperbaric oxygen therapy on children with spastic diplegic cerebral palsy: a pilot project. Undersea Hyperb Med. 1999;26(4):235-242. [pmid: 10642070].
Morgan D. The focus group guidebook. Thousand Oaks: Sage; 1998.
Mori T, Nagai K. Carbon-monoxide poisoning presenting as an afebrile seizure. Ped Neurol. 2000;22(4):330-331.
Morimura T, Kitz K, Stein H, et al. Determination of proliferative activities in human brain tumor specimens: a comparison of three methods. J Neurooncol. 1991;10(1):1-11. [pmid: 2022970].
Morse WR. Medical malpractice: failure to diagnose and timely treat carbon monoxide intoxication with appropriate hyperbaric oxygen therapy, resulting in brain stem stroke/basilar artery occlusion: defense verdict. Fred Barksdale v California Medical Center and Paul Corona, MD 1996.
Mullins M E, Beltran J T. Acute cerebral gas embolism from hydrogen peroxide ingestion successfully treated with hyperbaric oxygen. J Toxicol Clin Toxicol. 1998;36(3):253-256. [pmid: 9656984].
Muniz E C, Thomaz M C, Kubota M Y, et al. Use of the Glasgow Coma Scale and the Jouvet Coma Scale to evaluate the level of consciousness. Rev Esc Enferm USP. 1997;31(2):287-303. [pmid: 9411580].
Murphy B P, Harford F J, Cramer F S. Cerebral air embolism resulting from invasive medical procedures: treatment with hyperbaric oxygen. Ann Surg. 1985;201(2):242-245. [pmid: 3918516]. [pmcid: 1250649].
Mushkat Y, Luxman D, Nachum Z, et al. Gas embolism complicating obstetric or gynecologic procedures: case reports and review of the literature. Eur J Obstet Gyn Reprod Biol. 1995;63(1):97-103.
Muth C M, Shank E S. Gas embolism. New Engl J Med. 2000;342(7):476-482. [pmid: 10675429].
Myers D E, Myers R A. A preliminary report on hyperbaric oxygen in the relief of migraine headache. Headache. 1995;35(4):197-199. [pmid: 7775175].
Myers R A, Baker T, Cowley R A. Hyperbaric medicine: state of the art, 1979. Am Surg. 1982;48(9):487-494. [pmid: 7125385].
Myers R A, Snyder S K, Emhoff T A. Subacute sequelae of carbon monoxide poisoning. Ann Emerg Med. 1985;14(12):1163-1167. [pmid: 4061987].
Myking O, Schreiner A. Hyperbaric oxygen in hemolytic crisis. JAMA. 1974;227(10):1161-1162. [pmid: 4405898].
Nagayoshi I, Kawashima M, Tamura H, et al. The effect of hyperbaric oxygen therapy for cerebral embolism. Undersea Biomed Res Suppl. 1991;18:35.
Nagorsky M J. Radiation injury of the temporal bone. Clin Plast Surg. 1993;20(3):531-534. [pmid: 8324991].
Nair S, Nair K, Imbruce R. Treatment of chronic vertigo with hyperbaric oxygen. Lancet. 1973;1(7796):184-185. [pmid: 4118797].
Nakajima S, Meyer J S, Shaw T, et al. Cerebral vasomotor responsiveness during 100% oxygen inhalation in cerebral ischemia. Arch Neurol. 1983;40(5):271-276. [pmid: 6847419].
Narayan R K, Michel M E, Ansell B, et al. Clinical trials in head injury. J Neurotrauma. 2002;19(5):503-557. [pmid: 12042091]. [pmcid: 1462953].
Naylor C D. Grey zones of clinical practice: some limits to evidence-based medicine. Lancet. 2001;345:840-2. [pmid: 11747957].
Negovsky V. The neurological stage in reanimatology. Resuscitation. 1995;29(2):169-177. [pmid: 7481099].
Nelson D F, Urtasun R C, Saunders W M, et al. Recent and current investigations of radiation therapy of malignant gliomas. Sem Oncol. 1986;13(1):46-55.
Nelson K B, Ellenberg J H. Antecedents of cerebral palsy: multivariate analysis of risk. N Engl J Med. 1986;315(2):81-86. [pmid: 3724803].
Nelson V, Nelson E, Layon A J. Cerebral arterial gas embolism: a review and update. Respir Care. 1994;39(6):635-644.
Nemiroff P M, Rybak L P. Applications of hyperbaric oxygen for the otolaryngologist-head and neck surgeon. Am J Otolaryng Head Neck Med Surg. 1988;9(2):52-57.
Neretin V Y, Lobov M A, Kotov S V, et al. Hyperbaric oxygenation in comprehensive treatment of parkinsonism. Neurosci Behav Physiol. 1990;20(6):490-492. [pmid: 2096320].
Neubauer B, Tetzlaff K, Staschen C M, et al. Cardiac output changes during hyperbaric hyperoxia. Int Arch Occup Environ Health. 2001;74(2):119-122. [pmid: 11317704].
Neubauer R. The effect of hyperbaric oxygen in prolonged coma: possible identification of marginal functioning brain zones. Med Subacq Iperbar Minerv Med. 1985;5(3):75-79.
Neubauer R. Delayed metabolism or reperfusion in brain imaging after exposure to hyperbaric oxygation. Presented at: XV Annual Meeting of the European Undersea Biomedical Society; Eliat, Israel; 1989.
Neubauer R. Sequential SPECT scanning in long term anoxic encephalopathy. Presented at: UHMS Gulf Coast Chapter Annual Ccientific Assembly; New Orleans, LA; 1995.
Neubauer R. Hyperbaric oxygen therapy. Townsend Lett Doc Pat 1998.
Neubauer R. Hyperbaric oxygen therapy beats… carbon monoxide poisoning, decompression sickness, broken bones, gangrene, multiple sclerosis, severe burns. Bottom Line/Health. 1998;12(5):13-14.
Neubauer R. Hyperbaric oxygenation in cerebral palsy and the brain injured child. Presented at: 3rd EPNS Congress, European Paediatric Neurology Society; 1999.
Neubauer R. New frontiers: Anti-aging properties of hyperbaric oxygen therapy. Townsend Lett Doc Pat 1999.
Neubauer R. Cerebral palsy and the brain injured child. In: Cali-Corleo R, editor. Proceedings of the Annual Meeting on Diving and Hyperbaric Medicine, 26th Annual Meeting of the European Underwater and Baromedical Society. 2000. p. 244–251.
Neubauer R. Sequential SPECT imaging/hyperbaric oxygenation in long-term neurologic deficits. In: Cali-Corleo R, editor. Proceedings of the Annual Meeting on Diving and Hyperbaric Medicine. 2000. p. 211–216.
Neubauer R, Gottlieb S. Stroke treatment. Lancet. 1991;337:1601. [pmid: 1675724].
Neubauer R and Gottlieb SF. Amelioration of long term head injuries with hyperbaric oxygen - documentation via SPECT brain imaging and VCR. Presented at: XVII Annual Meeting on Diving and Hyperbaric Medicine; Crete, Greece; 1991.
Neubauer R, Hall-Dickenson M, Neubauer V I. New hope for kids with cerebral palsy and brain injuries. Alt Med. 2000;33:44-46.
Neubauer R and Kagan RL. Hyperbaric oxygenation in the acute stroke (four-hour window). 13th International Proceedings 2000:28.
Neubauer R, Ljubljana S and James P. Hyperbaric oxygenation: the recoverable brain in certain pediatraic patients. Presented at: 8th International Child Neurology Congress; 1998.
Neubauer R A. Hyperbaric oxygen treatment and stroke. JAMA. 1981;246(22):2574. [pmid: 7299977].
Neubauer RA. Regional cerebral blood flow studies of the effect of hyperbaric oxygen in acute stroke and chronic neurologic deficits of stroke: 30 cases. Presented at: Seventh Annual Conference on Clinical Applications of Hyperbaric Oxygen; 1982.
Neubauer R A. Generalized small-vessel stenosis in the brain: a case history of a patient treated with monoplace hyperbaric oxygen at 1.5 to 2 ATA. Minerva Med. 1983;74(35):2051-2055. [pmid: 6888786].
Neubauer RA. Hyperbaric oxygen in vegetative coma. In: Schutz J, editor. Proceedings of the First Swiss Symposium on Hyperbaric Medicine. Basel, Switzerland: Foundation for Hyperbaric Medicine; 1986. p. 116.
Neubauer R A. Idling neurons. Lancet. 1990;335(8699):1217. [pmid: 1977059].
Neubauer R A. Hyperbaric oxygenation for cerebral palsy. Lancet. 2001;357(9273):2052. [pmid: 11441857].
Neubauer R A, End E. Hyperbaric oxygenation as an adjunct therapy in strokes due to thrombosis: a review of 122 patients. Stroke. 1980;11(3):297-300. [pmid: 7394869].
Neubauer R A, Gottlieb S F. Reversal of a dense, persistent, holohemispheric neurological deficit after an endarterectomy of the carotid artery: case report. Neurosurg. 1992;30(2):301-302.
Neubauer R A, Gottlieb S F, Kagan R L. Enhancing “idling” neurons. Lancet. 1990;335(8688):542. [pmid: 1968553].
Neubauer R A, Gottlieb S F, Miale A Jr. Identification of hypometabolic areas in the brain using brain imaging and hyperbaric oxygen. Clin Nucl Med. 1992;17(6):477-481. [pmid: 1617842].
Neubauer R A, Gottlieb S F, Pevsner N H. Hyperbaric oxygen for treatment of closed head injury. South Med J. 1994;87(9):933-936. [pmid: 8091261].
Neubauer R A, Gottlieb S F, Rockswold G L. Hyperbaric oxygen for brain injury. J Neurosurg. 1993;78(4):687-688. [pmid: 8450347].
Neubauer R A, James P. Cerebral oxygenation and the recoverable brain. Neurol Res. 1998;20(Suppl 1):S33-S36. [pmid: 9584921].
Neubauer R A, James P B, Evans P H, et al. Free radicals and antioxidants. Lancet. 1994;344(8934):1440-1442. [pmid: 7968108].
Neubauer RA and Walker M. Hyperbaric oxygen therapy. Garden City Park, NY: Avery Publishing Group; 2001.
Neuman T S, Hallenbeck J M. Barotraumatic cerebral air embolism and the mental status examination: a report of four cases. Ann Emerg Med. 1987;16(2):220-223. [pmid: 3800099].
New P. Radiation injury to the nervous system. Curr Opin Neurol. 2001;14(6):725-734. [pmid: 11723380].
NHS Centre for Reviews and Dissemination. Undertaking systematic reviews of research on effectiveness, 2nd edition. York, England: University of York. 2001.
Nichter L S, Morwood D T, Williams G S, et al. Expanding the limits of composite grafting: a case report of successful nose replantation assisted by hyperbaric oxygen therapy. Plast Recon Surg. 1991;87(2):337-340.
Nighoghossian N, Trouillas P. Hyperbaric oxygen in the treatment of acute ischemic stroke: an unsettled issue. J Neurolog Sci. 1997;150(1):27-31.
Nighoghossian N, Trouillas P, Adeleine P, et al. Hyperbaric oxygen in the treatment of acute ischemic stroke: a double-blind pilot study. Stroke. 1995;26(8):1369-1372. [pmid: 7631339].
Noguchi T, Itoh N, Aoyagi M, et al. Application of hyperbaric oxygen therapy on central nervous system diseases. In: Shiraki K and Matsuoka S, editors. Hyperbaric Medicine and Underwater Physiology. Program Committee III UOEH Symposium. Kitakyushu, Japan; 1983. p. 297–301.
Norkool D M, Kirkpatrick J N. Treatment of acute carbon monoxide poisoning with hyperbaric oxygen: a review of 115 cases. Ann Emerg Med. 1985;14(12):1168-1171. [pmid: 4061988].
Norman J N, Childs C M, Jones C, et al. Management of a complex diving accident. Undersea Biomed Res. 1979;6(2):209-216. [pmid: 531999].
Novack T A, Bush B A, Meythaler J M, et al. Outcome after traumatic brain injury: pathway analysis of contributions from premorbid, injury severity, and recovery variables. Arch Phys Med Rehab. 2001;82(3):300-5.
Novikova OA and Klyavinsh YY. Effectiveness of hyperbaric oxygenation in severe forms of virus hepatitis and hepatic coma in children. In: Abstracts from the Seventh Congress on HBO Medicine. Moscow; 1981. p. 350.
Nuthall G, Seear M, Lepawsky M, et al. Hyperbaric oxygen therapy for cerebral palsy: two complications of treatment. Pediatrics. 2000;106(6):E80. [pmid: 11099623].
Nyland H, Naess A, Eidsvik S, et al. Effect of hyperbaric oxygen treatment on immunological parameters in multiple sclerosis. Acta Neurol Scand. 1989;79(4):306-310. [pmid: 2499161].
Obrist WD. Hyperbaric oxygen in senile dementia. In; 1975. p. 498–500.
O'Donnell P, Buxton P J, Pitkin A, et al. The magnetic resonance imaging appearances of the brain in acute carbon monoxide poisoning. Clin Radiol. 2000;55(4):273-280. [pmid: 10767186].
Ohashi S, Endoh H, Honda T, et al. Cerebral air embolism complicating percutaneous thin-needle biopsy of the lung: complete neurological recovery after hyperbaric oxygen therapy. J Anesth. 2001;15(4):233-236. [pmid: 14569441].
Ohta H, Kawamura S, Nemoto M. Treatment of increased intracranial pressure by hyperbaric oxygenation. Neurol Med Chir (Tokyo). 1986;26(5):385-391. [pmid: 2429218].
Ohta H, Yasui Y, Kitami K, et al. Intracranial pressure and hyperbaric oxygenation. In: Proceedings of the Eighth International Congress on Hyperbaric Medicine. Flagstaff, AZ: Best Publishing Company; 1987. p. 68–73.
Ohta S, Hadeishi H, Suzuki M. Effect of stellate ganglion block on cerebral blood flow in normoxemic and hyperoxemic states. J Neurosurg Anesthesiol. 1990;2(4):272-279. [pmid: 15815363].
Olson K R. Carbon monoxide poisoning: mechanisms, presentation, and controversies in management. J Emerg Med. 1984;1(3):233-243. [pmid: 6520369].
Olszanski R, Wermut W, Sicko Z, et al. Case of carbon monoxide poisoning treated with oxygen hyperbarism. Bull Inst Marit Trop Med Gdynia. 1993;44–45(14):83-87. [pmid: 7580355].
Omae T, Ibayashi S, Kusuda K, et al. Effects of high atmospheric pressure and oxygen on middle cerebral blood flow velocity in humans measured by transcranial Doppler. Stroke. 1998;29(1):94-97. [pmid: 9445335].
O'Meara S, Cullum N, Majid M, et al. Systematic reviews of wound care management: (3) antimicrobial agents for chronic wounds; (4) diabetic foot ulceration. Health Tech Assess. 2000;4(21):1-237.
Omenaas E, Moerkve O, Thomassen L, et al. Cerebral air embolism after transthoracic aspiration with a 0.6 mm (23 gauge) needle. Europ Respir J. 1989;2(9):908-910.
Orencia A and Biller J. Epidemiology and natural history of adult ischemic cerebrovascular disease. In: Zieler RE, editor. Surgical management of cardiovascular disese. New York: McGraw-Hill; 1995. p. 101–125.
Oriani G, Marroni A and Wattel F, ed. Handbook on hyperbaric medcine. New York: Springer; 1995.
Oshima M, Sadoshima S, Kusuda K, et al. Clinical application of hyperbaric oxygen therapy for acute cerebral infarction. Undersea Biomed Res Suppl. 1990;17:140.
Ouriel K. Peripheral arterial disease. Lancet. 2001;358(9289):1257-1264. [pmid: 11675083].
Ozyar E, Atahan I L. Caution on the use of altered fractionation for nasopharyngeal carcinoma. Radiother Oncol. 2000;54(3):283-284. [pmid: 10836902].
Packard M. 2000. The Cornell Study. www.netnet.net/mums/cornell.htm Available:2000
Pagani M, Ansjon R, Lind F, et al. Effects of acute hypobaric hypoxia on regional cerebral blood flow distribution: a single photon emission computed tomography study in humans. Acta Physiol Scand. 2000;168(3):377-383. [pmid: 10712575].
Pao B S, Hayden S R. Cerebral gas embolism resulting from inhalation of pressurized helium. Ann Emerg Med. 1996;28(3):363-366. [pmid: 8780487].
Pascual J, Peralta G, Sanchez U. Preventive effects of hyperbaric oxygen in cluster headache. Headache. 1995;35(5):260-261. [pmid: 7775187].
Paulson O B. Cerebral apoplexy (stroke): pathogenesis, pathophysiology and therapy as illustrated by regional blood flow measurements in the brain. Stroke. 1971;2(4):327-360. [pmid: 5164585].
Peacock A. ABC of oxygen. Oxygen at high altitude. BMJ. 1998;317(7165):1063-1066. [pmid: 9774298]. [pmcid: 1114067].
Pearson R R, Goad R F. Delayed cerebral edema complicating cerebral arterial gas embolism: case histories. Undersea Biomed Res. 1982;9(4):283-296. [pmid: 7168093].
Peirce E C. Specific therapy for arterial air embolism. Ann Thor Surg. 1980;29(4):300-303.
Peirce E C, Kaufmann H, Bensky W H, et al. A registry for carbon monoxide poisoning in New York City. J Toxicol Clin Toxicol. 1988;26(7):419-441. [pmid: 3230596].
Pereira P. A fatal case of cerebral artery gas embolism following fine needle biopsy of the lung. Med J Aust. 1993;159(1112):755-757. [pmid: 8264461].
Perry G F Jr. Occupational medicine forum. J Occup Med. 1994;36(6):595-597. [pmid: 7830163].
Phillips Y Y. Primary blast injuries. Ann Emerg Med. 1986;15(12):1446-1450. [pmid: 3535591].
Piantadosi C A. Diagnosis and treatment of carbon monoxide poisoning. Respir Care Clin N Amer. 1999;5(2):183-202. [pmid: 10333448].
Pierallini A, Pantano P, Fantozzi L M, et al. Correlation between MRI findings and long-term outcome in patients with severe brain trauma. Neuroradiology. 2000;42(12):860-7. [pmid: 11198202].
Pilgramm M. Clinical and animal experiment studies to optimise the therapy for acute acoustic trauma. Scand Audiol Suppl. 1991;20(34):103-122. [pmid: 1842458].
Pilinoga VG, Kondratenko VI and Timoshenko NA. Hyperbaric oxygenation in neonates with intracranial birth injury. In: Abstracts Seventh International Congress on HBO Medicine. Moscow; 1981. p. 366–367.
Pilotti L, DiRenzo F and Ginaldi L. Stroke and HBO: A statistic retrospective examination on the incidence of mortality at five years old. Presented at: XVII Annual Meeting on Diving and Hyperbaric Medicine; Crete, Greece; 1991.
Plafki C, Peters P, Almeling M, et al. Complications and side effects of hyperbaric oxygen therapy. Aviat Space Environ Med. 2000;71(2):119-124. [pmid: 10685584].
Plutzky M. Principles of psychiatric management of chronic brain syndrome. Geriatrics. 1974;29(8):120-124. [pmid: 4842811].
Pollak E W, Frieden F, Ozar M. Perineoscrotal gangrene: two-staged therapeutic approach. South Med J. 1981;74(9):1040-1042. [pmid: 7280747].
Pollard A J. High-altitude health for travellers. Pract Nurs. 1997;14(10):605-608.
Pomper J K, Graulich J, Kovacs R, et al. High oxygen tension leads to acute cell death in organotypic hippocampal slice cultures. Dev Brain Res. 2001;126(1):109-116. [pmid: 11172892].
Ponikvar R, Buturovic J, Cizman M, et al. Hyperbaric oxygenation, plasma exchange, and hemodialysis for treatment of acute liver failure in a 3-year-old child. Artif Organs. 1998;22(11):952-957. [pmid: 9821529].
Popay J, Williams G. Qualitative research and evidence-based healthcare. J Royal Soc Med. 1998;91(suppl 35):3207.
Pracyk J B, Stolp B W, Fife C E, et al. Brain computerized tomography after hyperbaric oxygen therapy for carbon monoxide poisoning. Undersea Hyperb Med. 1995;22(1):1-7. [pmid: 7742705].
Pravdenkova SV, Isakov YV and Yoffe YS. The therapeutic effect of hyperbaric oxygenation in the acute state of aschemic stroke. Anaesthesiol Reanim 1983(6):26–30.
Price J C, Stevens D L. Hyperbaric oxygen in the treatment of rhinocerebral mucormycosis. Laryngoscope. 1980;90(5:Pt 1):t-47. [pmid: 7374303].
Raju G S, Bendixen B H, Khan J, et al. Cerebrovascular accident during endoscopy: consider cerebral air embolism, a rapidly reversible event with hyperbaric oxygen therapy. Gastrointest Endosc. 1998;47(1):70-73. [pmid: 9468427].
Raphael J-C, Elkharrat D, Jars-Guincestre M-C, et al. Trial of normobaric and hyperbaric oxygen for acute carbon monoxide intoxication. Lancet. 1989;2(8660):414-419. [pmid: 2569600].
Rappaport M, Hall K M, Hopkins K. Disability Rating Scale for severe head trauma: coma to community. Arch Phys Med Rehab. 1982;63:118-23.
Raskin A, Gershon S, Crook T H, et al. The effects of hyperbaric and normobaric oxygen on cognitive impairment in the elderly. Arch Gen Psych. 1978;35(1):50-56.
Rattazzi M C, Lanse S B, McCullough R A, et al. Towards enzyme replacement in GM2 gangliosidosis: organ disposition and induced central nervous system uptake of human beta-hexosaminidase in the cat. Birth Defects Orig Art Ser. 1980;16(1):179-193.
Reiffenstein R J, Hulbert W C, Roth S H. Toxicology of hydrogen sulfide. Annu Rev Pharmacol Toxicol. 1992;32:109-134. [pmid: 1605565].
Reisberg B, Ferris S H, Gershon S. An overview of pharmacologic treatment of cognitive decline in the aged. Am J Psych. 1981;138(5):593-600.
Reivich M, Dickson J, Clark J, et al. Role of hypoxia in cerebral circulatory and metabolic changes during hypocarbia in man: studies in hyperbaric milieu. Scand J Clin Lab Invest 1968;102:IV.
Ren H, Wang W, Zhaoming G E, et al. Clinical, brain electric earth map, endothelin and transcranial ultrasonic Doppler findings after hyperbaric oxygen treatment for severe brain injury. Chin Med J. 2001;114(4):387-390. [pmid: 11780460].
Reshef A, Bitterman N, Kerem D. The effect of carbamazepine and ethosuximide on hyperoxic seizures. Epilepsy Res. 1991;8(2):117-121. [pmid: 2065642].
Rios-Tejada F, Azofra-Garcia J, Valle-Garrido J, et al. Neurological manifestation of arterial gas embolism following standard altitude chamber flight: a case report. Aviat Space Environ Med. 1997;68(11):1025-1028. [pmid: 9383503].
Robertson C S. Management of cerebral perfusion pressure after traumatic brain injury. Anesthesiology. 2001;95(6):1513-7. [pmid: 11748413].
Robertson C S, Valadka A B, Hannay H J, et al. Prevention of secondary ischemic insults after severe head injury. Crit Care Med. 1999;27(10):2086-2095. [pmid: 10548187].
Rockswald GL and Ford SE. Treatment of severe head injury with hyperbaric oxygen (HBO). Undersea Biomed Res 1985;12(46).
Rockswold GL. The cerebral microenvironment: hyperbaric oxygen, hypothermia. CN-00220177 1993.
Rockswold GL. The treatment of severe head injury with hyperbaric oxygenation. Hyperb Oxyg Pract 1994:641–648.
Rockswold G L, Ford S E. Preliminary results of a prospective randomized trial for treatment of severely brain-injured patients with hyperbaric oxygen. Minn Med. 1985;68:533-535. [pmid: 4021969].
Rockswold G L, Ford S E, Anderson D C, et al. Results of a prospective randomized trial for treatment of severely brain-injured patients with hyperbaric oxygen. J Neurosurg. 1992;76(6):929-934. [pmid: 1588426].
Rockswold S B, Rockswold G L, Vargo J M, et al. Effects of hyperbaric oxygenation therapy on cerebral metabolism and intracranial pressure in severely brain injured patients. J Neurosurg. 2001;94(3):403-411. [pmid: 11235943].
Rogatsky G G, Shifrin E G, Mayevsky A. Physiologic and biochemical monitoring during hyperbaric oxygenation: a review. Undersea Hyperb Med. 1999;26(2):111-122. [pmid: 10372431].
Rogatsky G G, Shifrin E G, Mayevsky A. Optimal dosing as a necessary condition for the efficacy of hyperbaric oxygen therapy in acute ischemic stroke: a critical review. Neurol Res. 2003;25(1):95-8. [pmid: 12564134].
Roman G. Perspectives in the treatment of vascular dementia. Drug Today. 2000;36(9):641-653.
Rosen B and Abroms I. Cerebral palsy. In: Gilchrist JM, editor. Prognosis in Neurology. Boston: Butterworth-Heinemann; 1998. p. 405–408.
Rosenthal R, Silbergleit R, Hof P, et al. Hyperbaric oxygen reduces neuronal death and improves neurological outcome after canine cardiac arrest. Stroke. 2003;34(5):1311-6. [pmid: 12677019].
Rosner M J, Rosner S D, Johnson A H. Cerebral perfusion pressure: management protocol and clinical results. J Neurosurg. 1995;83(6):949-62. [pmid: 7490638].
Ross D J, Mohsenifar Z, Potkin R T, et al. Pathogenesis of cerebral air embolism during neodymium-YAG laser photoresection. Chest. 1988;94(3):660-662. [pmid: 3409759].
Rossi G F, Maira G, Vignati A, et al. Neurological improvement in chronic ischemic stroke following surgical brain revascularization. Ital J Neurol Sci. 1987;8(5):465-475. [pmid: 3323126].
Rostain J C, Gardette-Chauffour M C, Naquet R. HPNS during rapid compressions of men breathing He-O2 and He-N2-O2 at 300 m and 180 m. Undersea Biomed Res. 1980;7(2):77-94. [pmid: 7404853].
Roth R N, Weiss L D. Hyperbaric oxygen and wound healing. Clin Dermatol. 1994;12(1):141-156. [pmid: 8180937].
Rounthwaite F J, Banerjee P. Hyperbaric oxygen radiotherapy and the need for preliminary myringotomy. Laryngoscope. 1968;78(12):2153-2159. [pmid: 4302688].
Rudehill A, Bellander B M, Weitzberg E, et al. Outcome of traumatic brain injuries in 1,508 patients: impact of prehospital care. J Neurotrauma. 2002;19(7):855-68. [pmid: 12184855].
Russman B S. Cerebral palsy. Curr Treat Option Neurol. 2000;2(2):97-108.
Rusyniak D E, Kirk M A, May J D, et al. Hyperbaric oxygen therapy in acute ischemic stroke: results of the Hyperbaric Oxygen in Acute Ischemic Stroke Trial Pilot Study. Stroke. 2003;34(2):571-4. [pmid: 12574578].
Sacco R L, Wolf P A, Kannel W B, et al. Survival and recurrence following stroke. The Framingham study. Stroke. 1982;13(3):290-295. [pmid: 7080120].
Sadan O, Adler M, Ezra S, et al. Air embolism due to pulmonary barotrauma in a patient undergoing cesarean section. Acta Obstet Gynecol Scand. 1991;70(6):511-513. [pmid: 1763619].
Salazar A M, Warden D L, Schwab K, et al. Cognitive rehabilitation for traumatic brain injury: a randomized trial. Defense and Veterans Head Injury Program (DVHIP) Study Group. JAMA. 2000;283(23):3075-81. [pmid: 10865301].
Salmon WC. Logic, 3rd ed. Upper Saddle River, NJ: Prentice Hall College Division; 1984.
Saltzman HA, Anderson B, Jr., Whalen RE, et al. Hyperbaric oxygen therapy of acute cerebral vascular insufficiency. Presented at: Third International Conference on Hyperbaric Medicine; Durham, NC; 1965.
Salzman C, Shader R I. Psychopharmacology in the aged: research considerations in geriatric psychopharmacology. J Geriatr Psychiatry. 1974;7(2):165-184. [pmid: 4155417].
Samuels A H, Vamos M J, Taikato M R. Carbon monoxide, amnesia and hyperbaric oxygen therapy. Aust NZ J Psych. 1992;26(2):316-319.
Sander A M, Fuchs K L, High W M Jr, et al. The Community Integration Questionnaire revisited: an assessment of factor structure and validity. Arch Phys Med Rehab. 1999;80(10):1303-8.
Sandhu K S, Henry J A. Concepts in the management of poisoning. Curr Anaesth Crit Care. 1996;7(2):95-100.
Sansone A, Gulotta G, Sparacia B, et al. Effect of hyperbaric oxygen therapy on neurologic recovery after focal cerebral ischaemia. Br J Anaesth. 1997;78(Suppl 1):73-74.
Sarno J E, Rusk H A, Diller L, et al. The effect of hyperbaric oxygen on the mental and verbal ability of stroke patients. Stroke. 1972;3(1):10-15. [pmid: 5008300].
Sarno M T, Sarno J E, Diller L. The effect of hyperbaric oxygen on communication function in adults with aphasia secondary to stroke. J Speech Hearing Res. 1972;15(1):42-48. [pmid: 5012810].
Sathananthan G L, Ferris S, Gershon S. Psychopharmacology of aging: current trends. Curr Dev Psychopharmacol. 1977;4:249-264. [pmid: 23249].
Saunders D, Clifton A, Brown M. Measurement of infarct size using MRI predicts prognosis in middle cerebral artery infarction. Stroke. 1995;26(12):2272-2276. [pmid: 7491649].
Saunders P. Hyperbaric oxygen therapy in the management of carbon monoxide. Birmingham, UK: West Midlands Health Technology Assessment Group, University of Birmingham. 2000.
Sawyer R. Grafts, implants, and late osseous reconstruction after maxillofacial trauma. Ear Nose Throat J. 1983;62(8):417-420. [pmid: 6354688].
Sayama T, Mitani M, Inamura T, et al. Normal diffusion-weighted imaging in cerebral air embolism complicating angiography. Neuroradiology. 2000;42(3):192-194. [pmid: 10772140].
Scannel G. Hyperbaric research efforts in traumatic brain injury. Hyperb Med Today. 2000;1(3):34-35.
Schalen W, Hansson L, Nordstrom G, et al. Psychosocial outcome 5–8 years after severe traumatic brain lesions and the impact of rehabilitation services. Brain Inj. 1994;8(1):49-64. [pmid: 8124317].
Scheffer E. Pathological pulmonary changes on an iatrogenic basis. Acta Tubercul Pneum Belg. 1979;70(34):191-201.
Scheinberg P. The neurologic approach to therapy--antiischemic agents. In: Cerebral manifestations of episodic cardiac dysrhythmias. Amsterdam: Excerpta Medica; 1979. p. 165–173.
Scheinkestel C, Bailey M, Myles P, et al. Hyperbaric or normobaric oxygen for acute carbon monoxide poisoning: a randomised controlled clinical trial. Med J Aust 1999(170):203–210.
Schiltz K L. Failure to assess motivation, need to consider psychiatric variables, and absence of comprehensive examination: a skeptical review of neuropsychologic assessment in carbon monoxide research. Undersea Hyperb Med. 2000;27(1):48-50. [pmid: 10813441].
Schmidt J M, Poublon R M. Rhinocerebral mycosis in immunocompromised patients: a case report and review of the literature. Rhinology. 1998;36(2):90-93. [pmid: 9695166].
Schmitz G F. Evaluation of hyperbaric oxygen therapy for senility. HBO Rev. 1981;2:231-251.
Schneider F, Lion R, Kummerlen C, et al. Neurological complications and pleural lavage with a fibrinolytic agent: a two-case report. Intens Care Med. 2000;26(7):995-997.
Schneider J S, Tobe E H, Mozley P D Jr, et al. Persistent cognitive and motor deficits following acute hydrogen sulphide poisoning. Occup Med. 1998;48(4):255-260.
Schreiber M A, Aoki N, Scott B G, et al. Determinants of mortality in patients with severe blunt head injury. Arch Surg. 2002;137(3):285-90. [pmid: 11888450].
Schulz-Stubner S. Laser treatment of endobronchial lesions. Anesthesiology. 1998;88(1):273-274. [pmid: 9447885].
Scolnick B, Hamel D, Woolf A D. Successful treatment of life-threatening propionitrile exposure with sodium nitrite/sodium thiosulfate followed by hyperbaric oxygen. J Occup Med. 1993;35(6):577-580. [pmid: 8331438].
Sealy R. Hyperbaric oxygen in the radiation treatment of head and neck cancers. Lancet 1920;1991.
Sealy R, Cridland S. The treatment of locally advanced head and neck cancer with misonidazole, hyperbaric oxygen and irradiation: an interim report. Int J Radiat Oncol Biol Physics. 1984;10:1721-1723.
Sealy R, Cridland S, Barry L, et al. Irradiation with misonidazole and hyperbaric oxygen: final report on a randomized trial in advanced head and neck cancer. Int J Radiat Oncol Biol Physics. 1986;12:1343-1346.
Seger D, Welch L. Carbon monoxide controversies: neuropsychologic testing, mechanism of toxicity, and hyperbaric oxygen. Ann Emerg Med. 1994;24(2):242-248. [pmid: 8037390].
Selivra A, Rafikov A and Sharapov O. Computerized assessment of EEG-changes in stroke patient during HBO therapy. In: Sipinen SA and Leinio M, editors. Proceedings of the XXI Annual Meeting of EUBS on Diving and Hyperbaric Medicine, Helsinki, Finland. 1995. p. 297.
Sellick B A. Induced hypothermia. Int Anesthesiol Clin. 1967;5(1):118-131. [pmid: 5598837].
Shah S. Hyperbaric oxygen decreases the incidence of neurological sequelae in acute carbon monoxide poisoning. Thorax. 2003;58(2):126. [pmid: 14586044].
Shalkevich V B, Kotova. Hyperbaric oxygenation and prevention of recurrent ischemic stroke. Eur J Neurol. 2000;7(Suppl 3):70.
Shank E S, Muth C M. Decompression illness, latrogenic gas embolism, and carbon monoxide poisoning: the role of hyperbaric oxygen therapy. Int Anesthesiol Clin. 2000;38(1):111-138. [pmid: 10723672].
Sheffield P J, Davis J C. Application of hyperbaric oxygen therapy in a case of prolonged cerebral hypoxia following rapid decompression. Aviat Space Environ Med. 1976;47(7):759-762. [pmid: 971162].
Sheridan R, Shank E. Hyperbaric oxygen treatment: a brief overview of a controversial topic. J Trauma Inj Infect Crit Care. 1999;47(2):426-435.
Sherman S J, Boyer L V, Sibley W A. Cerebral infarction immediately after ingestion of hydrogen peroxide solution. Stroke. 1994;25(5):1065-1067. [pmid: 8165680].
Shibuya H, Terashi H, Kurata S, et al. Gas gangrene following sacral pressure sores. J Dermatol. 1994;21(7):518-523. [pmid: 8089375].
Shiozawa Z, Takahasi H, Takahashi A, et al. Hyperbaric oxygenation treatment for superior sagittal sinus thrombosis: report of two cases. J Hyperb Med. 1986;1(4):203-214.
Shirley P J, Ross J A S. Hyperbaric medicine part I: theory and practice. Curr Anaesth Crit Care. 2001;12(2):114-120.
Shn-rong Z. Hyperbaric oxygen therapy for coma: a report of 336 cases. In: Proceedings of the Eleventh International Congress on Hyperbaric Medicine, Fuzhou, China. Flagstaff, AZ: A Best Publication; 1995. p. 279–285.
Shumate M J. Carbon monoxide poisoning. Chest. 1995;107(5):1474. [pmid: 7750355].
Siddiqui T S. Intracranial pressure - basic concepts and management. J Pakistan Med Assoc. 1981;31(11):262-266.
Signorini DF and Alderson P. Therapeutic hypothermia for head injury. Cochrane Lib 2001(1).
Silbiger A, Halpern P, Melamed Y, et al. Saturation recompression therapy in a diving accident. Aviat Space Environ Med. 1983;54(10):932-933. [pmid: 6651718].
Silver D A, Cross M, Fox B, et al. Computed tomography of the brain in acute carbon monoxide poisoning. Clin Radiol. 1996;51(7):480-483. [pmid: 8689822].
Singhal A B, Dijkhuizen R M, Rosen B R, et al. Normobaric hyperoxia reduces MRI diffusion abnormalities and infarct size in experimental stroke. Neurology. 2002;58(6):945-52. [pmid: 11914413].
Sluijter M E. Symposium on hyperbaric oxygen. Acta Anaesthes Scand Suppl. 1966;25:67-113.
Smallwood P, Murray G B. Neuropsychiatric aspects of carbon monoxide poisioning: a review and single case report suggesting a role for amphetamines. Ann Clin Psych. 1999;11(1):21-27.
Smith G, Lawson D D, Renfrew S, et al. Preservation of cortical activity by breathing oxygen at two atmospheres of pressure during cerebral ischemia. Surg Gynecol Obstet. 1961;113:13-16.
Snyder J W, Safir E F, Summerville G P, et al. Occupational fatality and persistent neurological sequelae after mass exposure to hydrogen sulfide. Am J Emerg Med. 1995;13(2):199-203. [pmid: 7893309].
Soares J C, Gershon S. Advances in the pharmacotherapy of Alzheimer's disease. Eur Arch Psych Clin Neurosci. 1994;244(5):261-271.
Sparacia B, Sparacia G, Sansone A. HBO and cerebral investigations in stroke. Anaesthes Intensve Care Italy. 1991;42(Suppl 2):216-230.
Sparacia G, Banco A, Sparacia B, et al. MR imaging evaluation of the effects of hyperbaric oxygen in the treatment of multiple sclerosis. Rev Neuroradiol. 1998;11(Suppl 2):35-36.
Spencer J, Johansson A. CO and suicide. Aust NZ J Psych. 1989;23(3):312-313.
Spira A. Diving and marine medicine review Part II: diving diseases. J Travel Med. 1999;6(3):180-198. [pmid: 10467155].
Spirduso W W. Physical fitness, aging, and psychomotor speed: a review. J Gerontol. 1980;35(6):850-865. [pmid: 7002994].
Stamford J A. Beyond NMDA antagonists: looking to the future of neuroprotection. Baillieres Clin Anaesth. 1996;10(3):581-598.
Stanfield B A, Cowan W M. The sprouting of septal afferents to the dentate gyrus after lesions of the entorhinal cortex in adult rats. Brain Res. 1982;232(1):162-170. [pmid: 7055693].
Steenblock D. Review of hyperbaric oxygen for stroke rehabilitation. Explore. 1996;5:49-55.
Steenblock D. Hyperbaric oxygen for treament of stroke and traumatic brain injuries. J Naturopath Med. 1998;8(1):61-67.
Steenblock D. Synergistic therapies for maximizing brain injury rehabilitation. Townsend Lett Doc Pat 1999.
Stellar S, Cooper I S. Recent advances in neurosurgical treatment for the elderly. J Am Geriatr Soc. 1970;18(11):845-860. [pmid: 4319509].
Steward D, Williams W G, Freedom R. Hypothermia in conjunction with hyperbaric oxygenation in the treatment of massive air embolism during cardiopulmonary bypass. Ann Thor Surg. 1977;24(6):591-593.
Stovner L J, Sjaastad O. Treatment of cluster headache and its variants. Curr Opin Neurol. 1995;8(3):243-247. [pmid: 7551127].
Strauss M B, Borer R C Jr. Diving medicine: Contemporary topics and their controversies. Am J Emerg Med. 2001;19(3):232-238. [pmid: 11326354].
Struchen M A, Hannay H J, Contant C F, et al. The relation between acute physiological variables and outcome on the Glasgow Outcome Scale and Disability Rating Scale following severe traumatic brain injury. J Neurotrauma. 2001;18(2):115-25. [pmid: 11229706].
Sugawa N, Sekimoto T, Ueda S. Oxygenation under hyperbaric pressure (OHP) therapy for the patient with deep coma caused by cerebellar hemorrhage: a case report. J Kyoto Prefect Univ Med. 1988;97:1091-1096.
Sugiyama H and Kamiyama K. The effectiveness ofhyperbaric oxygenation on cerebral infarction. Presented at: IX International Congress on Hyperbaric Medicine, conference programme; Sydney, Australia; 1987.
Sukoff M. Use of hyperbaric oxygenation for acute cerebral edema. fourth annual conference on clinical application of hyperbaric oxygenation. Presented at: 1979.
Sukoff M, Van Pelt J and Salibian A. Utilization of hyperbaric oxygen in microvascular cerebral revascularization. In: Proceedings of the Eighth International Congress on Hyperbaric Medicine. Flagstaff, AZ: A Best Publication; 1987. p. 153–158.
Sukoff M H. Experience in the treatment of cerebrovascular problems with hyperbaric oxygenation. Stroke. 1978;9:110.
Sukoff MH. Neurological complications of hyperbaric oxygen therapy [abstract]. Presented at: Seventh Annual Conference on Clinical Applications of HBO; 1982.
Sukoff M H. Update on the use of hyperbaric oxygenation for acute cerebral trauma. J Hyperb Med. 1986;1(3):174.
Sukoff M H. Effects of hyperbaric oxygenation. J Neurosurg. 2001;95(3):544-546. [pmid: 11565887].
Sukoff M H, Hollin S A, Espinosa O E, et al. The protective effect of hyperbaric oxygen in experimental cerebral edema. J Neurosurg. 1968;29:236-241. [pmid: 5684405].
Sukoff M H, Ragatz R E. Hyperbaric oxygenation for the treatment of acute cerebral edema. Neurosurg. 1982;10(1):29-38.
Sunami K, Takeda Y, Hashimoto M, et al. Hyperbaric oxygen reduces infarct volume in rats by increasing oxygen supply to the ischemic periphery. Crit Care Med. 2000;28(8):2831-2836. [pmid: 10966258].
Susman M, DiRusso S M, Sullivan T, et al. Traumatic brain injury in the elderly: increased mortality and worse functional outcome at discharge despite lower injury severity. J Trauma Inj Infect Crit Care. 2002;53(2):219-24.
Sussman M. Why don't we know more about what we are doing?. Dev Med Child Neurol. 2001;43(8):507. [pmid: 11508915].
Swaiman K and Russman BS. Cerebral palsy. In: Swaiman K and Ashwal S, editors. Pediatric Neurology, 3rd ed. Boston: Mosby, Inc.; 1999. p. 312–324.
Takita H, Olszewski W, Schimert G, et al. Hyperbaric treatment of cerebral air embolism as a result of open-heart surgery: report of a case. J Thorac Cardiovasc Surg. 1968;55(5):682-685. [pmid: 5651583].
Taliharm A. Hyperbaric oxygenation in treatment of cerebral hypoxia. Anaesthesia & Intensive Care in Italy, Supplemental of Acta Anaesthesiologica Italica. 1991;42(Suppl 2):178-180.
Talton I H, Thompson L W, Dent S J, et al. Investigation of changes in blood gases, EEG and vigilance behavior during increased oxygen pressure in old and young community volunteers. Anaesthesist. 1970;19(7):241-244. [pmid: 5521106].
Tan I K, Lim J M. Anaemia in the critically ill - the optimal haematocrit. Ann Acad Med Singapore. 2001;30(3):293-299. [pmid: 11817294].
Tauboll E, Sorteberg W, Owe J O, et al. Cerebral artery blood velocity in normal subjects during acute decreases in barometric pressure. Aviat Space Environ Med. 1999;70(7):692-697. [pmid: 10417006].
Teasdale G, Jennett B. Assessment of coma and impaired consciousness: a practical scale. Lancet. 1974;2(7872):81-84. [pmid: 4136544].
Teasdale G, Jennett B. Assessment and prognosis of coma after head injury. Acta Neurochir. 1976;34:45-55.
Teicher B A. An overview on oxygen carriers in cancer therapy. Artif Cells Blood Substit Immobil Biotechnol. 1995;23(3):395-405. [pmid: 7493064].
Teoh L S, Gowardman J R, Larsen P D, et al. Glasgow Coma Scale: variation in mortality among permutations of specific total scores. Intens Care Med. 2000;26(2):157-61.
Tetzlaff K, Reuter M, Kampen J, et al. Hyperbaric chamber-related decompression illness in a patient with asymptomatic pulmonary sarcoidosis. Aviat Space Environ Med. 1999;70(6):594-597. [pmid: 10373052].
Thalmann E D. Phenytoin sodium in oxygen-toxicity-induced seizures. Ann Emerg Med. 1983;12(9):592-593. [pmid: 6614618].
Thiede W H, Manley J. Cerebral air embolism and cerebral edema: one regimen of treatment. Aviat Space Environ Med. 1976;47(5):553-555. [pmid: 1275847].
Thom S. Hyperbaric oxygen therapy. J Intens Care Med. 1998;4:58-74.
Thompson L W, Davis G C, Obrist W D, et al. Effects of hyperbaric oxygen on behavioral and physiological measures in elderly demented patients. J Gerontol. 1976;31(1):23-28. [pmid: 1244400].
Thomsen I V. Late outcome of very severe blunt head trauma: a 10–15 year second follow-up. J Neurol Neurosurg Psych. 1984;47(3):260-268.
Thomson L F, Mardel S N, Jack A, et al. Management of the moribund carbon monoxide victim. Arch Emerg Med. 1992;9(2):208-213. [pmid: 1388498].
Thurman DJ, Alverson CA, Brown DB, et al. Traumatic brain injury in the United States: a report to Congress. Atlanta, GA: Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. 1999.
Thurman D J, Alverson C A, Dunn K A, et al. Traumatic brain injury in the United States: a public health perspective. J Head Trauma Rehab. 1999;14(6):602-615.
Tibbles P, Edelsberg J. Medical progress: hyperbaric-oxygen therapy. New Engl J Med. 1996;334(25):1642-1648. [pmid: 8628361].
Tobin D A, Vermund H. A randomized study of hyperbaric oxygen as an adjunct to regularly fractionated radiation therapy for clinical treatment of advanced neoplastic disease. Am J Roentgen Radium Ther Nucl Med. 1971;111(3):613-621.
Tomaszewski C. Carbon monoxide poisoning: early awareness and intervention can save lives. Postgrad Med. 1999;105(1):39-50. [pmid: 9924492].
Tomatis L, Nemiroff M, Riahi M, et al. Massive arterial air embolism due to rupture of pulsatile assist device: successful treatment in the hyperbaric chamber. Ann Thor Surg. 1981;32(6):604-608.
Toole JF. Brain infarction. In: Toole JF, editor. Cerebrovascular disorders. New York: Raven; 1990. p. 277–307.
Toole JF. Cerebrovaxcular disorders. Philadelphia: Lippincott Williams and Wilkins; 1999.
Torbati D, Peyman G A, Wafapoor H, et al. Experimental retinopathy by hyperbaric oxygenation. Undersea Hyperb Med. 1995;22(1):31-39. [pmid: 7742708].
Toscano M, Chiavarelli R, Ruvolo G, et al. Management of massive air embolism during open-heart surgery with retrograde perfusion of the cerebral vessels and hyperbaric oxygenation. Thorac Cardiovasc Surg. 1983;31(3):183-184. [pmid: 6192530].
Tovar E A, Del Campo C, Borsari A, et al. Postoperative management of cerebral air embolism: gas physiology for surgeons. Ann Thor Surg. 1995;60(4):1138-1142.
Tremblay S D, Vanasse M, Amar M, et al. A double blind, randomized, placebo controlled,multicentric, clinical trial assessing the effects of hyperbaric oxygen therapy on cerebral palsy. J Undersea Hyperbar Med Soc. 2000;27(Suppl):64.
Tribbles P, Perrotta P. Treatment of carbon monoxide poisoning: a critical review of human outcome studies comparing normobaric oxygen with hyperbaric oxygen. Ann Emerg Med. 1994;24(2):269-276. [pmid: 8037395].
Trytko B E, Bennett M. Hyperbaric oxygen therapy: complication rates are much lower than author suggest. BMJ. 1999;318(7190):1077-8. [pmid: 10336294].
Tsuro M, Nakagaway Y, Kitaoika K, et al. Treatment of cerebral ischemia by hyperbaric oxygenation. In: Shiraki K and Matsuoka S, editors. Hyperbaric Medicine. Kitakyushu, Japan: Fukuoka Printing Co., Ltd.; 1983. p. 315–328.
Turner M, Clark R J. Emergency casebooks. Glioblastoma presenting as carbon monoxide poisoning. J Accid Emerg Med. 1999;16(2):155-156. [pmid: 10191461].
Turner M, Clark R J. Glioblastoma presenting as carbon monoxide poisoning. J Accid Emerg Med. 1999;16(2):155-156. [pmid: 10191461].
Turner M, Hamilton-Farrell M R, Clark R J. Carbon monoxide poisoning: an update. J Accid Emerg Med. 1999;16(2):92-96. [pmid: 10191439].
Turner M, Kemp P M. Isotope brain scanning with Tc-HMPAO: a predictor of outcome in carbon monoxide poisoning?. Emerg Med J. 1997;14(3):139-141.
Ueki K, Okada K, Hayano M, et al. Symposium: brain edema. Neurol Med Chir. 1967;9:251-261.
Ugboko V I, Assam E, Oginni F O, et al. Necrotising fasciitis of the head and neck: a review of the literature. Nig J Med. 2001;10(1):6-10.
Undersea & Hyperbaric Medical Society. 2002. Indications for hyperbaric oxygen therapy. http://www.uhms.org/Indications/indications.htm Available:2002
Usenko LV and Kligunenko EN. Hyperbaric oxygenation and adaptation to severe craniocerebral trauma. Anaesthesiol Reanim 1993.
Van Bever Donker S C. Hyperbaric oxygen therapy for children with cerebral palsy. S Afr Med J. 1999;89(4):360-361. [pmid: 10341811].
van der Linden J, Layon A J, Mahla M E. High technology and embolism. Mayo Clin Proc. 1992;67(4):401-402. [pmid: 1548960].
Van Genderen L, Waite C L. Evaluation of the rapid recompression-high pressure oxygenation approach to the treatment of traumatic cerebral air embolism. Aerosp Med. 1968;39(7):709-713. [pmid: 5705738].
Van Genderen L and Waite CL. Evaluation of the rapid recompression-high pressure oxygenation approach to the treatment of traumatic cerebral embolism. US Naval Submarine Medical Center. 1968. Report Number 519. p.1–8.
Van Houtte P, Salazar O M, Henry J. Radiotherapy in non-small cell lung cancer: present progress and future perspectives. Eur J Cancer Clin Oncol. 1984;20(8):997-1006. [pmid: 6432542].
van Merkesteyn J P, Balm A J, Bakker D J, et al. Hyperbaric oxygen treatment of osteoradionecrosis of the mandible with repeated pathologic fracture: report of a case. Oral Surg Oral Med Oral Pathol. 1994;77(5):461-464. [pmid: 8028868].
Van Meter K, Weiss L and Harch PG. Hyperbaric oxygen in emergency medicine. In: Jain KK, editor. Textbook of hyperbaric medicine, 3rd rev. ed. Seattle, WA: Hogrefe & Huber; 1999.
Vasano VA, DeNunno T, Urciuoli R, et al. First observations on the use of oxygen under high atmospheric pressure for the treatment of traumatic coma: clinical application of hyperbaric oxygen. Presented at: First International Congress; Amsterdam; 1963.
Vavrina J, Muller W. Therapeutic effect of hyperbaric oxygenation in acute acoustic trauma. Rev Laryngol Otol Rhinol. 1995;116(5):377-380.
Veltkamp R, Toole J F. Hyperbaric oxygen - a neuroprotective adjunct for hyperacute ischemic stroke?. J Neurolog Sci. 1997;150(1):1-2.
Venter A, Leary M, Schoeman J, et al. Hyperbaric oxygen therapy for children with cerebral palsy. S Afr Med J. 1998;88(11):1362-1363. [pmid: 9861934].
Visser G H, Van Hulst R A, Wieneke G H, et al. The contribution of conventional and quantitative electroencephalography during monitoring of exposure to hyperbaric oxygen. Undersea Hyperb Med. 1996;23(2):91-98. [pmid: 8931283].
Visser G H, Van Hulst R A, Wieneke G H, et al. Transcranial Doppler sonographic measurements of middle cerebral artery flow velocity during hyperbaric oxygen exposures. Undersea Hyperb Med. 1996;23(3):157-165. [pmid: 8931283].
Vogel-Scibilia S, Gershon S. An update on cognitive enhancers for the elderly. New Trend Clin Neuropharmacol. 1989;3(4):207-216.
Vysotsky MV, Rodionov VV and Proskoryakov VV. Experience of the use of hyperbaric oxygenation in the treatment of embolism and thrombosis of the cerebral vessels. In: Abstracts from the Seventh International Congress on Hyperbaric Medicine. Moscow; 1981.
Wagner A K, Hammond F M, Sasser H C, et al. Use of injury severity variables in determining disability and community integration after traumatic brain injury. J Trauma Inj Infect Crit Care. 2000;49(3):411-9.
Wagner D L. Total spinal anesthesia during cesarean section hours after previous unintentional dural puncture. Anesthesiology. 1994;81(1):260-261. [pmid: 7992921].
Waisman D, Shupak A, Weisz G, et al. Hyperbaric oxygen therapy in the pediatric patient: the experience of the Israel Naval Medical Institute. Pediatrics. 1998;102(5):E53. [pmid: 9794983].
Walker M. Reversal of residual stroke symptoms using hyperbaric oxygenation therapy. Alt Complim Ther. 1996;2(1):24-31.
Wang C and Lau J. 2001. Hyperbaric oxygen therapy in treatment of hypoxic wounds and diabetic wounds of the lower extremities. http://www.cms.hhs.gov/coverage/8b3-mm2.asp Available:2001
Wang C, Schwaitzberg S, Berliner E, et al. Hyperbaric oxygen for treating wounds: a systematic review of the literature. Arch Surg 2003;138(3):272–9; discussion 280.
Warnell P. Advanced concepts in the management of cerebral vasospasm associated with aneurysmal subarachnoid hemorrhage. Axone. 1996;17(4):86-92. [pmid: 8716943].
Warwar R E, Bullock J D. Rhino-orbital-cerebral mucormycosis: a review. Orbit. 1998;17(4):237-245. [pmid: 12048703].
Wassmann H. Treatment of completed stroke with hyperbaric oxygenation and extra-intracranial arterial bypass operation. Fortschr Med. 1982;100(7):285-288. [pmid: 7076096].
Wassmann H and Holbach KH. Hyperbaric oxygen in the treatment of cerebral ischemia and infarction. In: Schmutz J, editor. Proceedings of the 1st Swiss symposium on hyperbaric medicine. Basel, Switzerland; 1986. p. 206–223.
Waters C. Cognitive enhancing agents: current status in the treatment of Alzheimer's disease. Can J Neurol Sci. 1988;15(3):249-256. [pmid: 3061625].
Weaver L K. Phenytoin sodium in oxygen-toxicity-induced seizures. Ann Emerg Med. 1983;12(1):38-41. [pmid: 6194720].
Weaver L K. Randomized clinical trial in carbon monoxide poisoning needed. Am J Emerg Med. 1994;12(6):685-687. [pmid: 7945612].
Weaver L K. Carbon monoxide poisoning. Crit Care Clin. 1999;15(2):297-317. [pmid: 10331130].
Weaver L K, Hopkins R O, Elliott G. Carbon monoxide poisoning. New Engl J Med. 1999;340(16):1290. [pmid: 10215498].
Weaver L K, Hopkins R O, Larson-Lohr V. Neuropsychologic and functional recovery from severe carbon monoxide poisoning without hyperbaric oxygen therapy. Ann Emerg Med. 1996;27(6):736-740. [pmid: 8644961].
Weaver L K, Hopkins R O, Larson-Lohr V, et al. Hyperbaric oxygen and carbon monoxide poisoning. Ann Emerg Med. 1995;26(3):390-392. [pmid: 7661437].
Weil M H, Becker L, Budinger T, et al. Workshop executive eummary report: post-resuscitative and initial utility in life saving efforts (PULSE). Circulation. 2001;103:1182-4. [pmid: 11238256].
Weiler-Ravell D, Adatto R, Borman J B. Blast injury of the chest: a review of the problem and its treatment. Isr J Med Sci. 1975;11(23):268-274. [pmid: 1172780].
Weiss L D, Ramasastry S S, Eidelman B H. Treatment of a cluster headache patient in a hyperbaric chamber. Headache. 1989;29(2):109-110. [pmid: 2708039].
Weiss L D, Van Meter K W. Cerebral air embolism in asthmatic scuba divers in a swimming pool. Chest. 1995;107(6):1653-1654. [pmid: 7781362].
Weissman A, Peretz B A, Michaelson M, et al. Air embolism following intra-uterine hypertonic saline instillation: treatment in a high-pressure chamber; a case report. Eur J Obstet Gyn Reprod Biol. 1989;33(3):271-274.
Welslau W and Almeling M. Incidence of oxygen intoxication to the central nervous system in hyperbaric oxygen therepy. In: Marroni A, Oriani G and Wattel F, editors. Proceedings of the International Joint Meeting on Hyperbaric and Underwater Medicine. Milan: EUBS; 1996. p. 211–216.
Werner B, Back W, Akerblom H, et al. Two cases of acute carbon monoxide poisoning with delayed neurological sequelae after a “free” interval. J Toxicol Clin Toxicol. 1985;23(46):249-265. [pmid: 4057317].
Whalen R E, Heyman A, Saltzman H. The protective effect of hyperbaric oxygenation in cerebral anoxia. Arch Neurol. 1966;14(1):15-20. [pmid: 5900227].
Whelan HT and Kindwall EP. Hyperbaric oxygen: some unanswered questions despite clinical usefulness. Adv Exper Med Biol 1998;454(pp 441–446):446.
Wherrett C G, Mehran R J, Beaulieu M A. Cerebral arterial gas embolism following diagnostic bronchoscopy: delayed treatment with hyperbaric oxygen : [Embolie gazeuse de l'artere cerebrale suivant une bronchoscopie diagnostique : traitement differe avec l'oxygene hyperbare]. Can J Anaesth. 2002;49(1):96-99. [pmid: 11782337].
Williamson J A, Webb R K, Russell W J, et al. The Australian Incident Monitoring Study: air embolism - an analysis of 2000 incident reports. Anaesth Intensive Care. 1993;21(5):638-641. [pmid: 8273888].
Wilson J R, Foresman B H, Gamber R G, et al. Hyperbaric oxygen in the treatment of migraine with aura. Headache. 1998;38(2):112-115. [pmid: 9529766].
Winter A. Coma and spinal cord dysfunction: Treatment with naloxone, hyperbaric oxygen, transcutaneous nerve stimulation, and electrophrenic pacemaker. J Neurol Orthopaedic Med Surg. 1991;12(2):124-128.
Winter A, Shatin L. Hyperbaric oxygen in reversing carbon monoxide coma: neurologic and psychologic study. NY State J Med. 1970;70(7):880-884.
Winter P, Gage A and Alvis H. Cerebral air embolism occurring during cardiopulmonary by-pass treated with hyperbaric oxygenation: report of 3 cases. In: Proceedings of the Fourth International Congress on Hyperbaric Medicine. Williams & Wilkins Company; 1969. p. 55–60.
Wirjosemito S A, Touhey J E, Workman W T. Type II altitude decompression sickness (DCS): U.S. Air Force experience with 133 cases. Aviat Space Environ Med. 1989;60(3):256-262. [pmid: 2653301].
Wittenborn J R. Pharmacotherapy for age-related behavioral deficiencies. J Nerv Mental Dis. 1981;169(3):139-156.
Wolf H K, Moon R E, Mitchell P R, et al. Barotrauma and air embolism in hyperbaric oxygen therapy. Am J Forensic Med Pathol. 1990;11(2):149-153. [pmid: 2343842].
Wong R, Wright D. Modes of presentation of patent foramen ovale in ten divers. S Pacif Underwater Med Soc J. 2001;31(2):62-69.
Wood J D. The role of gamma-aminobutyric acid in the mechanism of seizures. Prog Neurobiol. 1975;5(1):77-95. [pmid: 830081].
Wood J D, Peesker S J, Rozdilsky B. Sensitivity of GABA synthesis in human brain to oxygen poisoning. Aviat Space Environ Med. 1975;46(9):1155-1156. [pmid: 1164354].
Woolley S M, Lawrence J A, Hornyak J. The effect of hyperbaric oxygen treatment on postural stability and gait of a brain injured patient: single case study. Pediatr Rehab. 1999;3(3):81-90.
Wright J, Bushnik T, O'Hare P. The Center for Outcome Measurement in Brain Injury (COMBI): an Internet resource you should know about. J Head Trauma Rehab. 2000;15(1):734-8.
Wu Z Q, Li Y Z, Zhu S L. The effectiveness of hyperbaric oxygen therapy on protracted coma. J Hyperb Med. 1986;1(3):191.
Yamamoto T, Mori K, Maeda M. Assessment of prognostic factors in severe traumatic brain injury patients treated by mild therapeutic cerebral hypothermia therapy. Neurol Res. 2002;24(8):789-95. [pmid: 12500702].
Yanaka K, Sugimoto K, Yasuda M, et al. Current and future therapies for ischemic cerebrovascular disease II: surgery and new treatments on the horizon. Drug Today. 2001;37(2):75-84.
Yang J T, Chang C N, Lee T H, et al. Hyperbaric oxygen treatment decreases post-ischemic neurotrophin-3 mRNA down-regulation in the rat hippocampus. Neuroreport. 2001;12(16):3589-3592. [pmid: 11733717].
Yang Z. Hyperbaric oxygen in China. Chin Med J. 1985;98(8):613-615. [pmid: 3938726].
Yangsheng T. Hyperbaric oxygen treatment of acute ischemic and anoxic cerebral injury. In: Proceedings of the Eleventh International Congress on Hyperbaric Medicine, Fuzhou, China. Flagstaff, AZ: Best Publishing Co.; 1995. p. 218–222.
Yee L M, Brandon G K. Successful reversal of presumed carbon monoxide-induced semicoma. Aviat Space Environ Med. 1983;54(7):641-643. [pmid: 6882333].
Yin R, Reddihough D, Ditchfield M, et al. Magnetic resonance imaging findings in cerebral palsy. J Paediatr Child Health. 2000;36(2):139-144. [pmid: 10760012].
Yohai R A, Bullock J D, Aziz A A, et al. Survival factors in rhino-orbital-cerebral mucormycosis. Surv Ophthamol. 1994;39(1):3-22.
Yoshii F, Kozuma R, Takahashi W, et al. Magnetic resonance imaging and 11C-N-methylspiperone/positron emission tomography studies in a patient with the interval form of carbon monoxide poisoning. J Neurolog Sci. 1998;160(1):87-91.
Youngberg J T, Myers R A M. Complications from hyperbaric oxygen therapy?. Ann Emerg Med. 1990;19(11):1356. [pmid: 2240743].
Yu-Cheng Y, Yuan-Mei W and Ru-Fang J. Detection of cerebral arterial hemodynamics before and after hyperbaric oxygen treatments in patients with cerebral vascular diseases using 3D-TCD. In: Proceedings of the Eleventh International Congress on Hyperbaric Medicine, Fuzhou, China. Flagstaff, AZ: Best Publishing Co.; 1995. p. 51–53.
Yutsis P. High pressure oxygen treatment. To Your Health 1999.
Zafonte R D, Hammond F M, Mann N R, et al. Relationship between Glasgow coma scale and functional outcome. Am J Phys Med Rehab. 1996;75(5):364-9.
Zafren K. Gamow bag for high-altitude cerebral oedema. Lancet. 1998;352(9124):325-326. [pmid: 9690443].
Zandbergen E G, de Haan R J, Koelman J H, et al. Prediction of poor outcome in anoxic-ischemic coma. J Clin Neurophysol. 2000;17(5):498-501.
Zandbergen E G, de Haan R J, Stoutenbeek C P, et al. Systematic review of early prediction of poor outcome in anoxic-ischaemic coma. Lancet. 1998;352(9143):1808-12. [pmid: 9851380].
Zaza S, Wright-De Aguero L K, Briss P A, et al. Data collection instrument and procedure for systematic reviews in the guide to community preventive services. Am J Prev Med. 2000;18(1 Suppl):44-74. [pmid: 10806979].
Zerbini S. The use of hyperbaric oxygenation in the treatment of chronic childhood encephalopathy. In: Joiner JT, editor. Proceedings of the 2nd International Symposium on Hyperbaric Oxygenation for Cerebral Palsy in the Brain-Injured Child. Flagstaff, AZ: Best Publishing; 2002. p. 189–194.
Zhang J, Jiang J, Zhong T, et al. Outcome of 2,284 cases with acute traumatic brain injury. Chin J Traumatol. 2001;4(3):152-5. [pmid: 11835727].
Zhem Z Y, Zheng S D. Use of HBO in the treatment of impairment of short-term memory in patients with cerebrum thrombosis in different hemispheres. J Hyperb Med. 1986;1(3):173.
Zhi Y, Qingin L and Guiying F. Assessment of the efficacy of combined hyperbaric oxygen therapy in patients with a persistent vegetative state. In: Marroni A, Oriani G and Wattel F, editors. International Joint Meeting on Hyyperbaric and Underwater Medicine; XXII Annual Meeting of the EUBS; XII International Congrees on Hyperbaric Medicine; III Consensus Confrence of the ECHM. Bologna, Italy: Grafica Victoria; 1996.
Zimmerman S S, Truxal B. Carbon monoxide poisoning. Pediatrics. 1981;68(2):215-224. [pmid: 7267228].
Zink R S, Adkinson C D, Davies S F. Neurological recovery after prolonged coma from carbon monoxide poisoning. Am J Emerg Med. 1994;12(5):607-610. [pmid: 8060417].
Ziser A, Adir Y, Lavon H, et al. Hyperbaric oxygen therapy for massive arterial air embolism during cardiac operations. J Thorac Cardiovasc Surg. 1999;117(4):818-821. [pmid: 10096979].