# References

1 Robertson C S. Management of cerebral perfusion pressure after traumatic brain injury. Anesthesiology. 2001;95(6):1513-7. [pmid: 11748413].
2 Bulger E M, Nathens A B, Rivara F P, et al. Management of severe head injury: Institutional variations in care and effect on outcome. Crit Care Med. 2002;30(8):1870-6. [pmid: 12163808].
3 Thurman DJ, Alverson CA, Brown DB, et al. Traumatic brain injury in the United States: a report to Congress. Atlanta, GA: Centers for Disease Control and Prevention, National Center for Injury Prevention and Control; 1999.
4 Thurman D J, Alverson C A, Dunn K A, et al. Traumatic brain injury in the United States: a public health perspective. J Head Trauma Rehab. 1999;14(6):602-615.
5 Anonymous. Rehabilitation of persons with traumatic brain injury. Report of the NIH Consensus Development Conference. Bethesda, MD: National Institutes of Health. National Institute of Child Health and Development; 1999.
6 Jennett B, Bond M R. Assessment of outcome after severe brain damage. Lancet. 1975;1:480-4. [pmid: 46957].
7 Rappaport M, Hall K M, Hopkins K. Disability Rating Scale for severe head trauma: coma to community. Arch Phys Med Rehab. 1982;63:118-23.
8 Teasdale G, Jennett B. Assessment and prognosis of coma after head injury. Acta Neurochir. 1976;34:45-55.
9 Teasdale G, Jennett B. Assessment of coma and impaired consciousness: a practical scale. Lancet. 1974;2(7872):81-84. [pmid: 4136544].
10 Lewin W, Marshall T F, Roberts A H. Long-term outcome after severe head injury. BMJ. 1979;2(6204):1533-1538. [pmid: 119567]. [pmcid: 1597452].
11 Thomsen I V. Late outcome of very severe blunt head trauma: a 10–15 year second follow-up. J Neurol Neurosurg Psych. 1984;47(3):260-268.
12 Lyle D M, Pierce J P, Freeman E A, et al. Clinical course and outcome of severe head injury in Australia. J Neurosurg. 1986;65(1):15-18. [pmid: 3712023].
13 Schalen W, Hansson L, Nordstrom G, et al. Psychosocial outcome 5–8 years after severe traumatic brain lesions and the impact of rehabilitation services. Brain Inj. 1994;8(1):49-64. [pmid: 8124317].
14 Zafonte R D, Hammond F M, Mann N R, et al. Relationship between Glasgow coma scale and functional outcome. Am J Phys Med Rehab. 1996;75(5):364-9.
15 Marshall LF, Gautill T, Klauber MR, et al. The outcome of severe closed head injury. J Neurosurg 1991; (75):S28–S36.
16 Buechler C M, Blostein P A, Koestner A, et al. Variation among trauma centers' calculation of Glasgow Coma Scale score: results of a national survey. J Trauma Inj Infect Crit Care. 1998;45(3):429-32.
17 Teoh L S, Gowardman J R, Larsen P D, et al. Glasgow Coma Scale: variation in mortality among permutations of specific total scores. Intens Care Med. 2000;26(2):157-61.
18 Levin HS, Gary HE, Jr, Eisenberg HM, et al. Neurobehavioral outcome one year after severe head injury: experience of the Traumatic Coma Data Bank. J Neurosurg 1990; (73):699–709.
19 Susman M, DiRusso S M, Sullivan T, et al. Traumatic brain injury in the elderly: increased mortality and worse functional outcome at discharge despite lower injury severity. J Trauma Inj Infect Crit Care. 2002;53(2):219-24.
20 Clark D E, Ryan L M. Concurrent prediction of hospital mortality and length of stay from risk factors on admission. Health Serv Res. 2002;37(3):631-45. [pmid: 12132598]. [pmcid: 1434655].
21 Marmarou A, Anderson RL, Ward JD, et al. Impact of ICP instability and hypotension on outcome in patients with severe head trauma. J Neurosurg 1991; (75):S59–S66.
22 Schreiber M A, Aoki N, Scott B G, et al. Determinants of mortality in patients with severe blunt head injury. Arch Surg. 2002;137(3):285-90. [pmid: 11888450].
23 Katz DI. Brain injury. In: Gilchrist, JM, editor. Prognosis in neurology. Boston: Butterworth-Heinemann; 1998. p. 31–38.
24 Keyser-Marcus L A, Bricout J C, Wehman P, et al. Acute predictors of return to employment after traumatic brain injury: a longitudinal follow-up. Arch Phys Med Rehab. 2002;83(5):635-41.
25 Novack T A, Bush B A, Meythaler J M, et al. Outcome after traumatic brain injury: pathway analysis of contributions from premorbid, injury severity, and recovery variables. Arch Phys Med Rehab. 2001;82(3):300-5.
26 Andrews P J, Sleeman D H, Statham P F, et al. Predicting recovery in patients suffering from traumatic brain injury by using admission variables and physiological data: a comparison between decision tree analysis and logistic regression. J Neurosurg. 2002;97(2):326-36. [pmid: 12186460].
27 Chesnut R, Carney N, Maynard H, et al. Rehabilitation for traumatic brain injury. Rockville, MD: Agency for Health Care Policy and Research Report Number 2; 1999.
28 Fandino J, Stocker R, Prokop S, et al. Cerebral oxygenation and systemic trauma related factors determining neurological outcome after brain injury. J Clin Neurosci. 2000;7(3):226-33. [pmid: 10833621].
29 Katz D I. Neuropathology and neurobehavioral recovery from closed head injury. J Head Trauma Rehab. 1992;27:602-606.
30 Struchen M A, Hannay H J, Contant C F, et al. The relation between acute physiological variables and outcome on the Glasgow Outcome Scale and Disability Rating Scale following severe traumatic brain injury. J Neurotrauma. 2001;18(2):115-25. [pmid: 11229706].
31 Gray D S. Slow-to-recover severe traumatic brain injury: a review of outcomes and rehabilitation effectiveness. Brain Inj. 2000;14:1003-1014. [pmid: 11104140].
32 Lannoo E, Colardyn E, Jannes C, et al. Course of neuropsychological recovery from moderate-to-severe head injury: a 2-year follow-up. Brain Inj. 2001;15:1-13. [pmid: 11201310].
33 Millis S R, Rosenthal M, Novack T A, et al. Long-term neuropsychological outcome after traumatic brain injury. J Head Trauma Rehab. 2001;16(4):343-55.
34 McCrea M, Kelly J P, Randolph C, et al. Immediate Neurocognitive Effects of Concussion. Neurosurg. 2002;50:1032-1042.
35 Kushner D S. Mild traumatic brain injury. Arch Int Med. 1998;158:1617-24. [pmid: 9701095].
36 Bullock R M, Chesnut R, Clifton G L, et al. Management and prognosis of severe traumatic brain injury, part 1: Guidelines for the management of severe traumatic brain injury. J Neurotrauma. 2000;17:451-553.
37 Jain K K. Neuroprotection in cerebrovascular disease. Expert Opin Invest Drug. 2000;9(4):695-711.
38 Narayan R K, Michel M E, Ansell B, et al. Clinical trials in head injury. J Neurotrauma. 2002;19(5):503-557. [pmid: 12042091]. [pmcid: 1462953].
39 Rosner M J, Rosner S D, Johnson A H. Cerebral perfusion pressure: management protocol and clinical results. J Neurosurg. 1995;83(6):949-62. [pmid: 7490638].
40 Robertson C S, Valadka A B, Hannay H J, et al. Prevention of secondary ischemic insults after severe head injury. Crit Care Med. 1999;27(10):2086-2095. [pmid: 10548187].
41 Hayashi N. The brain hypothermia therapy for prevention of vegetation after severe brain injury. Nippon Geka Gakkai Zasshi. 1999;100(7):443-8. [pmid: 10766580].
42 Jiang J, Yu M, Zhu C. Effect of long-term mild hypothermia therapy in patients with severe traumatic brain injury: 1-year follow-up review of 87 cases. J Neurosurg. 2000;93(4):546-9. [pmid: 11014530].
43 Clifton G L, Miller E R, Choi S C, et al. Lack of effect of induction of hypothermia after acute brain injury. New Engl J Med. 2001;344(8):556-63. [pmid: 11207351].
44 Elf K, Nilsson P, Enblad P. Outcome after traumatic brain injury improved by an organized secondary insult program and standardized neurointensive care. Crit Care Med. 2002;30(9):2129-34. [pmid: 12352052].
45 Weil M H, Becker L, Budinger T, et al. Workshop executive eummary report: post-resuscitative and initial utility in life saving efforts (PULSE). Circulation. 2001;103:1182-4. [pmid: 11238256].
46 Zandbergen E G, de Haan R J, Stoutenbeek C P, et al. Systematic review of early prediction of poor outcome in anoxic-ischaemic coma. Lancet. 1998;352(9143):1808-12. [pmid: 9851380].
47 Zandbergen E G, de Haan R J, Koelman J H, et al. Prediction of poor outcome in anoxic-ischemic coma. J Clin Neurophysol. 2000;17(5):498-501.
48 Anonymous. Economic costs of birth defects and cerebral palsy -- United States, 1992. MMWR 1995; 44:(37):694–9.
49 Molnar G E. Cerebral palsy: prognosis and how to judge it. Pediatr Ann. 1979;8(10):596-605. [pmid: 492784].
50 Russman B S. Cerebral palsy. Curr Treat Option Neurol. 2000;2(2):97-108.
51 Furie K. Brain Infarction. In: Gilchrist, JM, editor. Prognosis in neurology. Boston: Butterworth-Heinemann; 1998. p. 83–86.
52 Saunders D, Clifton A, Brown M. Measurement of infarct size using MRI predicts prognosis in middle cerebral artery infarction. Stroke. 1995;26(12):2272-2276. [pmid: 7491649].
53 Sacco R L, Wolf P A, Kannel W B, et al. Survival and recurrence following stroke. The Framingham study. Stroke. 1982;13(3):290-295. [pmid: 7080120].
54 Jorgensen H S, Nakayama H, Raaschou H O, et al. Outcome and time course of recovery in stroke. Part II: Time course of recovery. The Copenhagen Stroke Study. Arch Phys Med Rehab. 1995;76(5):406-412.
55 Grim P, Gottlieb L J, Boddie A, et al. Hyperbaric oxygen therapy. JAMA. 1990;263(16):2216-2220. [pmid: 2181162].
56 Tibbles P, Edelsberg J. Medical progress: hyperbaric-oxygen therapy. New Engl J Med. 1996;334(25):1642-1648. [pmid: 8628361].
57 Sheridan R, Shank E. Hyperbaric oxygen treatment: a brief overview of a controversial topic. J Trauma Inj Infect Crit Care. 1999;47(2):426-435.
58 Leach R M, Rees P J, Wilmshurst P. ABC of oxygen: Hyperbaric oxygen therapy. BMJ. 1998;317(7166):1140-1143. [pmid: 9784458]. [pmcid: 1114115].
59 Kindwall EP. The multiplace chamber. In: Kindwall, EP, Whelan HT, editors. Hyperbaric Medicine Practice. 2nd. Flagstaff, AZ: Best Publishing; 1999.
60 Jain K, editor. Textbook of hyperbaric medicine. 3rd rev. ed. ed. Kirkland, WA: Hogrefe & Huber Publishers, Inc.; 1999.
61 Undersea & Hyperbaric Medical Society. 2002. Indications for hyperbaric oxygen therapy. Available: http://www.uhms.org/Indications/indications.htm
62 Wang C, Lau J. 2001. Hyperbaric oxygen therapy in treatment of hypoxic wounds and diabetic wounds of the lower extremities. Available: http://www.cms.hhs.gov/coverage/8b3-mm2.asp
63 Wang C, Schwaitzberg S, Berliner E, et al. Hyperbaric oxygen for treating wounds: a systematic review of the literature. Arch Surg 2003; 138:(3):272–9; discussion 280.
64 Centers for Medicare and Medicaid. Transmittal 164. National Coverage Determinations (NCDs) Hyperbaric Oxygen Therapy. In: Medicare Coverage Issues Manual; 2002. p. 10–13.
65 Foreman C, Weitershausen J. Regulation of hyperbaric chambers as medical devices. In: Workman, WT, editor. Hyperbaric facility safety: a practical guide. Flagstaff, AZ: Best Publishing Company; 1999. p. 135–147.
66 Anonymous. Hyperbaric oxygen therapy: its use and appropriateness. Dallas, TX: Office of Inspector General, Department of Health and Human Services; 2000.
67 Kindwall EP, Whelan HT, editors. Hyperbaric medicine practice. Flagstaff, AZ: Best Publishing Company; 1999.
68 Scheinkestel C, Bailey M, Myles P, et al. Hyperbaric or normobaric oxygen for acute carbon monoxide poisoning: a randomised controlled clinical trial. Med J Aust 1999; (170):203–210.
69 Liu P K, Robertson C S, Valadka A. The association between neuronal nitric oxide synthase and neuronal sensitivity in the brain after brain injury. Ann NY Acad Sci. 2002;962:226-41. [pmid: 12076978].
70 Harch PG, Neubauer RA. Hyperbaric oxygen therapy in global cerebral ischemia/anoxia and coma, Chapter 18. In: Jain, KK, editor. Textbook of hyperbaric medicine. 3rd rev. ed. Seattle, WA: Hogrefe and Huber Publishers; 1999.
71 Barrett K, Harch P, Masel B, et al. Cognitive and cerebral blood flow improvements in chronic stable traumatic brain injury induced by 1.5 ATA hyperbaric oxygen. Undersea Hyperb Med 1998; 25:(9).
72 Neubauer R A, Gottlieb S F, Miale A Jr. Identification of hypometabolic areas in the brain using brain imaging and hyperbaric oxygen. Clin Nucl Med. 1992;17(6):477-481. [pmid: 1617842].
73 Neubauer R A, Gottlieb S F, Pevsner N H. Hyperbaric oxygen for treatment of closed head injury. South Med J. 1994;87(9):933-936. [pmid: 8091261].
74 Neubauer R A, James P. Cerebral oxygenation and the recoverable brain. Neurol Res. 1998;20(Suppl 1):S33-S36. [pmid: 9584921].
75 Miljkovic-Lolic M, Silbergleit R, Fiskum G, et al. Neuroprotective effects of hyperbaric oxygen treatment in experimental focal cerebral ischemia are associated with reduced brain leukocyte myeloperoxidase activity. Brain Res. 2003;971(1):90-4. [pmid: 12691841].
76 Rosenthal R, Silbergleit R, Hof P, et al. Hyperbaric oxygen reduces neuronal death and improves neurological outcome after canine cardiac arrest. Stroke. 2003;34(5):1311-6. [pmid: 12677019].
77 Neubauer R, Ljubljana S, James P. Hyperbaric oxygenation: the recoverable brain in certain pediatraic patients. Presented at: 8th International Child Neurology Congress; 1998.
78 Neubauer R A. Idling neurons. Lancet. 1990;335(8699):1217. [pmid: 1977059].
79 Neubauer R A, Gottlieb S F, Kagan R L. Enhancing “idling” neurons. Lancet. 1990;335(8688):542. [pmid: 1968553].
80 Stanfield B A, Cowan W M. The sprouting of septal afferents to the dentate gyrus after lesions of the entorhinal cortex in adult rats. Brain Res. 1982;232(1):162-170. [pmid: 7055693].
81 Luria AR. Restoration of function after brain injury. New York, Oxford: Pergamon Press; 1963.
82 Salazar A M, Warden D L, Schwab K, et al. Cognitive rehabilitation for traumatic brain injury: a randomized trial. Defense and Veterans Head Injury Program (DVHIP) Study Group. JAMA. 2000;283(23):3075-81. [pmid: 10865301].
83 Harch P G, Meter V, Gottlieb S. HMPAO SPECT brain imaging and low pressure HBOT in the diagnosis and treatment of chronic traumatic, ischemic, hypoxic and anoxic encephalopathies. Undersea Hyperb Med Suppl. 1994;21:30.
84 Elwood M. Critical Appraisal of epidemiological studies and clinical trials. 2nd editor. New York: Oxford University Press; 1998.
85 Interagency Gray Literature Working Group. Gray Information Functional Plan; 1995.
86 NHS Centre for Reviews and Dissemination. Undertaking systematic reviews of research on effectiveness, 2nd edition. York, England: University of York; 2001.
87 Harris R P, Helfand M, Woolf S H, et al. Methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
88 Artru F, Chacornac R, Deleuze R. Hyperbaric oxygenation for severe head injuries: preliminary results of a controlled study. Eur Neurol. 1976;14(4):310-318. [pmid: 782888].
89 Rockswold G L, Ford S E. Preliminary results of a prospective randomized trial for treatment of severely brain-injured patients with hyperbaric oxygen. Minn Med. 1985;68:533-535. [pmid: 4021969].
90 Rockswold G L, Ford S E, Anderson D C, et al. Results of a prospective randomized trial for treatment of severely brain-injured patients with hyperbaric oxygen. J Neurosurg. 1992;76(6):929-934. [pmid: 1588426].
91 Rockswold GL. The treatment of severe head injury with hyperbaric oxygenation. Hyperb Oxyg Pract 1994; 641–648.
92 Muniz E C, Thomaz M C, Kubota M Y, et al. Use of the Glasgow Coma Scale and the Jouvet Coma Scale to evaluate the level of consciousness. Rev Esc Enferm USP. 1997;31(2):287-303. [pmid: 9411580].
93 Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352:609-613. [pmid: 9746022].
94 Artru F, Philippon B, Gau F, et al. Cerebral blood flow, cerebral metabolism and cerebrospinal fluid biochemistry in brain-injured patients after exposure to hyperbaric oxygen. Eur Neurol. 1976;14(5):351-364. [pmid: 7459].
95 Hayakawa T, Kanai N, Kuroda R, et al. Response of cerebrospinal fluid pressure to hyperbaric oxygenation. J Neurol Neurosurg Psychiatry. 1971;34(5):580-586. [pmid: 5122387].
96 Mogami H, Hayakawa T, Kanai N, et al. Clinical application of hyperbaric oxygenation in the treatment of acute cerebral damage. J Neurosurg. 1969;31(6):636-643. [pmid: 5359209].
97 Rockswold S B, Rockswold G L, Vargo J M, et al. Effects of hyperbaric oxygenation therapy on cerebral metabolism and intracranial pressure in severely brain injured patients. J Neurosurg. 2001;94(3):403-411. [pmid: 11235943].
98 Sukoff M H, Ragatz R E. Hyperbaric oxygenation for the treatment of acute cerebral edema. Neurosurg. 1982;10(1):29-38.
99 Ren H, Wang W, Zhaoming G E, et al. Clinical, brain electric earth map, endothelin and transcranial ultrasonic Doppler findings after hyperbaric oxygen treatment for severe brain injury. Chin Med J. 2001;114(4):387-390. [pmid: 11780460].
100 Jianhui C, Shaohua L. Effect of hyperbaric oxygen in the treatment of patients with brain stem injury. In: Book for 13th International Proceedings. 2000. p. 35–37.
101 Rockswald GL, Ford SE. Treatment of severe head injury with hyperbaric oxygen (HBO). Undersea Biomed Res 1985; 12:(46).
102 Guo H, Chen L, Li W. The evaluation of the effect of HBO therapy by digital symbol test. In: Marroni, A, Oriani G, Wattel F, editors. Proceedings of the International Joint Meting on Hyperbaric and Underwater Medicine, XXII Annual meeting of the EUBS, XII International congress on Hyperbaric Medicine, III Consensus conference of the ECHM, Milano, Italy. Bolgna: Grafica Victoria; 1996. p. 181.
103 Gelety JE, Neubauer RA, Mcgeehe FO. Treatment of chronic vegetative coma with hyperbaric oxygen. Presented at: Eighth Annual Conference on the Clinical Applications of Hyperbaric Oxygen; Long Beach, CA; 1983.
104 Kondratenko VI, Pilinoga VG, Gyulyameryants VA. Hyperbaric oxygenation in neurosurgery [abstract]. In: Abstracts Seventh International Congress on Hyperbaric Medicine. Moscow; 1981. p. 300.
105 Neubauer RA, Walker M. Hyperbaric oxygen therapy. Garden City Park, NY: Avery Publishing Group; 2001.
106 Jianhua N, Xijiu L, Cuixia C, et al. Curative effect analysis of combined treatment of child cerebritis sequel with high pressure oxygen. In: Proceedings of the Eleventh International Congress on Hyperbaric Medicine. Flagstaff, AZ: Best Publishing Company; 1995. p. 214–217.
107 Chuba P J, Aronin P, Bhambhani K, et al. Hyperbaric oxygen therapy for radiation-induced brain injury in children. Cancer. 1997;80(10):2005-2012. [pmid: 9366305].
108 Imai Y. Hyperbaric oxygen (OHP) therapy in memory disturbances. In: Trapp, WG, Bannester EW, Davison AJ, et al., editors. Fifth International Hyperbaric Conference. Burnaby, Canada: Simon Fraser University Press; 1974. p. 402–408.
109 Mathieu D, Wattel F, Gosselin B, et al. Hyperbaric oxygen in the treatment of posthanging cerebral anoxia. J Hyperb Med. 1987;2(2):63-67.
110 Shn-rong Z. Hyperbaric oxygen therapy for coma: a report of 336 cases. In: Proceedings of the Eleventh International Congress on Hyperbaric Medicine, Fuzhou, China. Flagstaff, AZ: A Best Publication; 1995. p. 279–285.
111 Keim L, Aita J, Hankins J, et al. Quantitative spect. scanning in the assessment of patients with ischemic/traumatic brain injury treated with HBO. Chest. 1997;112(3S):91.
112 Zhi Y, Qingin L, Guiying F. Assessment of the efficacy of combined hyperbaric oxygen therapy in patients with a persistent vegetative state. In: Marroni, A, Oriani G, Wattel F, editors. International Joint Meeting on Hyyperbaric and Underwater Medicine; XXII Annual Meeting of the EUBS; XII International Congrees on Hyperbaric Medicine; III Consensus Confrence of the ECHM. Bologna, Italy: Grafica Victoria; 1996.
113 Juan M. Management of hyperbaric oxygen (HBO) for anoxic encephalopathy after open heart surgery done under extracorporeal circulation: a report of four cases. Undersea Biomed Res Suppl 1992; 19:(Jun 23 – 27):100.
114 Lianbi X. The effect of hyperbaric oxygen treatment on the brain-injured child is immediate and long term. In: Joiner, JT, editor. Proceedings of the 2nd International Symposium on Hyperbaric Oxygenation in the Brain-Injured Child. Flagstaff, AZ: Best Publishing; 2002. p. 129–129.
115 Mathieu D, Wattel F, Gosselin C, et al. Hyperbaric oxygen therapy in unsuccessful hangings. Presented at: Seventh Annual Conference on Clinical Applications of HBO; 2002.
116 Lantsev EA. Hyperbaric oxygenation in complex treatment of newborn infants with asphyxia delivered by Caesarian section. In: Abstracts Seventh International Congress on HBO Medicine. Moscow; 2002. p. 368–369.
117 Pilinoga VG, Kondratenko VI, Timoshenko NA. Hyperbaric oxygenation in neonates with intracranial birth injury. In: Abstracts Seventh International Congress on HBO Medicine. Moscow; 1981. p. 366–367.
118 Packard M. 2000. The Cornell Study. Available: http://www.netnet.net/mums/cornell.htm
119 Collet J P, Vanasse M, Marois P, et al. Hyperbaric oxygen for children with cerebral palsy: a randomised multicentre trial. Lancet. 2001;357:582-586. [pmid: 11558483].
120 Hardy P, JP C, J G et-al. Neuropsychological effects of hyperbaric oxygen therapy in cerebral palsy. Dev Med Child Neurol 2002; 44:436–446.
121 Chavdarov I. The effects of hyperbaric oxygenation on psycho-motor functions by children with cerebral palsy. Presented at: Proceedings of the 2nd International Symposium on Hyperbaric Oxygenation in Cerebral Palsy and the Brain-injured Child; 2002.
122 Machado JJ. Reduction of spasticity, clinically observed in patients with neurological diseases, submitted to hyperbaric oxygen-therapy specially children with cerebral palsy. Presented at: Annual Meeting of the Undersea and Hyperbaric Medicine; 1989.
123 Montgomery D, Goldberg J, Amar M, et al. Effects of hyperbaric oxygen therapy on children with spastic diplegic cerebral palsy: a pilot project. Undersea Hyperb Med. 1999;26(4):235-242. [pmid: 10642070].
124 Marois P. 1998. The use of hyperbaric oxygen therapy in children with cerebral palsy: A pilot study - preliminary results. Available: http://www.hyperbaric-solutions.com/library
125 Barrett KF, Corson KP, Mader JT. Pediatric cerebral palsy treatment by 1.5 ATA hyperbaric oxygen - a pilot study [abstract]. 2001.
126 Nighoghossian N, Trouillas P, Adeleine P, et al. Hyperbaric oxygen in the treatment of acute ischemic stroke: a double-blind pilot study. Stroke. 1995;26(8):1369-1372. [pmid: 7631339].
127 Anderson D C, Bottini A G, Jagiella W M, et al. A pilot study of hyperbaric oxygen in the treatment of human stroke. Stroke. 1991;22(9):1137-1142. [pmid: 1926256].
128 Sarno J E, Rusk H A, Diller L, et al. The effect of hyperbaric oxygen on the mental and verbal ability of stroke patients. Stroke. 1972;3(1):10-15. [pmid: 5008300].
129 Marroni A. Hyperbaric oxygen therapy at 1.5 or 2.0 ATA as an adjunct to the rehabilitation of stabilized stroke patients. A controlled study. In: Proceedings of the Ninth international Congress on Hyperbaric Medicine. Sydney, Australia; 1987. p. 123–129.
130 Sarno M T, Sarno J E, Diller L. The effect of hyperbaric oxygen on communication function in adults with aphasia secondary to stroke. J Speech Hearing Res. 1972;15(1):42-48. [pmid: 5012810].
131 Rusyniak D E, Kirk M A, May J D, et al. Hyperbaric oxygen therapy in acute ischemic stroke: results of the Hyperbaric Oxygen in Acute Ischemic Stroke Trial Pilot Study. Stroke. 2003;34(2):571-4. [pmid: 12574578].
132 Marroni A. Hyperbaric oxygen and in-water rehabilitation in complete stroke. J Hyperbar Med. 1988;3(1):15-27.
133 Heyman A, Saltzman HA, Whalen RE. The use of hyperbaric oxygenation in the treatment of cerebral ischemia and infarction. Circulation 1966; 33:(5:Suppl):Suppl-7.
134 Jain K K. Effect of hyperbaric oxygenation on spasticity in stroke patients. J Hyperb Med. 1989;4:55-61.
135 Li W-R. Cerebral thrombosis treated by hyperbaric oxygenation, A Report of 490 Cases Fujiian Provincial Hospital, Fuzhou, China. In: Proceedings of the Ninth International Congress on Hyperbaric Medicine, March 1–4, 1987, Sydney, Australia. Flagstaff AZ: Best Publishing Company; 1998. p. 115–117.
136 Noguchi T, Itoh N, Aoyagi M, et al. Application of hyperbaric oxygen therapy on central nervous system diseases. In: Shiraki, K, Matsuoka S, editors. Hyperbaric Medicine and Underwater Physiology. Program Committee III UOEH Symposium. Kitakyushu, Japan; 1983. p. 297–301.
137 Steenblock D. Hyperbaric oxygen for treament of stroke and traumatic brain injuries. J Naturopath Med. 1998;8(1):61-67.
138 Tsuro M, Nakagaway Y, Kitaoika K, et al. Treatment of cerebral ischemia by hyperbaric oxygenation. In: Shiraki, K, Matsuoka S, editors. Hyperb Med. Kitakyushu, Japan: Fukuoka Printing Co., Ltd.; 1983. p. 315–328.
139 Neubauer R A, End E. Hyperbaric oxygenation as an adjunct therapy in strokes due to thrombosis: a review of 122 patients. Stroke. 1980;11(3):297-300. [pmid: 7394869].
140 Hart G B, Thompson R E. The treatment of cerebral ischemia with hyperbaric oxygen (OHP). Stroke. 1971;2(3):247-250. [pmid: 5165167].
141 Holbach K H, Wassmann H, Hoheluchter K L, et al. Differentiation between reversible and irreversible post-stroke changes in brain tissue: its relevance for cerebrovascular surgery. Surg Neurol. 1977;7(6):325-331. [pmid: 882903].
142 Holbach KH, Wassmann H, Bonatelli AP. A method to identify and treat reversible ischemic alterations of brain tissue. In: Schmiedek, P, editor. Microsurgery for stroke. New York: Springer-Verlag; 1977.
143 Jain KK, Fischer B, Dickreiter B, et al. Hyperbaric oxygen therapy in the rehabilitation of stroke patients. In: Second Swiss Symposium on Hyperbaric Medicine, 2nd European Conference on Hyperbaric Medicine. Basel, Switzerland: Foundation for Hyperbaric Medicine; 1990. p. 341–345.
144 Kapp J P. Neurological response to hyperbaric oxygen--a criterion for cerebral revascularization. Surg Neurol. 1981;15(1):43-46. [pmid: 6277026].
145 Saltzman HA, Anderson B, Jr., Whalen RE, et al. Hyperbaric oxygen therapy of acute cerebral vascular insufficiency. Presented at: Third International Conference on Hyperbaric Medicine; Durham, NC; 1965.
146 Wassmann H, Holbach KH. Hyperbaric oxygen in the treatment of cerebral ischemia and infarction. In: Schmutz, J, editor. Proceedings of the 1st Swiss symposium on hyperbaric medicine. Basel, Switzerland; 1986. p. 206–223.
147 Pilotti L, DiRenzo F, Ginaldi L. Stroke and HBO: A statistic retrospective examination on the incidence of mortality at five years old. Presented at: XVII Annual Meeting on Diving and Hyperbaric Medicine; Crete, Greece; 1991.
148 Jain KK, Klausenbach F, Fischer B. Effect of hyperbaric oxygen (HBO) on spasticity in stroke patients. Undersea Biomed Res Suppl 1989; 16:(June 6–11):25.
149 Hart GB, SD L. The treatment of chronic cerebral ischemia with hyperbaric oxygen: Naval Hospital, Long Beach, CA. In: 5th International Hyperbaric Congress Proceedings. Burnaby, BC Canada: Simon Fraser University; 1973. p. 409–413.
150 Hart GB, Strauss MB. Central nervous system oxygen toxicity in a clinical setting. In: Bove, AA, editor. Proceedings of the Ninth International Symposium on Underwater and Hyperbaric Physiology. Bethesda, MD: Undersea and Hyperbaric Medical Society; 1987. p. 695–699.
151 Harch PG. The dosage of hyperbaric oxygen in chronic brain injury. Proceedings of the 2nd International Symposium on Hyperbaric Oxygenation in Cerebral Palsy and the Brain-injured Child 2002; 31.
152 Nuthall G, Seear M, Lepawsky M, et al. Hyperbaric oxygen therapy for cerebral palsy: two complications of treatment. Pediatrics. 2000;106(6):E80. [pmid: 11099623].
153 Harch PG, Deckoff-Jones J, Neubauer RA. Low pressure hyperbaric oxygen therapy for pediatric brain injury, a minimal risk medical treatment. Pediatrics 2001; Eletter:(http://pediatrics.aappublications.org/cgi/eletters/106/6/e80 - 145).