# Acknowledgments

The research team would like to express our regard and appreciation for the efforts of Martha Swain for editing, Daphne Plaut, MLS, for information services, Debra Burch and Carole Reule for secretarial support, Susan Wingenfeld for program support, and Rosaly Correa-de-Araujo, MD, MSc, PhD, of the Agency for Healthcare Research and Quality for advice as our Task Order Officer.