# Appendix H. Outcome measures used in HBOT studies ^1;^ ^2^

Test Name | Description | Strength of Test | Weakness of Test
2-Point Discrimination Test | With eyes closed, pt asked whether he feels 1 or 2 pins touching tip of finger | Part of Neurological exam; a test of parietal lobe function (sensory part of the brain) | Not very sensitive and not very specific
Ashworth Scale (Spasticity) | Amount of resistance that examiner feels when passively moving a joint | Inexpensive; no equipment needed; a test of muscle tone | Unreliably unless examiner very well trained; inter-rater reliability is generally poor; not specific for spasticity
Bender-Gestalt Test | Pt asked to reproduce figures; a written test | Inexpensive; can be given in 10 minutes; a test of visual-perception | Assumes that pt had normal visual-perception prior to the injury
CT Scan White Matter Low Attenuation Volume | Area of decreased blood flow in the Scan in the white matter part of the brain | High correlation with poor blood flow in the brain | Requires availability of equipment; about $500 per test
Digit Span | Part of the WAIS-R; ask pt to repeat digits as presented by examiner; a test of attention | Reliable; validated and easily administered | Not sensitive
Disability Rating Scale | Sum of ratings over different scales of disability and impairment | Validated, excellent reliability and administered in 5 minutes | Not helpful for mild to moderate TBI
Double Simultaneous Stimulation Test | Same as 2-point discrimination
Electroencephalogram (EEG) | Recording the electrical activity of the brain | Easily performed; excellent reliability | Not specific for a disability
Functional Independent Measure (FIM) | Measures the degree of assistance a pt requires following recovery from a TBI | 30 minute or less to administer; reliable | Cognitive, and behavioral aspects of test not adequate to evaluate TBI pts
Glasgow Coma Scale (GCS) | A scale that semi-objectifies the level of coma (3–15) | Administered at the bed-side; used for assessment of a pt in coma | Must use with other evaluations before offering a prognosis of recovery from the TBI
Glasgow Outcome scale (GOS) | Ordinal rating of Global Outcome (1–5) | Good reliability; administrated at bedside; correlates with GCS | Not very sensitive
Gross Motor Function Measure (GMFM) | Developed to measure changes in motor function in children with CP | Validated, reliable and sensitive | Limited to Children less than age 7 years
Mental Status Examination | Part of Routine Neurological Examination; a screening test for memory, general knowledge, attention, etc. | Easily administered; reliable and valid | A Screening test; not sensitive and not specific.
Motor power of hand by dynamometer | Hand held gauge to determine strength of hand grasp | Reliable and easily administered | Very specific for strength; not correlated with function
Multiple Modality Evoked responses | Tests of pathway for vision, hearing and sensation | Easily administered, reliable | Non-specific
Repetitive Thumb/finger Movements | Ask pt to rapidly oppose finger and thumb; standardized part of the neurologic exam; test of coordination of fine motor movements | Easily administered | Non-specific; very subjective
SPECT (Single Photon Emission Computed Tomography) | Single proton emission computed tomography (SPECT) measures the uptake and distribution of a radioactive nucleotide within the brain and is believed to be proportional to cerebral blood flow (CBF). The CBF demonstrated by SPECT correlates with the metabolic activity that is shown by proton emission tomography (PET). | Less expensive form of functional imaging than the PET scan. This procedure can detect generalized hypo metabolism secondary to anoxia for example. In severe head trauma there is a strong association between axonal injury and decreased metabolism within the brain | Limited prognostic value for recovery for stroke; clinical significance of abnormal SPECT in TBI unknown. To date, there are no studies correlating a change in CBF asdemonstrated by SPECT and a functional change in the patient.
Token Test-test for receptive aphasia | Tokens presented to patient of increasing length and complexity | Educational level does not contaminate the test
Volume of hypodensity on CT Scan | A finding on CT scan that is consistent with an infarction | Well standardized | Not specific; a finding caused by change in blood flow to the brain
WAIS-R (Wechsler Adult Intelligence Scale -Revised) | A validated and reliable test of Intelligence | Good predictor of academic intelligence, especially when recovering form a TBI | May be preserved after TBI despite debilitating problems with executive functions or memory
Wechsler Memory Scale | Well standardized test of immediate recall and long-term memory | | Insensitive for pts with profound memory deficits

The following tests were utilized in one or more of the studies cited; references for these tests could not be found.

Guild Memory test

Hunt-Minnesota Test

Jebsen's test (Fine Motor Function)

Memory Drum test

Neurologic Disability Evaluation

Neurology Recovery Score

Orgogozo Scale

Rankin Disability Scale

Reaction Time (visual and auditory)

Rheology studies

Stockton Geriatric Scale

Tien's Organic integrity Test

Trouilla Scale

Wechsler Mental status

## Appendix H References

1 Assessment of brain SPECT. Report of the Therapeutics and Technology Assessment Subcommittee of the American Academy of Neurology. Neurology 1996; 46(1):278–285.
2 Johnston MV, Hall K, Carnevale G, Boake C. Functional assessment and outcome evaluation in traumatic brain injury rehabilitation. In: Horn LJ, Zasler ND, editors. Medical rehabilitation of traumatic brain injury. Philadelphia: Mosby, 1996: 197–226.