# Appendix G. Unretrieved Studies

1 Hyperbaric oxygen in experimental and clinical cerebral ischemia. International Society of Hyperbaric Medicine 5th Symposium. Word Meeting of Hyperbaric Medicine, Capri, Sept. 26–28: 1991.
2 Cerebral amino acids and acute hyperbaric oxygen toxicity. Undersea & Hyperbaric Medicine Si[ 1992; 19 (Jun 23 – 27):158.
3 Duim W, Cronje FJ. The use of hyperbaric oxygen in acute and sub-acute stroke - a correlation of stroke type, pathophysiology and treatment response in fifteen patients. JNS 187(Suppl 1):2001 1 A.D.; (Suppl. 1):2001.
4 Dunn JE, Connolly JM. Effects of hypobaric and hyperbaric oxygen on experimental brain injury. Hyperbaric medicine 1966;447–454.
5 Fasano VA, Nunno T De, Urciolo R, Lombard G. First observation on the use of oxygen under high pressure for the treatment of traumatic coma. In: Boerema, Brummelkamp, and Meigne, editors. Clinical Application of Hyperbaric Oxygen. Elsevier, Amsterdam: 1964: 168–173.
6 Furutani S. Hyperbaric oxygenation for the ischemic cerebral damage due to cardiac arrest during spinal and epidural anesthesia. J Intesn Car Med. 1986;10:845-850.
7 Jinnai D, et al. Mogami H. Ioko M. Effect of hyperbaric oxygenation on cereberal edema. Neurol Med Clin. 1967;9:260-261.
8 Kapp JP, Smith RR, Markor MR et al. The effect of hyperbaric oxygenation on post-ischemic encephalopathy.: 1982.
9 Keim LW, Aita JF, Hankins JH et al. Quantitative spect. scanning in the assessment of patients with ischemic/traumatic brain injury treated with HBO. Chest 1997; 112(3S) (Sept Supplement):91.
10 Long DM. Assessment of hyperbaric oxygen for treatment of acute cerebral edema. Public Health Service 1984; 148.
11 Neubauer RA. Hyperbaric oxygen in vegetative coma. In: Schutz J, editor. Proceedings of the First Swiss Symposium on Hyperbaric Medicine. Basel, Switzerland: Foundation for Hyperbaric Medicine, 1986: 116.
12 Pravdenkova SV, Isakov YV, Yoffe YS. The therapeutic effect ofhyperbaric oxygenation in the acute state of aschemic stroke. Anesteziol Reanimatol 1983; (6):26–30.
13 Sugiyama H, Kamiyama K The effectiveness ofhyperbaric oxygenation on cerebral infarction.: 1987.
14 Sukoff M Use of hyperbaric oxygenation for acute cerebral edema. fourth annual conference on clinical application of hyperbaric oxygenation. 79 Jun 7-79 Jun 7; Long Beach, Calif.: 1979.
15 Vasano VA, DeNunno T, Urciuoli R et al. First observations on the use of oxygen under high atmospheric pressure for the treatment of traumatic coma. Clinical Application of Hyperbaric oxygen.: Elsevier Publishing, 1964, 1963.
16 Zhem ZY, Zheng SD Use of HBO in the treatment of impairment of short-term memory in patients with cerebrum thrombosis in different hemispheres. 1986.