# Appendix F. Studies with Intermediate Outcomes

1 Hadeishi H, Suzuki E, Suzuki A, et al. Hyperbaric oxygenation therapy for cerebral ischemia. Undersea Biomed Res Suppl. 1990;17:121.
2 Hayakawa T, Kanai N, Kuroda R, et al. Response of cereborspinal fluid pressure to hyperbaric oxygenation. J Neurol Neurosurg Psychiatr. 1971;34(5):580-586. [pmid: 5122387].
3 Ingvar H D, Lassen N A. Treatment of focal cerebral ischemia with hyperbaric oxygen. Acta Neurol Scand. 1965;41:92-95. [pmid: 14274097].
4 Kanai N, Hayakawa T, Mogami H. Blood flow changes in carotid and vertebral arteries by hyperbaric oxygenation. Neurology. 1973;23(2):159-163. [pmid: 4734510].
5 Katsurada K, Minami T, Onji Y. Effect of hyperbaric oxygenation on DSF Po2 in patients with head injury, department of traumatology, Osaka University Hospital, Osaka, Japan. O2 5th Int Hyperbaric Congress Proceedings. Burnaby, BC Canada: Simon Fraser University, 1974: 362–369.
6 Kawamura S., Ohta H., Yasui N, Nemoto M., Hinuma Y., Suzuki E. Effects of hyperbaric oxygenation in patients with subarachnoid hemorrhage evaluated with somatosensory evoked potentials. Proceedings of the Eighth International Congress on Hperbaric Medicine, August 20 – 22, 1984. A Best Publication, 1987: 159–163.
7 Kawamura S, Ohta H, Yasui N, et al. Effects of hyperbaric oxygenation in patients with subarachnoid hemorrhage. J Hyperb Med. 1988;3(4):243-255.
8 Kazantseva N. Mechanisms of curative effect of minimized hyperbaric treatment in cerebral ischemia. Proceedings of the 2nd International Symposium on Hyperbaric Oxygenation for Cerebral Palsy and the Brain-Injured Child. 2002: 199–212.
9 Kohshi K, Yokota A, Konda N, et al. Intracranial pressure responses during hyperbaric oxygen therapy. Neurol Med Chir (Tokyo). 1991;31(9):575-581. [pmid: 1723171].
10 Matsuoka S, Tokuda H. EEG analysis for evaluating chronic cerebral ischemia treated by hyperbaric oxygenation and microsurgery. In: Shiraki K, Matsuoka S, editors. Hyperbaric Medicine and Underwater Physiology. Kitakyushu, Japan: Fukuoka Printing Co, Ltd., 1983: 303–314.
11 Nakajima S, Meyer J S, Shaw T, et al. Cerebral vasomotor responsiveness during 100% oxygen inhalation in cerebral ischemia. Arch Neurol. 1983;40(5):271-276. [pmid: 6847419].
12 Neubauer RA Regional cerebral blood flow studies of the effect of hyperbaric oxygen in acute stroke and chronic neurologic deficits of stroke: 30 cases.: 1982.
13 Ohta H, Yasui Y, Kitami K, Kawamura S., Nemoto M., Hinuma Y. et al. Intracranial pressure and hyperbaric oxygenation. San Pedro, CA: Best Publishing Company, 1987: 68–73.
14 Rockswold SB, Rockswold GL, Vargo JM et al. Effects of hyperbaric oxygenation therapy on cerebral metabolism and intracranial pressure in severely brain injured patients. J Neurosurg 94(3):403–411, 2001.
15 Selivra AI, Rafikov AM, Sharapov OI Computerized assessment of EEG-changes in stroke patient during HBO therapy. 95 A.D. Jun 28; 1995.
16 Yu-Cheng Y, Yuan-Mei W, Ru-Fang J Detection of cerebral arterial hemodynamics before and after hyperbaric oxygen treatments in patients with cerebral vascular diseases using 3D-TCD. Flagstaff, AZ: Best Publishing Co., 1995.