# Appendix E. Excluded Studies

1 Brain Injury Improves with Hyperbaric Oxygen. Life Extension. 1999;5(7), 71.
2 Akimov G A, Lobzin V S, Sapov I A, et al. Assessment of the efficiency of hyperbaric oxygenation therapy in early forms of cerebrovascular disorders. Neurosci Behav Physiol. 1985;15(1):13-17. [pmid: 4000466].
3 Ashamalla H L, Thom S R, Goldwein J W. Hyperbaric oxygen therapy for the treatment of radiation-induced sequelae in children. The University of Pennsylvania experience. Cancer. 1996;77(11):2407-2412. [pmid: 8635114].
4 Belokurov M. HBO in the combined therapy of comatose states in children. Pediatriia 1988.
5 Bischof F. Hyperbaric oxygen therapy in cerebral palsy. S Afr Med J. 2001;91(3):182. [pmid: 11291406].
6 Brown J A, Preul M C, Taha A. Hyperbaric oxygen in the treatment of elevated intracranial pressure after head injury. Pediatr Neurosci. 1988;14(6):286-290. [pmid: 3270048].
7 Chung MM, Strauss MB, Nation PA et al. Clinical outcomes of carbon monoxide poisoned comatose patients. Undersea and Hyperbaric Med suppl 1996; 23 (May 12–26):89.
8 Clifton G L. Hypothermia and hyperbaric oxygen as treatment modalities for severe head injury. New Horizons: Sci Pract Acute Med. 1995;3(3):474-478.
9 Coe J E, Hayes T M. Treatment of experimental brain injury by hyperbaric oxygenation. Am Surg. 1966;32:493-495. [pmid: 5938626].
10 Cordoba-Cabeza T, et al. Hyperbaric oxygenation and neurological recovery in children with organic brain damage. Revista Neurological 1998; (158):571–574.
11 Cronje F, Bever Donker S C, Venter A. Hyperbaric oxygen therapy for children with cerebral palsy. S Afr Med J. 1999;89(4):359-361. [pmid: 10341811].
12 Cronje F. Hyperbaric oxygen therapy for children with cerebral palsy. S Afr Med J. 2001;91(8):615-616. [pmid: 11584767].
13 Ducasse J L. Brain disease after circulatory arrest and hyperbaric oxygen therapy. Med Aeronaut spatiale, Med Subaquat, Hyperb. 1980;73(19):78-79.
14 Ducasse J L, Genestal M, Hugot B, et al. Hyperbaric oxygenotherapy effects on cerebral arterio-venous differences in anoxic comas. Medsubhyp. 1982;1(3):103-110.
15 Dutka A. Hyperbaric oxygen and stroke. Pressure. 1998;27(1):6.
16 Fontanesi J, Golden E, Heideman R. Treatment of radiation induced CNS radiation necrosis with hyperbaric oxygen therapy (HBOT). Undersea Hyperb Med Suppl 1993; 7 – 10 (Jul):20–23.
17 Giebfried J W, Lawson W, Biller H F. Complications of hyperbaric oxygen in the treatment of head and neck disease. Otolaryngol Head Neck Surg. 1986;94(4):508-512. [pmid: 3086814].
18 Gismondi A, Michalelle F, Metrangolo C, et al. Treatment of cerebral ischemia with hyperbaric oxygen therapy. Minn Med. 1980;72:1417-1420.
19 Gottlieb SF, Neubauer RA, Harch PG et al. Hyperbaric oxygen in acute nd chronic deficits of stroke; imagining as a therapeutic guilde. Undersea and Hyperbaric Medical Society Gulf Coast Chapter Annual Scientific Meeting, Ft. Lauderdale, FL, Apr 22–25, 1993.
20 Green M O, Brannen A L. Hyperbaric oxygen therapy for beta-radiation-induced scleral necrosis. Ophthalmology. 1995;102(7):1038-1041. [pmid: 9121750].
21 Guy J, Schatz N J. Hyperbaric oxygen in the treatment of radiation-induced optic neuropathy. Ophthalmology. 1986;93(8):1083-1088. [pmid: 3763158].
22 Hart G B, Thompson R E. The treatment of cerebral ischemia with hyperbaric oxygen (OHP). Stroke. 1971;2(3):247-250. [pmid: 5165167].
23 He KM, Guan LX, Zhang J. Effect of hyperbaric oxygen on neonatal hypoxic-ischmia encephalopathy (32 cases). Chin J Contemp Pediatr 2(5):345–346, 2000.
24 Henk J M. Late results of a trial of hyperbaric oxygen and radiotherapy in head and neck cancer: a rationale for hypoxic cell sensitizers?. Int J Radiat Oncol Biol Phys. 1986;12(8):1339-1441. [pmid: 3531112].
25 Holbach K, Wassman H, Kolberg T. Improved reversibility of traumatic mid-brain syndrome following the use of hyperbaric oxygen. Neurol Neurosurg Exerpt Med. 1975;1975:494.
26 Iwa T, Fell E H, Weinberg M J. Effects of hyperbaric oxygen therapy on cerebral air embolism. Chest. 1960;50:333.
27 Kaasik A E, Dmitriev K K, Tomberg T A. Hyperbaric oxygenation in the treatment of patients with ischemic stroke. Zh Nevropatol Psikhiatr Im S S Korsakova. 1988;88(9):38-43. [pmid: 3232453].
28 Kapp J. Hyperbaric oxygen after circulatory arrest: Modivication of postischemic encephalopathy. Neurosurgery. 1982;11(4):496-499. [pmid: 7145063].
29 Kapp J P. The role of hyperbaric oxygen in the management of cerebral infarction. Geriatr Med Today. 1984;3(4):78-84.
30 Keogh A J. Clostridial brain abscess and hyperbaric oxygen. Postgrad Med J. 1973;49(567):64-66. [pmid: 4354408].
31 Kindwall EP. Acute cerebral edema: Evidence for the efficacy of hyperbaric oxygen and comparison to other modalities. A critical review. Camporesi EM, Barker AC, editors. 166. 1991.
32 Kohshi K, Yokota A, Konda N, et al. Hyperbaric oxygen therapy adjunctive to mild hypertensive hypervolemia for symptomatic vasospasm. Neurol Med Chir (Tokyo). 1993;33(2):92-99. [pmid: 7682672].
33 Lebedev V, et al. Effect of hyperbarixc oxygenation on the clinical course and complications of the acute period of ischemic stroke. Shurnal Vopr Neirokhirnry. 1983;3:37-42.
34 Levine ER, Heyworth E. Hyperbaric treatment of coma of hypoxic origin. Abstracts VII Int Cong HBO Medicine, Moscow, Sept 2–6, 1981. 1981: 337.
35 Marano P, Pallotta R, Longobardi P et al. Use of TRH-T during HBO and physiotheraphy treatments of stroke. Undersea Biomed Res Suppl 1991; 18 (19–23 Jun):34.
36 Mcgraw C, Wagoner R, Buonanno F et al. Effect of hyperbaric oxygen on cerebral infarction. Acta Neurol Scand Suppl 60 1979; (72):470–471.
37 Mclean C. Waking up sleeping cells. Alberta Report 2000; (Feb; 26 (48)).
38 McSherry CK, Patterson RH, Lamphier EH. Effect of hyperbaric oxygen and hypothermia on cerebral ischemia. In: Brown IW, Cox BG, editors. Proceedings of the Third International Conference on Hyperbaric Medicine. Washington, DC: National Academy of Sciences, 1966: 374–380.
39 Miller J D, Ledingham I M. Reduction of increased intracranial pressure. Comparison between hyperbaric oxygen and hyperventilation. Arch Neurol. 1971;24:210-216. [pmid: 5544630].
40 Neubauer R, Gottlieb SF Amelioration of long term head injuries with hyperbaric oxygen - Documentation via SPECT brain imaging and VCR:1991.
41 Neubauer R. Hyperbaric oxygenation in cerebral palsy and the brain injured child. 3rd EPNS Congress, European Paediatric Neurology Society; 7–10 November 1999:283.
42 Neubauer R, Kagan R. Hyperbaric oxygenation in the acute stroke (four-hour window). 13th International Proceedings 2000;28.
43 Neubauer RA Sequential SPECT scanning in long term anoxic encephalopathy. 95 A.D. Mar 30; 1995.
44 Neubauer RA, Ljubljana S, James P Hyperbaric oxygenation: The recoverable brain in certain pediatraic patients: 1998.
45 Neubauer RA. Cerebral palsy and the brain injured child. In: Ramiro Cali-Corleo, editor. Proceedings of the Annual Meeting on Diving and Hyperbaric Medicine, 26th Annual Meeting of the European Underwater and Baromedical Society 2000 Sep 14–17. 2000: 244–251.
46 Neubauer RA. Sequential SPECT imaging/hyperbaric oxygenation in long-term neurologic deficits. In: Ramiro Cali-Corleo, editor. Proceedings of the Annual meeting on Diving and Hyperbaric Medicine. 2000: 211–216.
47 Neubauer R, Hall-Dickenson M, Neubauer VI. New hope for kids with cerebral palsy and brain injuries. Altern Med 2000;(33):44–6, 48–50.
48 Neubauer R A, Gottlieb S F, Rockswold G L. Hyperbaric oxygen for brain injury. J Neurosurg. 1993;78(4):687-688. [pmid: 8450347].
49 Neubauer R A, Gottlieb S F, Pevsner N H. Hyperbaric oxygen for treatment of closed head injury. South Med J. 1994;87(9):933-936. [pmid: 8091261].
50 Nighoghossian N, Trouillas P. Hyperbaric oxygen in the treatment of acute ischemic stroke: An unsettled issue. J Neurol Sci. 1997;150(1):27-31. [pmid: 9260854].
51 Novikova OA, Klyavinsh YY. Effectiveness of hyperbaric oxygenation in severe forms of virus hepatitis and hepatic coma in children. Abstracts VII Cong HBO Medicine, Moscow, Sept. 2–6, 1981. 1981: 350.
52 Rogatsky G G, Shifrin E G, Mayevsky A. Physiologic and biochemical monitoring during hyperbaric oxygenation: a review. Undersea Hyperb Med. 1999;26(2):111-122. [pmid: 10372431].
53 Scannel G. Hyperbaric research efforts in traumatic brain injury. Hyperb Med Today. 2000;1(3):34-35.
54 Schmitz G F. Evaluation of hyperbaric oxygen therapy for senility. HBO Rev. 1981;2:231-251.
55 Shiozawa Z, Takahasi H, Takahashi A, et al. Hyperbaric oxygenation treatment for superior sagittal sinus thrombosis: Report of two cases. J Hyper Med. 1986;1(4):203-214.
56 Smith G, Lawson D D, Renfrew S, et al. Preservation of cortical activity by breathing oxygen at two atmospheres of pressure during cerebral ischemia. Surg Gynecol Obstet. 1961;113:13-16.
57 Sparacia B, Sparacia G V, Sansone A. HBO and cerebral investigations in stroke. Anaesthesia & Intensive Care in Italy. Acta Anaesthesiol Ital. 1991;42(Suppl 2):216-230.
58 Steenblock D A. Review of hyperbaric oxygen for stroke rehabilitation. Explore!. 1996;5:49-55.
59 Sugawa N, Sekimoto T, Ueda S. Oxygenation under hyperbaric pressure (OHP) therapy for the patient with deep coma caused by cerebellar hemorrhage: a case report. J Kyoto Perfect Univ Med. 1988;97:1091-1096.
60 Sukoff M, Van Pelt J I, Salibian A. Utilization of hyperbaric oxygen in microvascular cerebral revascularization. Proceedings of the Eighth International Congress on Hyperbaric Medicine, August 20–22, 1984, Long Beach, CA. A Best Publication, 1987: 153–158.
61 Sukoff M H, Hollin S A, Espinosa O E, et al. The protective effect of hyperbaric oxygen in experimental cerebral edema. J Neurosurg. 1968;29:236-241. [pmid: 5684405].
62 Sukoff M H. Update on the use of hyperbaric oxygenation for acute cerebral trauma. J Hyperb Med. 1986;1(3):174.
63 Sukoff M H. Effects of hyperbaric oxygenation. J Neurosurg. 2001;95(3):544-546. [pmid: 11565887].
64 Taliharm A. Hyperbaric oxygenation in treatment of cerebral hypoxia. Anaesthesia & Intensive Care in Italy. Acta Anaesthesiol Ital. 1991;42(Suppl 2):178-180.
65 Van Bever Donker S C. Hyperbaric oxygen therapy for children with cerebral palsy. S Afr Med J. 1999;89(4):360-361. [pmid: 10341811].
66 Veltkamp R, Toole J F. Hyperbaric oxygen - A neuroprotective adjunct for hyperacute ischemic stroke?. J Neurol Sci. 1997;150(1):1-2. [pmid: 9260851].
67 Venter A, Leary M, Schoeman J, et al. Hyperbaric oxygen therapy for children with cerebral palsy. S Afr Med J. 1998;88(11):1362-1363. [pmid: 9861934].
68 Walker M. Reversal of residual stroke symptoms using hyperbaric oxygenation therapy. Altern Compl Ther. 1996;2(1):24-31.
69 Wassmann H. Treatment of completed stroke with hyperbaric oxygenation and extra-intracranial arterial bypass operation. Fortschr Med. 1982;100(7):285-288. [pmid: 7076096].
70 Whalen R E, Heyman A, Saltzman H. The protective effect of hyperbaric oxygenation in cerebral anoxia. Arch Neurol. 1966;14(1):15-20. [pmid: 5900227].
71 Winter PM, Gage AA, Alvis HJ Cerebral air embolism occurring during cardiopulmonary by-pass treated with hyperbaric oxygenation: Report of 3 cases.: Williams & Wilkins Company, 55–60, 1969.
72 Winter A. Coma and spinal cord dysfunction: Treatment with naloxone, hyperbaric oxygen, transcutaneous nerve stimulation, and electrophrenic pacemaker. J Neurol Orthop Med Surg. 1991;12(2):124-128.
73 Woolley SM, Lawrence JA, Hornyak J. The effect of hyperbaric oxygen treatment on postural stability and gait of a brain injured patient: single case study. Pediatr Rehabil 1999.
74 Wu Z Q, Li Y Z, Zhu S L. The effectiveness of hyperbaric oxygen therapy on protracted coma. J Hyperb Med. 1986;1(3):191.
75 Yee L M, Brandon G K. Successful reversal of presumed carbon monoxide-induced semicoma. Aviation Space Environ Med. 1983;54(7):641-643.