# Appendix D. Quality Assessment Criteria

## US Preventive Services Task Force Criteria for Grading the Internal Validity of Individual Studies

(Harris RP, Helfand M, Woolf SH, et al. Current methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21–35.)

### Randomized Controlled Trials and Cohort Studies

Seven categories of criteria apply to RCTs and cohort studies. They include:

1. Initial assembly of comparable groups.
  a. For RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
  b. For cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
2. Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination).
3. Levels of follow-up: differential loss between groups; overall loss to follow-up.
4. Measurements: equal, reliable, and valid, and including masking of outcome assessment.
5. Clear definition of interventions.
6. All important outcomes considered.
7. Analysis:
  a. For RCTs: intention-to-treat analysis.
  b. For cohort studies: adjustment for potential confounders.

The definitions of the three rating categories for these types of studies are as follows:

Good: Comparable groups assembled initially and maintained throughout the study; follow-up at least 80 percent; reliable and valid measurement instruments applied equally to the groups; outcome assessment masked; interventions defined clearly; all important outcomes considered; appropriate attention to confounders in analysis; for RCTs, intention-to-treat analysis.

Fair: Generally comparable groups assembled initially but some question remains whether some (although not major) differences occurred with follow-up; measurement instruments acceptable (although not the best) and generally applied equally; outcome assessment masked; some, but not all important, outcomes considered; appropriate attention to some, but not all, potential confounders; for RCTs, intention-to-treat analysis.

Poor: Groups assembled initially not close to being comparable or not maintained throughout the study; measurement instruments unreliable or invalid or not applied at all equally among groups; outcome assessment not masked; key confounders given little or no attention; for RCTs, no intention-to-treat analysis.

## Criteria for Grading the Overall Evidence

### Aggregate Internal Validity

This category refers to the overall extent to which data are valid for conditions addressed within studies. It would be rated according to quality grading information about individual studies.

### Aggregate External Validity

This category concerns the generalizability of evidence to questions addressed by the linkage. This would include the concordance between populations, interventions, and outcomes in the studies reviewed (on the one hand) and those to which the linkage pertains (on the other). In short, this category reflects the applicability of the evidence to real-world conditions.

The Methods Work Group expects that differences between conditions examined in studies and those addressed by the linkages should be considered if they could potentially influence outcomes. These might include (but not necessarily be limited to): (a) biologic or pathologic characteristics; (b) incidence and prevalence of clinical conditions; (c) distribution of comorbid conditions that might affect outcomes; and (d) likelihood of acceptability and adherence on the part of patients or providers (or both).

### Consistency

This category relates to the overall “coherence” of the body of evidence relating to the linkage. Specifically, it includes the number of studies, the homogeneity of those studies (in terms of clinical conditions, populations, settings, and the like), the level of precision of findings in the studies, and the direction of results. In addition, it can include dose-response relationships.

## NHS Centre for Reviews and Dissemination, based at University of York

(Available at http://www.york.ac.uk/inst/crd/crd4_ph5.pdf)

### Experimental Studies

1. Was the assignment to the treatment groups really random?
  - Adequate approaches to sequence generation
    - Computer-generated random numbers
    - Random numbers tables
  - Inadequate approaches to sequence generation
    - Use of alternation, case record numbers, birth dates or week days
2. Was the treatment allocation concealed?
  - Adequate approaches to concealment of randomization
    - Centralized or pharmacy-controlled randomization
    - Serially-numbered identical containers
    - On-site computer based system with a randomization sequence that is not readable until allocation
    - Other approaches with robust methods to prevent foreknowledge of the allocation sequence to clinicians and patients
  - Inadequate approaches to concealment of randomization
    - Use of alternation, case record numbers, birth dates, or week days
    - Open random numbers lists
    - Serially numbered envelopes (even sealed opaque envelopes can be subject to manipulation)
3. Were the groups similar at baseline in terms of prognostic factors?
4. Were the eligibility criteria specified?
5. Were the outcome assessors blinded to the treatment allocation?
6. Was the care provider blinded?
7. Was the patient blinded?
8. Were the point estimates and measure of variability presented for the primary outcome measure?
9. Did the analyses include and intention-to-treat analysis?

### Observational Studies

Cohort studies:

- Is there sufficient description of the groups and the distribution of prognostic factors?
- Are the groups assembled at a similar point in their disease progression?
- Is the intervention/treatment reliably ascertained?
- Were the groups comparable on all important confounding factors?
- Was there adequate adjustment for the effects of these confounding variables?
- Was a dose-response relationship between intervention and outcome demonstrated?
- Was outcome assessment blind to exposure status?
- Was followup long enough for the outcomes to occur?
- What proportion of the cohort was followed up?
- Were dropout rates and the reasons for dropout similar across intervention and unexposed groups?

Case series:

- Is the study based on a representative sample selected from a relevant population?
- Are the criteria for inclusion explicit?
- Did all individuals enter the survey at a similar point in their disease progression?
- Was followup long enough for important events to occur?
- Were outcomes assessed using objective criteria or was blinding used?
- If comparisons of sub series are being made, was there sufficient description of the series and the distribution of prognostic factors?