# Appendix C. Literature Search Strategies

## Summary of Online Searching

[underlined: Stroke or Brain Injury Search Terms]

[underlined: MeSH Terms]

Explode brain diseases

Explode confusion

Explode meningitis

Explode coma

Explode craniocerebral trauma

[underlined: Textwords]

Stroke

TIA

Transient ischemi$

Transient ischaemi$

Brain

Cerebro$

Cerebral$

Intracranial$

Concussion$

Confusion$

Coma$

Stupor$

Encephalopath$

Meningitis

Encephalitis

Dementia

Leukoencephalopath$

Leukodystroph$

Cortical dysplas$

Craniocerebral$

[underlined: Hyperbaric Oxygen Therapy Search Terms]

[underlined: MeSH Terms]

Hyperbaric oxygenation

[underlined: Textwords]

Hyperbaric oxygen$

Hyperbaric therap$

## Search Strategy

[sh] = subject heading, [ti] = title word, [ab] = word in abstract

1. exp Brain Diseases/ [sh]
2. exp CONFUSION/ [sh]
3. exp MENINGITIS/ [sh]
4. exp COMA/ [sh]
5. exp Craniocerebral Trauma/ [sh] or exp Head Injury/ [sh]
6. (stroke or tia or brain or cerebro$ or cerebral$) [ti,ab,sh]
7. (transient ischemi$ or transient ischaemi$) [ti,ab,sh]
8. (intracranial$ or concussion$ or confusion$ or coma$) [ti,ab,sh]
9. (stupor$ or encephalopath$ or meningitis) [ti,ab,sh]
10. (encephalitis or dementia or leukoencephalopath$) [ti,ab,sh]
11. (leukodystroph$ or craniocerebral$) [ti,ab,sh]
12. cortical dysplas$ [ti,ab,sh]
13. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12
14. Hyperbaric Oxygenation/ [sh]
15. hyperbaric oxygen$ [ti,ab,sh]
16. hyperbaric therap$ [ti,ab,sh]
17. 14 or 15 or 16
18. 13 and 17
19. limit 18 to (human and english language)

Databases & Results

Database | Date of search | Time period covered | Search interface | Citations | Comments
MEDLINE & PreMEDLINE | 3/23/01 | 1966- | OVID | 400
HealthStar | 3/23/01 | 1975-2000 | OVID | 2 | Excluding MEDLINE citations
CINAHL | 3/23/01 | 1982- | OVID | 17
Cochrane Data- base of Systematic Reviews | 3/23/01 | Issue 1 2001 | Update Software CD | 2
Cochrane Controlled Trials Register | 3/23/01 | Issue 1 2001 | Update Software CD | 16 | Excluding MEDLINE citations
DARE | 3/23/01 | Issue 1 2001 | Update Software CD | 1
AltHealthWatch | 3/23/01 | 1990- | EBSCOhost | 4
MANTIS | 3/23/01 | 1880- | OVID | 1
EMBASE | 3/27/01 | 1980- | OVID | 269 | Much overlap with MEDLINE

Update Searches and Results

Database | Date of search | Time period covered | Search interface | New Citations | Comments
MEDLINE & PreMEDLINE | 1/30/02 | April 2001 - | OVID | 46
| 7/31/03 | February 2002 - | OVID | 10
HealthStar | | | | | Defunct database
CINAHL | 1/30/02 | April 2001 - | OVID | 2
| 7/31/03 | February 2002 - | OVID | 0
Cochrane Database of Systematic Reviews | 2/6/02 | Issue 1 2002 | OVID | 5
Cochrane Controlled Trials Register | 2/6/02 | Issue 1 202 | OVID | 29 | Excluding MEDLINE citations
DARE | 2/6/02 | Issue 1 2002 | OVID | 1
AltHealthWatch | 2/12/02 | April 2001 - | EBSCOhost | 3
MANTIS | 2/12/02 | April 2001 - | OVID | 2
EMBASE | 2/11/02 | April 2001 - | OVID | 34 | Much overlap with MEDLINE
| 7/31/03 | February 2002 - | OVID | 6 | Overlap with MEDLINE
Health Technology Assessment (HTA) | 2/12/02 | | University of York website | 6
Undersea & Hyperbaric Medical Society Database | 2/26/02 | | UHMS proprietary system | 416 | Much overlap with MEDLINE

A small amount of overlap between the databases, including overlap with the previous search, was apparent in the Cochrane Controlled Trials Register, EMBASE, and the Undersea & Hyperbaric Medical Society Database. After eliminating these duplicate citations and conducting dual abstract assessment, 110 full papers were ordered. Eighty-seven of these were from the Undersea & Hyperbaric Medical Society Database, which did not provide abstracts for titles and included a large number of meeting abstracts. In addition to these, one member of the Technical Expert Advisory Group provided articles and meeting abstracts from his personal library (Dr. Paul Harch).