# Appendix B. Research Team, Technical Expert Advisory Group, and Peer Reviewers

## Research Team

- Marian S. McDonagh, PharmD, Principal Investigator
- Assistant Professor of Medical Informatics & Clinical Epidemiology
- Oregon Health & Science University
- Portland, Oregon
- Previously: Senior Research Associate
- Center for Health Research
- Kaiser Permanente Northwest
- Portland, Oregon

- Mark Helfand, MD, MS
- Director, Evidence-based Practice Center
- Associate Professor of Medicine and Medical Informatics & Clinical Epidemiology
- Oregon Health & Science University
- Portland, Oregon

- Joan S. Ash, MLS, MBA, PhD
- Associate Professor of Medical Informatics & Clinical Epdemiology
- Oregon Health & Science University
- Portland, Oregon

- Barry S. Russman, MD
- Professor of Pediatrics and Neurology
- Oregon Health & Science University
- Portland, Oregon

- P. Zoë Stavri, PhD
- Assistant Professor of Medical Informatics & Clinical Epidemilogy
- Oregon Health & Science University
- Portland, Oregon

- Kathryn Pyle Krages, AMLS, MA
- Administrator, OHSU Evidence-based Practice Center
- Division of Medical Informatics & Clinical Epidemiology
- Oregon Health & Science University
- Portland, Oregon

- Susan Carson, MPH
- Senior Research Associate
- Division of Medical Informatics & Clinical Epidemilogy
- Oregon Health & Science University
- Portland, Oregon

- Daphne Plaut, MLS
- Research Center Librarian
- Center for Health Research
- Kaiser Permanente Northwest
- Portland, Oregon

- Martha Swain
- Senior Technical Writer-Editor
- Center for Health Research
- Kaiser Permanente Northwest
- Portland, Oregon

- Debra Burch
- Secretary
- Center for Health Research
- Kaiser Permanente Northwest
- Portland, Oregon

- Susan Wingenfeld
- Research Assistant
- Division of Medical Informatics & Clinical Epidemiology
- Oregon Health & Science University
- Portland, Oregon

## Technical Expert Advisory Group

- Mary Barnease
- New Orleans, Louisiana

- Randall M. Chesnut, MD
- Associate Professor of Neurosurgery
- Oregon Health & Science University
- Portland, Oregon

- Dr Jean-Paul Collet
- Randomised Clinical Trial Unit
- SMBD Jewish General Hospital
- Montreal, Quebec, Canada

- Paul G. Harch, MD
- Clinical Assistant Professor
- Director of Hyperbaric Medicine Fellowship
- President, International Hyperbaric Medical Association
- Department of Medicine, Section of Emergency and Hyperbaric Medicine
- Louisiana State University School of Medicine
- New Orleans, Louisiana

- Jeffrey Shuren, MD, JD
- Centers for Medicare and Medicaid Services
- Coverage and Analysis Group
- Baltimore, Maryland

- Roger P. Simon, MD
- Robert Stone Dow Chair of Neurology
- Director, Dow Neurobiology Laboratories
- Legacy Health System
- Portland, Oregon

- William A. Spisak, MD
- Internal Medicine
- Providence Health System
- Portland, OR

- Tom Workman MS, CHT
- Director, Quality Assurance & Regulatory Affairs
- Undersea & Hyperbaric Medical Society
- San Antonio, Texas

## Peer Reviewers

- David C. Anderson, MD
- Professor of Neurology
- University of Minnesota
- Minneapolis, Minnesota

- Stephen Ashwall, MD
- Representing the Child Neurology Society
- Loma Linda University Children's Hospital
- Loma Linda, California

- David Atkins, MD, MPH
- Chief Medical Officer, Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, Maryland

- Harvey Bernard, MD
- Medical Director
- Office of Medicaid Management
- Albany, New York

- Ronald Deicas, MD
- Center for Medicare and Medicaid Services
- Baltimore, Maryland

- Bruce Flareau, MD
- Representing American Academy of Family Physicians
- Mease Hospital
- Clearwater, Florida

- George Gaebler, MSEd, RRT, FAARC
- Representing American Academy of Respiratory Therapists
- Syracuse, NY

- Murray Goldstein, DO
- United Cerebral Palsy
- Research and Education Foundation
- Washington, DC

- Neil B. Hampson, MD
- Representing Undersea and Hyperbaric Medical Society
- Section Head, Pulmonary and Critical Care Medicine
- Medical Director, Hyperbaric Department
- Virginia Mason Medical Center
- Seattle, WA

- Paul G. Harch, MD
- Clinical Assistant Professor
- Director of Hyperbaric Medicine Fellowship
- President, International Hyperbaric Medical Association
- Department of Medicine, Section of Emergency and Hyperbaric Medicine
- Louisiana State University School of Medicine
- New Orleans, Louisiana

- George Hart, MD
- Long Beach Memorial Hospital
- Long Beach, CA

- Bonnie Kaplan, PhD
- Yale Center for Medical Informatics
- New Haven, Connecticut

- Edgar Kenton III, MD
- Representing American Heart Association
- Wynnewood, Pennsylvania

- Valerie Larsson-Lohr
- Representing Baromedical Nurses Association
- San Antonio, TX
- David Montgomery, MD
- Co-chair, Seagram Science Sports Centre
- Faculty of Education
- McGill University
- Montreal, Quebec, Canada

- Richard Neubauer, MD
- Ocean Hyperbaric Center
- Lauderdale-by-the-Sea, Florida

- Nancy Pearson, PhD
- National Center for Complementary and Alternative Medicine
- Bethesda, Maryland

- Roger P. Simon, MD
- Robert Stone Dow Chair of Neurology
- Director, Dow Neurobiology Laboratories
- Legacy Health System
- Portland, Oregon

- Ann Tilton, MD
- Representing American Academy of Pediatrics
- Children's Hospital
- New Orleans, Louisiana

- Elmer Villanueva, MD, ScM
- Centre for Clinical Effectiveness
- Monash Medical Centre
- Clayton, Australia

- Tom Workman MS, CHT
- Director, Quality Assurance & Regulatory Affairs
- Undersea & Hyperbaric Medical Society
- San Antonio, Texas