# Appendix A. Indications for HBOT

Food and Drug Administration | | Undersea and Hyperbaric Medical Society | Centers for Medicare and Medicaid Services
1. | Air or gas embolism | Air or gas embolism | Gas embolism, (ICD-9-CM diagnosis 958.0, 999.1).
2. | Carbon monoxide poisoning and smoke inhalation | Carbon monoxide poisoning | Acute carbon monoxide intoxication, (ICD-9-CM diagnosis 986).
3. | Carbon monoxide poisoning complicated by cyanide poisoning | Carbon monoxide poisoning complicated by cyanide poisoning | Cyanide poisoning (ICD-9-CM diagnosis 987.7, 989.0).
4. | Clostridial myonecrosis | Gas gangrene | Gas gangrene, (ICD-9-CM diagnosis 0400).
5. | Crush injury | Crush injury | Crush injuries and suturing of severed limbs. (ICD-9-CM diagnosis 927.00-927.03, 927.09-927.11, 927.20-927.21, 927.8-927.9, 928.00- 928.01, 928.10-928.11, 928.20-928.21, 928.3, 928.8-928.9, 929.0, 929.9, 996.90-996.99.)
6. | Compartment syndrome, acute traumatic ischemias | Compartment syndrome and other acute traumatic ischemias | Acute traumatic peripheral ischemia. (ICD-9-CM diagnosis 902.53, 903.1, 903.01 904.0, 904.41.)
7. | | | Acute peripheral arterial insufficiency, (ICD-9-CM diagnosis 444.21, 444.22, 444.81).
8. | Decompression sickness | Decompression sickness | Decompression illness, (ICD-9-CM diagnosis 993.2, 993.3).
9. | Enhancement of healing in selected problem wounds | Enhancement of healing in selected problem wounds
10. | Exceptional blood loss | Exceptional blood loss (anemia)
11. | Necrotizing soft tissue infections | Necrotizing soft tissue infections | Progressive necrotizing infections (necrotizing fasciitis), (ICD-9-CM diagnosis 7278.86).
12. | Osteomyelitis (refractory) | Refractory osteomyelitis | Chronic refractory osteomyelitis (ICD-9-CM diagnosis 730.10–730.19).
13. | Radiation tissue damage | Delayed radiation injury (soft tissue and bony necrosis) | Osteoradionecrosis (ICD-9-CM diagnosis 526.89).
14. | | | Soft tissue radionecrosis (ICD-9-CM diagnosis 990).
15. | Skin grafts & flaps (compromised) | Skin grafts & flaps (compromised) | Treatment of compromised skin grafts, (ICD-9-CM diagnosis 996.52; excludes artificial skin).
16. | Thermal burns | Thermal burns
17. | Adjunctive hyperbaric oxygen in intracranial abscess | Intracranial abscess
18. | | Actinomycosis | Actinomycosis(ICD-9-CM diagnosis 039.0-039.4, 039.8, 039.9).