# Appendixes

Appendix A. Indications for HBOT

Appendix B. Research Team, Technical Expert Advisory Group, and Peer Reviewers

Appendix C. Literature Search Strategies

Appendix D. Quality Assessment Criteria

Appendix E. Excluded Studies

Appendix F. Studies with Intermediate Outcomes

Appendix G. Unretrieved Studies

Appendix H. Outcome measures used in HBOT studies