# Acronyms and Abbreviations

~ | Data not provided
* | Level representing microalbuminuria
ACR | Albumin to creatinine ratio
CAD | Coronary artery disease
CHF | Congestive heart failure
DCCT | Diabetes Control and Complications Trial
DM | Diabetes mellitus
ETDRS | Early Treatment of Diabetic Retinopathy Scale
ESRD | End-stage renal disease
F/U | Follow up
GFR | Glomerular filtration rate
GHB | Total glycosylated hemoglobin
IMT | Intimal-medial thickness
IR | Incidence rate
n | Number of participants enrolled in for a given level of urinary albumin excretion
NGSP | National Glycohemoglobin Standardization Program
OR | Odds ratio
PAD | Peripheral arterial disease
RCT | Randomized controlled trial
RH | Relative hazard
ROR | Relative odds reduction
RR | Relative risk
RRR | Relative risk reduction
SD | Standard deviation
SEM | Standard error of the mean
SMBG | Self monitoring blood glucose
UAC | Urine albumin concentration
UAE | Urinary albumin excretion

Abbreviations for urine albumin excretion (UAE)

Albumin excretion rate (AER)

mg/min=milligrams albumin excreted per minute

mg/24hrs=milligrams urinary albumin excreted per 24 hours

Urine albumin concentration (UAC)

mg/ml=milligrams albumin per milliliter urine

mg/l= milligrams albumin per liter urine

Albumin to creatinine ratio (ACR)

mg/g=milligrams urinary albumin excreted per gram urinary creatinine excreted

mg/mmol=milligrams urinary albumin excreted per millimol urinary creatinine excreted

mg/mol=milligrams urinary albumin excreted per mol urinary creatinine excreted

g/mol=grams urinary albumin excreted per mol urinary creatinine excreted