# Evidence Tables

Table 1. Study Population, Design, Location, Recruitment, Outcomes, Quality

Reference | Type of DM | Design | Location | Number of Sites | Recruitment | Outcomes | | | | Quality Score
| | | | | | Retinopathy | Nephropathy | CVD/Stroke/PVD/CHF (Fatal or non fatal) | Neuropathy
Olson et al., 2002 [7] | 1 | Cohort | NA | Single city | Hospital based clinic | | | X | | 61.5
White et al., 2002 [19] | 1 | CC | NA | One country | Previous or concurrent clinical trial | X | | | | 62.9
Scott et al., 2001 [25] | 1 | Cohort | NA | Single city | Hospital based specialty clinic | | X | | | 53.7
Chaturvedi et al., 2001a [84] | 1 | Cohort | Europe | Multi-country | Outpatient specialty clinic | | X | | | 63.4
Chaturvedi et al., 2001b [140] | 1 | Cohort | Europe | Multi-country | Outpatient specialty clinic | X | | | | 48.5
Hovind et al., 2001 [154] | 1 | Cohort | Europe | Single city | Outpatient specialty clinic | | X | | | 42.4
Muhlhauser et al., 2000a [178] | 1 | Cohort | Europe | One country | Hospital based specialty clinic | X | X | X | | 65.8
Makimattila et al., 2000 [184] | 1 | Cohort | Europe | Single City | NOS | | | | X | 33.6
Muhlhauser et al., 2000b [185] | 1 | Cohort | Europe | One Country | Hospital based specialty clinic | X | X | X | | 33.4
Stella et al., 2000 [224] | 1 | Cohort | NA | Single City | All childhood onset IDDM cases seen at Children's Hospital of Pittsburgh | | | | X | 51.4
Nosadini et al., 2000 [245] | 2 | Cohort | Europe | One Country | NOS | | X | | | 61.0
Shichiri et al., 2000 [247] | 2 | RCT | Asia | Single City | Outpatient clinic, NOS | X | X | | | 64.1
Sawicki et al., 2000 [289] | 1 | Cohort | Europe | One Country | Clinic/Hospital based specialty clinic | | X | | | 43.2
DCCT, 2000 [292] | 1 | CC | NA | One Country | Previous or concurrent clinical trial | X | X | | | 47.3
Warram et al, 2000 [304] | 1 | Cohort | NA | Single City | Outpatient specialty clinic | | X | | | 61.8
The Microalbuminuria Collaborative Study Group, 1999 [310] | 1 | Cohort | Europe | Single City | Hospital based specialty clinic | | X | | | 64.5
Oue et al., 1999 [315] | 2 | Cohort | Asia | Single City | Outpatient specialty clinic | | X | | | 45.3
Villar et al., 1999 [325] | 1 and 2 | Cohort | Europe | One Country | Outpatient specialty clinic | | X | | | 55.0
Klein et al., 1999 [387] | 1 | Cohort | NA | Single City | General population | | X | | | 70.3
Lehto et al., 1999 [397] | 1 | CC | NA | One Country | Previous or concurrent clinical trial | | | X | | 69.4
Gaede et al., 1999 [416] | 1 | RCT | Europe | Single City | Outpatient specialty clinic | X | | | X | 71.4
Molyneaux et al., 1998 [424] | 2 | Cohort | New Zealand | Single City | Hospital based specialty clinic | X | X | | | 36.7
Niskanen et al., 1998 [457] | 2 | Cohort | Europe | One Country | General population | | | X | | 70.8
Bojestig et al., 1998 [460] | 1 | Cohort | Europe | Single City | Hospital based clinic, NOS | X | X | | | 27.3
Florkowski et al., 1998a [481] | 2 | Cohort | New Zealand | Single City | Outpatient specialty clinic | X | | | | 53.0
Jones et al., 1998 [482] | 1 | Cohort | Europe | Single City | Hospital based specialty clinic | | X | | | 48.8
Yokoyama et al., 1998 [503] | 2 | Cohort | Asia | Single City | Outpatient specialty clinic | | X | | | 70.8
Florkowski et al., 1998b [519] | 2 | Cohort | New Zealand | Single City | Outpatient specialty clinic | | | X | | 73.3
Ravid et al., 1998 [531] | 2 | Cohort | Israel | NOS | NOS | | X | | | 64.5
Park et al., 1998 [534] | 2 | Cohort | Asia | Single City | Hospital based specialty clinic | | X | | | 61.5
Mulec et al., 1998 [540] | 1 | Cohort | Europe | One Country | Hospital based clinic, NOS | | X | | | 67.5
Guillausseau et al., 1998 [556] | 2 | Cohort | Europe | Single City | Hospital based specialty clinic | X | | | | 70.8
Earle et al., 1997 [566] | 1 | Cohort | Europe | Single City | Outpatient specialty clinic | | X | | | 42.8
d'Annunzio et al., 1997 [587] | 1 | Cohort | Europe | Single City | Outpatient general clinic | X | | | | 74.2
Yokoyama et al., 1997 [653] | 2 | Cohort | Asia | Single City | Outpatient specialty clinic | | X | | | 47.2
Gall et al., 1997 [654] | 2 | Cohort | Europe | Single City | Hospital based clinic, NOS | | X | | | 69.7
Alaveras et al., 1997 [681] | 1 | Cohort | Europe | Single City | Hospital based specialty clinic | | X | | | 52.3
Reichard et al., 1996 [699] | 1 | CC | Europe | NOS | Previous or concurrent clinical trial | | X | | | 68.3
DCCT., 1996 [718] | 1 | CC | NA | Multi-country | Outpatient clinic, NOS | X | X | | X | 75.5
Niskanen et al., 1996 [749] | 2 | Cohort | Europe | Single City | Outpatient general clinic | | X | | | 48.3
Lloyd et al., 1996 [777] | 1 | Cohort | NA | Single City | Hospital based clinic, NOS | X | X | X | X | 35.1
Klein et al., 1996 [809] | 1 and 2 | CC | NA | One Country | General population | X | X | | X | 66.2
Gall et al., 1995 [827] | 2 | Cohort | Europe | Single City | Hospital based Clinic, NOS | | | X | | 79.2
Klein et al., 1995a [853] | 1 and 2 | Cohort | NA | One Country | Outpatient General Clinic | | X | | | 37.5
Lloyd et al., 1995 [870] | 1 | Cohort | NA | Single City | Hospital based clinic, NOS | X | | | | 70.4
Izumi et al., 1995 [871] | 1 | Cohort | Asia | Single City | Diabetes summer camp | | X | | | 8.6
Ohkubo et al., 1995 [888] | 2 | RCT | Asia | Single City | Outpatient clinic NOS | X | X | | | 72.7
Reichard et al., [921] | 1 | RCT | Europe | Single City | Outpatient clinic, NOS | | | | X | 28.1
Powrie et al., 1994 [929] | 1 | Cohort | Europe | Single City | Hospital based specialty clinic | | X | | | 53.7
Danne et al., 1994 [934] | 1 | Cohort | Europe | Single City | Hospital based specialty Clinic | X | | | | 23.8
Rudberg et al., 1993 [1023] | 1 | Cohort | Europe | Single City | Hospital based clinic, NOS | | X | | | 35.3
Reichard et al., 1993 [1069] | 1 | RCT | Europe | Single City | NOS | X | X | | | 55.3
Klein et al., 1993 [1103] | 2 | CC | NA | Single City | Previous or concurrent clinical trial | | X | | | 59.2
Haneda et al., 1992 [1172] | 2 | Cohort | Asia | Single City | Hospital based clinic, NOS | | X | | | 24.1
Reichard et al., 1992 [1188] | 1 | CC | Europe | Single City | Previous or concurrent clinical trial | X | X | | X | 37.8
Rudberg et al., 1992 [1204] | 1 | Cohort | Europe | Single City | Hospital based clinic, NOS | | X | | | 36.9
Reichard et al., 1991 [1266] | 1 | RCT | Europe | NOS | NOS | X | X | | X | 38.7
Chase et al., 1989 [1444] | 1 | Cohort | NA | NOS | Outpatient Specialy Clinic | X | X | | | 62.9
Porta et al., 2001 [1769] | 1 | Cohort | Europe | Multi-country | NOS | X | | | | 50.2
Zhang et al., 2001 [1833] | 1 | CC | NA/Europe | NOS | Previous or concurrent clinical trial, NOS | X | | | | 51.8
Stratton et al., 2001 [1863] | 2 | CC | Europe | One Country | Hospital based clinic, NOS | X | | | | 47.2
Yoshida et al., 2001 [1864] | 2 | Cohort | Asia | Single City | Outpatient specialty clinic | X | | | | 62.7
Voutilainen-Kaunisto et al., 2001 [1867] | 2 | Cohort | Europe | NOS | General population | X | | | | 45.2
Okudaira at al., 2000 [1899] | 2 | Cohort | Asia | Single City | Outpatient specialty clinic | X | | | | 77.7
Christen et al., 1999 [1999] | 1 | CC | NA | One Country | Previous or concurrent clinical trial | | | | X | 47.2
Dyck et al., 1999 [2022] | 2 | CC | NA | Single City | General population/Previous or concurrent clinical trial | | | | X | 51.6
Cohen et al., 1999 [2039] | 1 | CC | NA | Single City | Hospital based specialty clinic | X | | | | 43.4
Moss et al., 1999 [2047] | 1 and 2 | Cohort | NA | One Country | Outpatient general clinic | | | X | | 63.0
Klein et al., 1998 [2108] | 1 | Cohort | NA | One Country | Outpatient general clinic | X | | X | | 68.7
United Kingdom Prospective Diabetes Study (UKPDS) Group, 1998 [2113] | 2 | RCT | Europe | One Country | Outpatient general clinic | X | X | X | X | 80.5
Moss et al., 1998 [2145] | 1 | Cohort | NA | One Country | Outpatient general clinic | X | | | | 68.9
Arfken et al., 1998 [2157] | 1 | Cohort | NA | Single City | Outpatient general clinic/ Outpatient specialty clinic | X | | | | 64.2
Kim et al., 1998 [2171] | 2 | Cohort | Asia | Single City | Hospital based clinic, NOS | X | | | | 53.7
Tudor et al., 1998 [2173] | 2 | Cohort | NA | One Country | NOS | X | | | | 44.4
Nakagami et al., 1997 [2259] | 2 | Cohort | Asia | Single City | Hospital based specialty Clinic | X | | | | 39.1
Klein et al., 1997 [2270] | 1 | Cohort | NA | One Country | General population | X | | | | 45.7
Sands et al., 1997 [2275] | 2 | Cohort | NA | One Country | General population | | | | X | 48.4
Henricsson et al., 1997 [2281] | 2 | Cohort | Europe | Single City | Hospital based specialty clinic | X | | | | 32.9
Vitale et al., 1997 [2282] | 1 | Cohort | NA | One Country | Outpatient general clinic/Outpatient specialty clinic: General population | X | | | | 29.3
Moss et al., 1996 [2326] | 1 and 2 | Cohort | NA | One Country | Outpatient general clinic | | | X | | 46.2
Lehto et al., 1996a [2330] | 2 | Cohort | Europe | One Country | General population/diabetic register | | | X | | 66.5
Kovacs et al., 1995 [2372] | 1 | Cohort | NA | Single City | Diabetes Endocrinology inpatient service | X | | | | 49.8
Bonney et al., 1995 [2379] | 1 | Cohort | New Zealand | One Country | Diabetes complications assessment service | X | | | | 54.0
Yokoyama et al., 1995 [2386] | 1 | Cohort | Asia | Single City | Hospital based specialty Clinic | X | X | | | 66.4
Vitale et al., 1995 [2391] | 1 | Cohort | NA | Single City | Outpatient general clinic/Outpatient specialty clinic/ Summer camp for children with diabetes, Outpatient pediatric clinic | X | | | | 36.2
Chen et al., 1995 [2392] | 2 | Cohort | Asia | One Country | Outpatient general clinic | X | | | | 58.3
Klein et al., 1995b [2437] | 1 and 2 | Cohort | NA | Single City | Outpatient clinic, NOS | X | | | | 42.2
DCCT, 1995 [2438] | 1 | RCT | NA | One Country | NOS | X | | | | 65.9
Klein et al., 1994 [2458] | 1 and 2 | Cohort | NA | One Country | Outpatient general clinic | X | | | | 49.0
Moss et al., 1994a [2482] | 1 and 2 | CC | NA | Single City | Previous or concurrent clinical trial | X | | | | 52.8
Morisaki et al, 1994 [2502] | 2 | Cohort | Asia | Single City | Hospital based clinic, NOS | X | | | | 77.9
Araki et al, 1993 [2535] | 2 | Cohort | Asia | Single City | Hospital based specialty clinic | X | | | | 63.5
Marshal et al, 1993 [2537] | 1 | Cohort | NA | Single City | Hospital based specialty clinic | X | | | | 76.7
Moss et al, 1992 [2636] | 1 and 2 | CC | NA | Single City | Previous or concurrent clinical trial | | | X | | 47.8
Klein et al, 1991 [2691] | 1 | Cohort | NA | Single City | Outpatient general clinic | | X | | | 56.2
Klein et al, 1989 [2787] | 1 and 2 | Cohort | NA | Single City | Outpatient general clinic/ Wisconsin Health Service Area 1 | X | | | | 48.5
Janka et al, 1989 [2809] | 1 | CC | NA | Single City | Hospital based specialty clinic | X | | | | 61.7
Klein et al, 1988 [2832] | 1 and 2 | Cohort | NA | One Country | Previous or concurrent clinical trial | X | | | | 50.5
Waltman et al, 1984 [3029] | 1 | Cohort | NA | Single City | Outpatient general clinic | X | | | | 57.3
Toyry et al., 1996 [3527] | 2 | CC | Europe | Single City | General population/Referred by GPs in community Health Center | | | X | | 39.5
Nichols et al., 2001 [4025] | 2 | Cohort | NA | One Country | Kaiser Permanente Northwest Division Diabetes Registry | | | X | | 52.2
Yamasaki et al., 2000 [4081] | 2 | Cohort | Asia | One Country | Hospital based clinic, NOS | | | X | | 52.4
Stratton et al., 2000 [4087] | 2 | CC | Europe | Multi-country | Previous or concurrent clinical trial | X | | X | | 51.9
Adler et al., 1999 [4124] | 2 | CC | Europe | Multi-country | Previous or concurrent clinical trial | | | X | | 57.5
Epidemiology of Diabetes Intervention and Complications (EDIC) Research Group, 1999 [4147] | 1 | CC | NA | One Country | Previous or concurrent clinical trial | | | X | | 62.4
Turner et al, 1998 [4217] | 2 | CC | Europe | Multi-country | Previous or concurrent clinical trial | | | X | | 61.0
Lehto et al., 1997 [4240] | 2 | Cohort | Europe | One Country | Diabetes patient registry | | | X | | 70.9
Standl et al., 1996 [4276] | 2 | CC | Europe | One Country | Outpatient general clinic | | | X | | 63.4
Lehto et al., 1996b [4313] | 2 | CC | Europe | One Country | General population | | | X | | 43.9
Moss et al, 1994b [4338] | 1 and 2 | CC | NA | One Country | Trial | | | X | | 44.7
Fu et al., 1993 [4403] | 2 | Cohort | Asia | One Country | Community Health Centers | | | X | | 39.2
DCCT, 1993 [4638] | 1 | RCT | NA | Single City | Outpatient clinic, NOS | X | X | | X | 83.3

CC=Cohort study from a previous clinical trial; RCT = Randomized Controlled Trial; NA = North America

Table 2. Baseline Data for All Study Participants; Cohort Studies

Reference and Study Group | Total N | Age, Y | Gender | | Race/Ethnicity n (%) | Diabetes Duration (Y) | Smoking n (%) | BMI* (kg/m^2^) | FG* | Prior CVD* n (%)
| | | M n (%) | F n (%)
Olson et al., 2002 [7] | 586
No LEAD | 516 | Mean: 26.5 | 51.9% | 48.1% | ~ | Mean: 18.1 | Hx: 34.1% | ~ | ~ | CHD: 3.1%
| | SD: 7.6 | | | | SD: 7.2
LEAD | 70 | Mean: 31.3 | 47.1% | 52.9% | ~ | Mean: 23.4 | Hx: 48.6% | ~ | ~ | CHD: 4.3%
| | SD: 7.1 | | | | SD: 7.1
White et al., 2002 [19] | 170
“Standard” | 89 | Mean: 26.3 | 40% | 60% | ~ | Mean: 16.3 | ~ | ~ | ~ | ~
| | SD: 2.2 | | | | SD: 4.3§
“Intensive” | 81 | Mean: 27.2 | 52% | 48% | ~ | Mean: 17.4 | ~ | ~ | ~ | ~
| | SD: 2.4 | | | | SD: 4.2§
Scott et al., 2001 [25] | 943 | Mean: 28.7 | 46% | 54% | W: 94 | Mean: 13 | Past: 142 | ~ | ~ | ~
| | SD: 0.8 | | | | SD: 8 | Current: 197
| | | | | | | Never: 384
Chaturvedi et al., 2001a [84] | 1134
Progressors | 143 | Mean: 33 | ~ | ~ | ~ | Mean: 14 | Current: 31% | Mean: 24.1 | ~ | Hx CVD: 8%
| | SD: 10 | | | | SD: 10 | | SD: 2.7
Non-Progressors | 972 | Mean: 32 | ~ | ~ | ~ | Mean: 13 | Current: 27% | Mean: 23.4 | ~ | Hx CVD: 7%
| | SD: 10 | | | | SD: 10 | | SD: 2.8
Chaturvedi et al., 2001b [140] | 764
Retinopathy | 429 | Mean: 29 | ~ | ~ | ~ | Mean: 11 | Hx: 32% | ~ | ~ | CVD Hx: 5%
| | SD: 0.5 | | | | SD: 0.3
No retinopathy | 335 | Mean: 30 | ~ | ~ | ~ | Mean: 9 | Hx: 27% | ~ | ~ | CVD Hx: 6%
| | SD: 0.4 | | | | SD: 0.4
Hovind et al., 2001 [154] | 301 | Mean: 36 | 192 | 109 | ~ | Mean: 22 | Hx: 164 | ~ | ~ | ~
| | SD: 11 | | | | SD: 8
Muhlhauser et al., 2000a [178] | 3570 | Mean: 27.5 | 49.8% | 50.2% | ~ | Mean: 10.5 | Hx: 43% | Mean: 22.6 | ~ | CVD Hx: 3.4%
| | SD: 9.5 | | | | SD: 9.5 | | SD: 0.3
Makimattila et al., 2000 [184] | 83 | Mean: 22 | 43 | 40 | ~ | Mean: 11 | ~ | Mean: 22.2 | ~ | ~
| | SD: 1 | | | | SD: 1 | | SD: 0.3
Muhlhauser et al., 2000b [185] | 3674
Normal protein | 1829 | Mean: 26.1 | 52.3% | 47.7% | ~ | Mean: 8.4 | Hx: 41.5% | Mean: 22.4 | ~ | ~
| | SD: 8.7 | | | | SD: 8.3 | | SD: 3
Micro protein | 1257 | Mean: 28.2 | 44.8% | 55.2% | ~ | Mean: 11.4 | Hx: 42.2% | Mean: 22.8 | ~ | ~
| | SD: 10 | | | | SD: 9.9 | | SD: 3.2
Macro protein | 367 | Mean: 33.5 | 55.3% | 44.7% | ~ | Mean: 19.7 | Hx: 48.9% | Mean: 23.3 | ~ | ~
| | SD: 9.7 | | | | SD: 8.5 | | SD: 3.3
Stella et al., 2000 [224] | 373 | Mean: 28.7 | | | | Mean: 20.2
Incident cases | 104 | Mean: 33.3 | 56.9% | 43.1% | ~ | Mean: 23.8 | Hx: 28.1% | ~ | ~ | ~
| | SD: 7.5 | | | | SD: 8.2
Non-cases | 269 | Mean: 26.8 | 47.6% | 52.4% | ~ | Mean: 18.7 | Hx: 36.0% | ~ | ~ | ~
| | SD: 7.2 | | | | SD: 6.5
Nosadini et al., 2000 [245] | 108 | | 60 | 48
Micro Progressors | 37 | Mean: 58 | 20 | 17 | W: 37 | Mean: 12 | ~ | Mean: 28.8 | ~ | ~
| | SD 6 | | | | SD: 6 | | SD: 9
Micro Non Progressors | 37 | Mean: 58 | 19 | 18 | W: 37 | Mean: 10 | ~ | Mean: 27.9 | ~ | ~
| | SD: 7 | | | | SD: 7 | | SD: 4.0
Protein Progressors | 17 | Mean: 58 | 11 | 6 | W: 17 | Mean: 15 | ~ | Mean: 28.6 | ~ | ~
| | SD: 8 | | | | SD: 5 | | SD: 4
Protein Non Progressors | 17 | Mean: 52 | 10 | 7 | W: 17 | Mean: 12 | ~ | Mean: 30.0 | ~ | ~
| | SD: 7 | | | | SD: 7 | | SD: 3.3
Sawicki et al., 2000 [289] | 601 | Mean: 26.4 | 318 | 283 | ~ | Mean: 8.4 | Hx: 54% | ~ | ~ | ~
| | SD: 6.8 | | | | SD: 7.4
DCCT, 2000 [292] | 1177
“Standard” | 603 | Mean: 33 | 53% | 47% | ~ | Mean: 11.7 | ~ | ~ | ~ | ~
| | SD: 7 | | | | SD: 4.8
“Intensive” | 605 | Mean: 34 | 52% | 48% | ~ | Mean: 12.1 | ~ | ~ | ~ | ~
| | SD: 7 | | | | SD: 4.9
Warram et al, 2000 [304 ] | 279 | | | | W: (92%)
Quartile 1 | 85 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
Quartile 2 | 57 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
Quartile 3 | 64 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
Quartile 4 | 68 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
Progressors | | Mean: 30 | 58% | 42% | ~ | Mean: 17 | ~ | ~ | ~ | ~
| | SD: 6 | | | | SD: 8
Non Progressors | | Mean: 30 | 48% | 52% | ~ | Mean: 18 | ~ | ~ | ~ | ~
| | SD: 8 | | | | SD: 9
The Microalbuminuria Collaborative Study Group, 1999 [310] | 148 | | | | | | Hx: 20%
Persistent normoalbuminuria | 109 | Mean: 29 | 63 | 46 | ~ | Mean: 12 | Hx: 12% | Mean: 24.5 95% | ~ | ~
| | Range: 17–58 | | | | IQR: 1–33 | | CI: 23.8 –25.1
Persistent microalbuminuria | 25 | Mean: 29 | 10 | 15 | ~ | Mean: 14 | Hx: 16% | Mean: 26 95% | ~ | ~
| | Range: 17–55 | | | | IQR: 1–33 | | CI: 24.6 – 27.4
Persistent macroalbuminuria | 14 | Mean: 31 | 6 | 8 | ~ | Mean: 18 | Hx: 21% | Mean: 26 95% | ~ | ~
| | Range: 22–56 | | | | IQR: 1–29 | | CI: 23.7 –27.4
Oue et al., 1999 [315] | 67 | | | | Japanese: 67
Progressors | 27 | Mean: 61 | 15 | 12 | | Mean: 11 | Hx: 30% | Mean: 22.7 | ~ | ~
| | SD: 12 | | | | SD: 8 | | SD: 9.6
Non Progressors | 40 | Mean: 51 | 20 | 20 | | Mean: 11 | Hx: 15% | Mean: 22.7 | ~ | ~
| | SD: 10 | | | | SD: 5 | | SD: 2.4
Villar et al., 1999 [325] | 598
Type I | 340 | Mean: 35 | 55.6% | 44.4% | ~ | Mean: 19 | Hx: 30.3% | Mean: 24.6 | ~ | Hx CVD: 7 (2.1%)
| | SD: 13 | | | | SD: 8 | | SD: 3
Type II | 258 | Mean: 60 | 54.7% | 45.3% | ~ | Mean: 14 | Hx: 17.1% | Mean: 26.7 | ~ | Hx CVD: 41 (15.9%)
| | SD: 9 | | | | SD: 8 | | SD: 4.1
Klein et al., 1999 [387] | 529 | Mean: 31.3 | 49% | 51% | W: 98.9% | Mean: 17.1 | Hx: 18% | Mean: 24.7 | ~ | ~
| | | | | | | Current: 22%
Lehto et al., 1999 [397] | 177 | | 87 | 90
Men no CHD | 70 | Mean: 53.5 | 100% | 0% | ~ | Mean: 13.8 | Hx: 25.7% | Mean: 25.1 | ~ | ~
| | SE: 0.5 | | | | SE: 1 | | SE: 0.4
Men with CHD | 17 | Mean: 58.6 | 100% | 0% | ~ | Mean: 15.7 | Hx: 35.3% | Mean: 24.4 | ~ | ~
| | SE: 1.4 | | | | SE: 0.6 | | SE: 0.8
Women no CHD | 79 | Mean: 56.2 | 0% | 100% | ~ | Mean: 13 | Hx: 11.4% | Mean: 25.5 | ~ | ~
| | SE: 0.6 | | | | 0.8 | | SE: 0.5
Women with CHD | 11 | Mean: 56.4 | 0% | 100% | ~ | Mean: 22.4 | Hx: 9.1% | Mean: 26.1 | ~ | ~
| | SE: 1.8 | | | | SE: 2 | | SE: 1.4
Molyneaux et al., 1998 [424] | 963 | Mean; 54.9 | ~ | ~ | ~ | Mean: 3.8 | ~ | ~ | ~ | ~
| | IQR: 50–64.9 | | | | IQR: 0.8 – 8.3
Niskanen et al., 1998 [457] | 133 | Mean: 55.7 | 53% | 47% | ~ | ~ | ~ | Mean: 30.4 | Mean: 10.7 | Hx CHD: 67 (50.3%)
| | SE: 0.8 | | | | | | SE: 0.5 | SE: 0.3 | Hx CHD: 67 (50.3%)
Bojestig et al., 1998 [460] | 180 | Mean: 8.5 | 45.5% | 54.5%
Good glycemic control | 81 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
Poor glycemic control | 66 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
Very poor glycemic control | 33 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
Florkowski et al., 1998a [481] | 233 | Mean: 60.3 | ~ | ~ | W: 96% | Mean: 8.8 | Hx: 15.8% | Mean: 28.9 | Mean: 11.9 | Hx CHD: 18.2%
| | SD: 10.1 | | | | SD: 7 | | SD: 5.3 | SD: 5.3
Jones et al., 1998 [482] | 233 | ~ | 114 | 119 | ~ | Median: 3.9 | ~ | ~ | ~ | ~
| | | | | | IQR: 1.8–6.7
Raised ACR | 34 | ~ | 9 | 25 | ~ | Median: 7.2 | ~ | ~ | ~ | ~
| | | | | | IQR: 4.1–10
Intermittent ACR | 27 | ~ | 9 | 18 | ~ | Median: 3.8 | ~ | ~ | ~ | ~
| | | | | | IQR: 1.6–8.5
Normal ACR | 172 | ~ | 96 | 76 | ~ | Median: 3.3 | ~ | ~ | ~ | ~
| | | | | | IQR: 1.8– 6.7
Yokoyama et al., 1998 [503] | 426 | Mean: 27 | 55% | 45% | Japanese: 100% | Mean: 4.4 | Hx: 31% | Mean: 23.2 | ~ | ~
| | SD: 8.2 | | | | SD: 6 | | SD: 5.1
Florkowski et al., 1998b [519] | 447 | Mean: 62 | 208 | 239 | “European”: 95%
| | IQR: 30–82
Dead | 133 | Mean: 67.1 | 49% | 51% | | Mean: 11.9 | Hx: 17% | Mean: 27.3 | Mean: 13.2 | Hx CVD: 41%
| | SD: 8.1 | | | | SD: 7.8 | | SD: 4.5 | SD: 8.2
Alive | 289 | Mean: 60.3 | 45% | 55% | | Mean: 8.8 | Hx: 14% | Mean: 28.9 | Mean: 11.9 | Hx CVD: 16%
| | SD: 10.1 | | | | SD: 7 | | SD: 5.3 | SD: 4.7
Ravid et al., 1998 [531] | 574 | Mean: 47.7 | 289 | 285 | ~ | Mean: 1.92 | Hx: 205 | Mean: 24.9 | ~ | ~
| | SD: 4.5 | | | | SD: 1.2 | | SD: 3.4
Park et al., 1998 [534] | 146
Progressors | 37 | Mean: 65 | 16 | 21 | W: 100% | Mean: 16.7 | ~ | Mean: 25.2 | Mean:10.5 | ~
| | SD: 11 | | | | SD: 7.9 | | SD: 3.5 | SD: 3.9
Non Progressors | 109 | Mean: 59 | 51 | 58 | | Mean: 11.1 | ~ | Mean: 24.5 | Mean: 10.2 | ~
| | SD: 10 | | | | SD: 5.7 | | SD: 3.2 | SD: 2.8
Mulec et al., 1998 [540] | 158 | Mean: 35.5 | 104 | 59 | ~ | Mean: 21.8 | Hx: 63% | Mean: 23.3 | | ~
| | SD: 9 | | | | SD: 8 | | SD: 3.2
Guillausseau et al., 1998 [556] | 64 | Mean: 54.5 | 35 | 29 | ~ | Mean: 7.5 | Hx: 20% | Mean: 26.2 | Mean: 9 | ~
| | SD: 9.1 | | | | SD: 6.9 | | SD: 4 | SD: 2.3
| | IQR: 31–79 | | | | IQR: 0–24 | | IQR: 16–38 | IQR: 5.2–17.2
Earle et al., 1997 [566] | 44
With hypertension | 36 | Mean: 39 | 25 | 21 | ~ | Mean: 18.8 | ~ | ~ | ~ | ~
| | SD: 2.4 | | | | SD: 5.7
Without hypertension | 8 | Mean: 31 | 3 | 5 | ~ | Mean: 15.6 | ~ | ~ | ~ | ~
| | SD: 2.3 | | | | SD: 3.7
d'Annunzio et al., 1997 [587] | 100 | Mean: 8.3 | 53 | 47 | ~ | ~ | ~ | ~ | ~ | ~
| | SD: 3.5
| | IQR: 1.2–16.4
Yokoyama et al., 1997 [653] | 182 | Mean: 57 | 124 | 58 | ~ | ~ | Hx: 67% | Mean: 22.5 | ~ | Hx CHD: 71
| | SD: 11 | | | | | | SD: 3.3
Gell et al., 1997 [654] | 176 | | 99 | 77 | W: 100% | ~ | Hx: 128 | | ~ | Hx CHD: 26
Normoalbuminuria | 135 | Median: 54 | 52 | 48 | | Median: 5 | Hx: 95 | Mean: 27.9 | ~ | Hx CHD: 15
| | IQR: 20–65 | | | | IQR: 1–34 | | SD: 5.3
Nephropathy | 41 | Median: 56 | 71 | 29 | | Median: 6 | Hx: 33 | Mean: 27.3 | ~ | Hx CHD: 11
| | IQR: 39–65 | | | | IQR: 1–18 | | SD: 4
Alaveras et al., 1997 [681] | 58 | ~ | 37 | 21 | AA: 3 | Mean: 13 | ~ | ~ | ~ | ~
| | | | | W: 55 | IQR: 14–51
Reichard et al., 1996 [699] | 91 | Mean: 31 | ~ | ~ | ~ | Mean: 17 | Hx: 28 | ~ | ~ | ~
| | SD: 7 | | | | SD: 6
“Standard” | 43 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
“Intensive” | 48 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
DCCT, 1996 [718] | 1273 | Mean: 26 | 54% | 46% | W: 96% | Mean: 2.6 | Current: 17% | ~ | ~ | ~
| | SD: 8 | | | | SD: 1.4
“1° Standard” | 378 | Mean: 27 | 49% | 51% | W: 96% | Mean: 2.6 | Current: 19% | ~ | ~ | ~
| | SD: 7 | | | | SD: 1.4
“1° Intensive” | 348 | Mean: 27 | 54% | 46% | W: 97% | Mean: 8.6 | Current: 19% | ~ | ~ | ~
| | SD: 7 | | | | SD: 3.7
“2° Standard” | 352 | Mean: 27 | 53% | 47% | W: 97% | Mean: 8.9 | Current: 19% | ~ | ~ | ~
| | SD: 7 | | | | SD: 3.8
“2° Intensive” | 363 | Mean: 26 | 54% | 46% | W: 96% | Mean: 2.6 | Current: 17% | ~ | ~ | ~
| | SD: 8 | | | | SD: 1.4
Niskanen et al., 1996 [749] | 133 | Mean: 56 | 70 | 63 | ~ | ~ | Hx: 62 | Mean: 30.4 | Mean: 10.7 | Hx CHD: 24
| | | | | | | | SD: 0.5 | SD: 0.3
Lloyd et al., 1996 [777] | 658 | ~ | | | ~ | ~ | ~ | ~ | ~ | ~
Fair Control | 438 | Mean: 27.9 | 50% | 50% | ~ | Mean: 19.6 | ~ | ~ | ~ | ~
| | SD: 7.7 | | | | SD: 7.5
Poor Control | 220 | Mean: 27.1 | 50% | 50% | ~ | Mean: 18.9 | ~ | ~ | ~ | ~
| | SD: 8.3 | | | | SD: 7.5
Klein et al., 1996 [809] | 1298
Young onset using insulin | 765 | Mean: 29.3 | ~ | ~ | ~ | Mean: 14.7 | ~ | ~ | ~ | ~
Older onset using insulin | 251 | Mean: 65.2 | ~ | ~ | ~ | Mean: 15 | ~ | ~ | ~ | ~
Older onset not using insulin | 282 | Mean: 68 | ~ | ~ | ~ | Mean: 8.8 | ~ | ~ | ~ | ~
Gall et al., 1995 [827] | 328 | | | | W: 328
Normoalbuminuria | 191 | Mean: 55 | 109 | 92 | W: 191 | Mean: 5 IQR: | Hx: 24% | Mean: 27.9 | ~ | Hx CHD: 16%
| | IQR: 20–65 | | | | 1–39 | | SD: 5
Microalbuminuria | 86 | Mean: 58 | 50 | 36 | W: 86 | Mean: 8 | Hx: 24 | Mean: 29.3 | ~ | Hx CHD: 20%
| | IQR: 28–65 | | | | IQR: 1–31 | | SD: 4.7
Macroalbuminuria | 51 | Mean: 56 | 43 | 8 | W: 51 | Mean: 8 | Hx: 34 | Mean: 30.6 | ~ | Hx CHD: 35%
| | IQR: 35–65 | | | | IQR: 1–25 | | SD: 5.3
Klein et al., 1995a [853] | 1460 | | 690 | 770
Young onset | 666 | ~ | 335 | 331 | ~ | ~ | ~ | ~ | ~ | ~
Older onset using insulin | 376 | ~ | 170 | 206 | ~ | ~ | ~ | ~ | ~ | ~
Older onset not using insulin | 418 | ~ | 185 | 206 | ~ | ~ | ~ | ~ | ~ | ~
Lloyd et al., 1995 [870] | 322 | Mean: 27.8 | 53% | 47% | ~ | Mean: 19.4 | ~ | ~ | ~ | Hx PVD: 9%
| | SD: 7.9 | | | | SD: 7.5 | | | | Hx CVD: 4%
Izumi et al., 1995 [871] | 107 | ~ | 43 | 64 | ~ | ~ | ~ | ~ | ~ | ~
Powrie et al., 1994 [929] | 97 | Mean: 31.3 | | | ~ | Mean: 16 | | Mean: 21.8 | ~ | ~
| | Range: 12–56 | | | | Range: 1–45 | | Range: 13–34.7
Normoalbuminuria | 89 | ~ | 55 | 34 | ~ | ~ | Hx: 31% | | ~ | ~
Microalbuminuria | 8 | ~ | 4 | 4 | ~ | ~ | Hx: 25% | | ~ | ~
Danne et al., 1994 [934] | 346 | Mean; 9 | 190 | 156 | ~ | ~ | ~ | ~ | ~ | ~
| | IQR: 1–18
Rudberg et al., 1993 [1023] | 156 | Mean: 14 | 67 | 89 | ~ | Mean: 6.9 | ~ | ~ | ~ | ~
| | SD: 3.9 | | | | SD: 3.9
Klein et al., 1993 [1103] | 987
Insulin | 376 | ~ | 170 | 206 | ~ | ~ | Hx: 123 | ~ | ~ | Hx CVD: 95
No insulin | 418 | ~ | 185 | 233 | ~ | ~ | Hx: 129 | ~ | ~ | Hx CVD: 74
Haneda et al., 1992 [1172] | 34 | | | | Asian: 100%
Remained Normoalbuminuria | 23 | Mean: 58.2 | 8 | 15 | | Mean: 9.7 | ~ | ~ | Mean: 149 | ~
| | SE: 2.5 | | | | SD: 1.5 | | | SE: 13
Developed Microalbuminuria | 11 | Mean: 56.2 | 7 | 4 | | Mean: 10.2 | ~ | ~ | Mean: 158 | ~
| | SE: 2.9 | | | | SD: 2.2 | | | SE: 11
Reichard et al., 1992 [1188] | 96 | Mean: 30.1 | 49 | 47 | ~ | Mean: 17 | ~ | ~ | ~ | ~
| | SD: 0.8 | | | | SD: 0.6
Rudberg et al., 1992 [1204] | 64 | Mean: 16.9 | 33 | 31 | ~ | Mean: 11.6 | ~ | ~ | ~ | ~
| | SD: 0.3 | | | | SD:0.3
| | IQR: 12–22 | | | | IQR: 8–17
Chase et al., 1989 [1444] | 230
Good Control | 69 | Mean: 18.4 | 40 | 29 | AA: 1 | Mean: 9.2 | ~ | ~ | ~ | ~
| | SE: 0.7 | | | W: 67 | SE: 0.5 | | SD: 5.3
| | | | | Asian 1
Intermediate Control | 79 | Mean: 17.8 | 35 | 44 | W: 74 | Mean: 10.1 | ~ | ~ | ~ | ~
| | SE: 0.3 | | | Other: 5 | SE: 0.4 | | SD: 5.3
Poor Control | 82 | Mean: 17.3 | 38 | 44 | AA: 6 | Mean: 10 | ~ | ~ | ~ | ~
| | SE: 0.3 | | | W: 69 | SE: 0.4
| | | | | Other: 7
Porta et al., 2001 [1769] | 1249 | Mean: 31 | | | | Mean: 13
Progressors | 157 | Mean: 32 | ~ | ~ | ~ | Mean: 17 | Hx: 35% | Mean: 23.5 | ~ | Hx CVD: 6%
| | SD: 0.8 | | | | SE: 0.6 | | SD: 0.23
Non-Progressors | 1092 | Mean: 31 | ~ | ~ | ~ | Mean: 13 | Hx: 30 | Mean: 23.5 | ~ | Hx CVD: 7%
| | SD: 0.3 | | | | SE: 0.2 | | SD: 0.09
Zhang et al., 2001 [1833] | 319 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
Stratton et al., 2001 [1863] | 1919
No retinopathy at baseline | ~ | Mean: 52.2 | 57% | 43% | AA: 70 | ~ | Hx: 432 | Mean: 27.7 | Mean: 7.8 | ~
| | SD: 8.5 | | | W: 1050 | | | SD: 5.2 | IQR: 6.5–9.6
| | | | | Other: 96
Retinopathy at baseline | ~ | Mean: 52.2 | 61.4% | 38.6% | AA: 49 | ~ | Hx: 246 | Mean: 27.4 | IQR: 6.7–10.6 | ~
| | SD: 8.6 | | | W:606 | SD: 3.9 | | SD: 4.9
| | | | | Other: 48
Yoshida et al., 2001 [1864] | 787 | Mean: 53.6 | 597 | 190 | ~ | Mean: 8 | | Mean: 22.6 | ~
| | SD: 8.1 | | | | SD: 6.8 | | SE: 3
| | Median: 54 | | | | Median: 6
| | IQR: 18–69 | | | | IQR: 0–38
Voutilainen-Kaunisto et al., 2001 [1867] | 85 | Mean: 9.7 | 70 | 63 | ~ | ~ | Hx: 62 | Mean: 30.4 | Mean: 12 | Hx CHD: 24
| | SD: 9.7 | | | | | | SD: 5.2 | SD: 4
Okudaira at al., 2000 [1899] | 394 | Mean: 26.9 | 54% | 46% | Asian | Mean: 4.4 | Hx: 30% | Mean: 23 | ~ | ~
| | SD: 8.2 | | | | SD: 6 | | SD: 5.1
Christen et al., 1999 [1999] | 407 | Mean: 31.4 | 306 | 101 | ~ | Mean: 6.5 | Hx: 23.1% | Mean; 24 | ~ | ~
| | SD: 7.4 | | | | SD: 3.5 | | SD: 3.4
Dyck et al., 1999 [2022] | 264 | ~ | 138 | 126 | ~ | Mean: 17.1 | ~
| | | | | | SD: 9
Type 1 | 97 | Mean: 52.1 | ~ | ~ | ~ | Mean: 20.8 | Current: 96 | Mean: 27.3 | Mean: 178.9 | ~
| | SD: 16.6 | | | | SD: 9.9 | Hx: 83 | SD: 5.1 | SD: 40.5
Type 2 | 149 | Mean: 69.7 | 55% | 45% | ~ | Mean: 14.8 | Current:147 | Mean: 30.7 | Mean: 177.7 | ~
| | SD: 9.7 | | | | SD: 7.7 | Hx: 124 | SD: 5.7 | SD: 42.2
Cohen et al., 1999 [2039] | 485 | Mean: 31.5 | 74% | 26% | ~ | Mean: 6.5 | Hx: 22.1% | Mean: 24 | ~ | ~
| | SD: 7.3 | | | | SD: 3.4 | | SD: 3.4
Moss et al., 1999 [2047] | 1890
Young onset | 906 | Mean: 27.9 | 50.4% | 49.6% | W: 99% | Mean: 13.5 | ~ | Mean: 23.4 | ~ | ~
| | SD: 12.2 | | | | SD: 9.6 | | SD: 4.2
Older onset | 984 | Mean: 64.4 | 43.6% | 56.4% | W: 98.5% | Mean: 10.9 | ~ | Mean: 29.2 | ~ | ~
| | SD: 11.1 | | | | SD: 7.8 | | SD: 5.7
Klein et al., 1998 [2108] | 634 | Mean: 26.8 | 49.2% | 50.8% | ~ | Mean: 12.6 | Hx: 15.5% | Mean: 23.3 | ~ | ~
| | SD: 11.2 | | | | SD: 9 | | SD: 4
Moss et al., 1998 [2145] | 634 | Mean: 26.8 | 49.2% | 50.8% | ~ | Mean: 12.6 | Hx: 15.5% | Mean: 23 | ~ | ~
| | SD: 11.2 | | | | SD: 9 | | SD: 4
Arfken et al., 1998 [2157] | 312
African American Subjects | 97 | Mean: 27 | 32% | 68% | AA: 100% | Mean: 9.2yrs | ~ | ~ | ~ | ~
| | SD: 15 | | | | SD: 7
Caucasian Subjects | 215 | Mean: 19 | 45% | 55% | W: 100% | Mean: 8yrs | ~ | ~ | ~ | ~
| | SD: 11 | | | | SD: 6.4
Kim et al., 1998 [2171] | 130 | | | | Asian: 100%
No retinopathy | 100 | Mean: 53 | ~ | ~ | | Mean: 7 | ~ | Mean: 25.2 | Mean: 10.1 | ~
| | SD: 11 | | | | SD: 5 | | SD: 3.4 | SD: 3.1 mmol/L
Incident retinopathy | 30 | Mean: 58 | ~ | ~ | | Mean: 11 | ~ | Mean: 25 | Mean: 10.1 | ~
| | SD: 8 | | | | SD: 5 | | SD: 2.6 | SD: 2.9mmol/L
Tudor et al., 1998 [2173] | 169
Non-Hispanic (White) Subjects | 53 | Mean: 58.7 | | 37.7% | W: 53 | Mean: 3.7 | Hx: 56.6% | Mean: 29.8 | ~ | ~
| | SD: 8.3 | | | | SD: 4.9 | | SD: 5.2
Hispanic Subjects | 116 | Mean: 56.7 | | 65.5% | Hispanic: 116 | Mean: 4.9 | Hx: 56.9% | Mean: 29.8 | ~ | ~
| | SD: 10.3 | | | | SD: 6.4 | | SD: 7.2
Nakagami et al., 1997 [2259] | 137 | Mean: 49.9 | 61 | 76 | Asian: 137 | Range: 0–3 | ~ | Mean: 23.5 | ~ | ~
| | SD: 8.3 | | | | | | SD: 7.2
Klein et al., 1997 [2270] | 354 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
Sands et al., 1997 [2275] | 231 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
Henricsson et al., 1997 [2281] | 1378 | ~ | | | W: 100%
Oral or Diet | 871 | ~ | 513 | 356 | | Mean: 5.3 | Hx: 29% | ~ | ~ | ~
| | | | | | SD: 5.2
Change to Insulin therapy | 174 | ~ | 99 | 75 | | Mean: 8.6 | Hx: 26% | ~ | ~
| | | | | | SD: 6.3
Insulin therapy | 333 | ~ | 168 | 166 | | Mean: 11.5 | Hx: 28% | ~ | ~ | ~
| | | | | | SD: 7.7
Vitale et al., 1997 [2282] | 175 | Median: 17 | 63% | 37% | ~ | Mean: 7 | ~ | ~ | ~ | ~
| | IQR: 4–43 | | | | IQR: 0–18
Moss et al., 1996 [2326] | 1835
Young onset | 879 | Mean: 28 | 50.3% | 49.7% | ~ | Mean: 13.6 | Hx: 115 | Mean: 23.4 | ~ | ~
| | SD: 12.3 | | | | SD: 9.6 | | SD: 4.2
Older onset | 956 | Mean: 64.5 | 44.2% | 55.8% | ~ | Mean: 11 | Hx: 286 | Mean: 29.2 | ~ | ~
| | SD: 11 | | | | SD: 7.9 | | SD: 5.8
Lehto et al., 1996a [2330] | 1044 | ~ | 571 | 473 | W: 100% | ~ | ~ | ~ | ~ | ~
Kovacs et al., 1995 [2372] | 66 | Mean: 11 | 34 | 32 | AA: 5 | ~ | ~ | ~ | ~ | ~
| | SD: 1.5 | | | W: 61
| | IQR: 8.3–13.6
Bonney et al., 1995 [2379] | 203
Level 10 | 120 | Median: 14.6 | 52 | 68 | W: 100% | Mean: 4.8 | ~ | ~ | ~ | ~
| | IQR: 12.8–16.1 | | | | IQR: 3.6–8.2
Level 21 | 57 | Median: 14 | 30 | 27 | | Mean: 7.5 | ~ | ~ | ~ | ~
| | IQR: 13–16 | | | | IQR: 5–9.9
Level 31 + 41 | 26 | Median: 15.2 | 11 | 15 | | Mean: 15.2 | ~ | ~ | ~ | ~
| | IQR: 12.9–17.2 | | | | IQR: 12.9–17.2
Yokoyama et al., 1995 [2386] | 324 | | | | Japanese: 100%
Level 1 | 47 | ~ | 46.8% | 53.2% | | ~ | ~ | ~ | ~ | ~
Level 2 | 154 | ~ | 40.8% | 59.2% | | ~ | ~ | ~ | ~ | ~
Level 3 | 123 | ~ | 40.7% | 59.3% | | ~ | ~ | ~ | ~ | ~
Vitale et al., 1995 [2391] | 189 | Mean: 14 | 64% | 36% | AA: 16% | | ~ | ~ | ~ | ~
| | IQR: 3–40
Chen et al., 1995 [2392] | 464 | | 191 | 273 | Other: 100% | Mean: 4.5 | Hx: 118
| | | | | | IQR: 0–10
No Retinopathy | 344 | Mean: 60.4 | 146 | 198 | ~ | Mean: 4.2 | | ~ | ~ | ~
| | SD: 9.5 | | | | SD: 4.8
Retinopathy | 120 | Mean: 63.1 | 45 | 75 | ~ | Mean: 9.1 | | ~ | ~ | ~
| | SD: 9.6 | | | | SD: 7.1
Klein et al., 1995b [2437] | 1461
Younger onset | 688 | ~ | ~ | 342 | 346 | ~ | Hx: 82 | ~ | ~ | Hx CVD: 14
Older onset | 773 | ~ | ~ | 366 | 407 | ~ | Hx: 121 | ~ | ~ | Hx CVD: 182
Klein et al., 1994 [2458] | 1516 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
Moss et al., 1994a [2482] | 1816 | | | | ~
Young onset | 880 | ~ | 443 | 437 | ~ | ~ | Hx: 116 | ~ | ~ | ~
Older onset using insulin | 442 | ~ | 217 | 225 | ~ | ~ | Hx: 154 | ~ | ~ | ~
Older onset not using insulin | 494 | ~ | 222 | 272 | ~ | ~ | Hx: 145 | ~ | ~ | ~
Morisaki et al, 1994 [2502] | 114 | Mean: 68.6 | 26% | 74% | Japanese: 100% | Mean: 5.7 | Current: 6% | Mean: 24 | ~ | Hx CHD: 23%
| | SD: 6 | | | | SD: 5.3 | | SD: 3 | | Hx CVD: 10%
| | | | | | | | | | Hx PVD: 4%
Araki et al, 1993 [2535] | 110 | Mean: 69.2 | 36 | 74 | ~ | Mean: 6.9 | ~ | Mean: 24 | Mean: 10 | ~
| | SD: 5.5 | | | | SD: 7.9 | | SD: 3.8 | SD: 42
Marshal et al, 1993 [2537] | 277 | Mean: 17.9 | 138 | 139 | ~ | Mean: 9.7 | Hx: 11% | ~ | ~ | ~
| | SD: 3.2 | | | | SD: 3.9
Moss et al, 1992 [2636] | 1878
Young onset | 891 | ~ | 442 | 437 | ~ | ~ | Hx: 115 | ~ | ~ | ~
Older onset | 987 | ~ | 423 | 533 | ~ | ~ | Hx: 286 | ~ | ~ | ~
Klein et al, 1991 [2691] | 661 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
Klein et al, 1989 [2787] | 1262
Young onset | 610 | ~ | | | ~ | ~ | Hx: 206 | ~ | ~ | Hx CHD: 9
Older onset | 652 | ~ | | | ~ | ~ | Hx: 306 | ~ | ~ | Hx CHD: 145
Janka et al, 1989 [2809] | 153 | | | | W: 153
Minimal progression | 79 | Mean: 41.8 | ~ | ~ | W: 79 | Mean: 27.5 | ~ | Mean: 23.7 | Mean: 9.7 | ~
| | SD: 10.4 | | | | SD: 9.2 | | SD: 2.8 | SD: 4.7
Moderate progression | 40 | Mean: 39.5 | ~ | ~ | W: 40 | Mean: 25.5 | ~ | Mean: 24.2 | Mean: 9.8 | ~
| | SD: 10.4 | | | | SD: 8.3 | | SD: 3.4 | SD: 4.6
Severe progression | 37 | Mean: 33.9 | ~ | ~ | W: 37 | Mean: 24.4 | ~ | Mean: 23.7 | Mean: 10.5 | ~
| | SD: 9 | | | | SD: 7.1 | | SD: 2.3 | SD: 4.3
Klein et al, 1988 [2832] | 1878 | ~
Young onset | 891 | ~ | 442 | 437 | ~ | ~ | Hx: 115 | ~ | ~ | ~
| | | | | | | Current: 197
Older onset with insulin | 987 | ~ | 170 | 206 | ~ | ~ | Hx: 123 | ~ | ~ | Hx CVD: 97
| | | | | | | Current: 53
Older onset no insulin | | ~ | 185 | 233 | ~ | ~ | Hx: 129 | ~ | ~ | Hx CVD: 74
| | | | | | | Current: 54
Waltman et al, 1984 [3029] | 61 | Mean: 23.12 | 29 | 32 | W: 100% | Mean: 6.72 | Hx: 14 | ~ | ~ | ~
| | SE: 0.91 | | | | SE: 0.75
| | IQR: 10–40 | | | | IQR: 2–20
Toyry et al., 1996 [3527] | 133 | Mean: 55.7 | 52.6% | 47.4% | Finnish: 100% | ~ | Hx: 46.6% | Mean: 30.4 | Mean: 12 | Hx CHD: 24 (18%)
| | SD: 9.7 | | | | | | SD: 0.17 | SD: 4
Nichols et al., 2001 [4025] | 8460 | Mean: 63 | 52.2% | 47.8% | ~ | Mean: 4.5 | ~ | ~ | ~ | Hx CHD: 19.7%
Yamasaki et al., 2000 [4081] | 287 | Mean: 61.7 | 124 | 163 | Asian: 100% | Mean: 15.6 | ~ | Mean: 22.6 | ~ | ~
| | SD: 0.6 | | | | SD: 0.5 | | SD: 0.17
Stratton et al., 2000 [4087] | 3642 | Mean: 53 | 60% | 40% | AA: 8% | ~ | ~ | Mean: 27 | Mean: 7.9 | ~
| | SD: 8 | | | W: 82% | | | SD: 5.3 | IQR: 6.6–10
| | | | | Other: 10%
Adler et al., 1999 [4124] | 5063 | Mean: 53 | 59% | 41% | AA: 8% | Mean: 0 | Hx: 31% | Mean: 27 | Mean: 166 | Hx CHD: 2%
| | | | | W: 82% | | | | | Hx CVD: 1.4%
| | | | | Other: 10%
Epidemiology of Diabetes intervention and Complicaitons (EDIC) Research Group, 1999 [4147] | 1325
Women Intensive | 321 | Mean: 35 | 0% | 100% | ~ | Mean: 168 (months) | Hx : 19.7% | Mean: 26.5 | ~ | ~
| | SD: 7 | | | | SD: 58 | | SD: 4.6
Women Conventional | 313 | Mean: 34 | 0% | 100% | ~ | Mean: 170 (months) | Hx: 18.1% | Mean: 25.1 | ~ | ~
| | SD: 7 | | | | SD: 61 | | SD: 3.6
Men Intensive | 340 | Mean: 36 | 100% | 0% | ~ | Mean: 167 (months) | Hx: 19.3% | Mean: 26.8 | ~ | ~
| | SD: 7 | | | | SD: 59 | | SD: 4.2
Men Conventional | 351 | Mean: 36 | 100% | 0% | ~ | Mean: 159 (months) | Hx: 18.4% | Mean: 25.9 | ~ | ~
| | SD: 7 | | | | SD: 55 | | SD: 3.2
Turner et al, 1998 [4217] | 2693
Men | 1564 | Mean: 52 | 100% | 0% | W:100% | ~ | Hx: 712 | Mean: 27.1 | Mean: 8.3 | ~
| | SD: 9 | | | | | | SD: 4.7 | SD: 2.8
Women | 1129 | Mean: 53 | 0% | 100% | W:100% | ~ | Hx: 297 | Mean: 29.4 | Mean: 9.2 | ~
| | SD: 9 | | | | | | SD: 6.4 | SD: 3
Lehto et al., 1997 [4240] | 1059
Men no CHD | 425 | Mean: 57 | 425 | 0 | ~ | Mean: 8 | Hx: 24% | Mean: 28.2 | Mean: 11 | Hx CHD: 13.4%
| | SE: 03 | | | | SE: 0.2 | | SE: 0.2 | SE: 0.2
Men with CHD | 156 | Mean: 58.2 | 156 | 0 | ~ | Mean: 8.4 | Hx: 26.9% | Mean: 28.5 | Mean: 11.6 | Hx CHD: 37.2%
| | SE: 0.4 | | | | SE: 0.4 | | SE: 0.3 | SE: 0.3
Women no CHD | 378 | Mean: 58.7 | 0 | 378 | ~ | Mean: 7.8 | Hx: 6.9% | Mean: 30.4 | Mean: 12.1 | Hx CHD: 9.5
| | SE: 0.3 | | | | SE: 0.2 | | SE: 0.3 | SE: 0.2
Women with CHD | 100 | Mean: 60.7 | 0 | 100 | ~ | Mean: 9 | Hx: 5% | Mean: 30.2 | Mean: 13.4 | Hx CHD: 18%
| | SE: 0.4 | | | | SE: 0.4 | | SE: 0.5 | SE: 0.4
Standl et al., 1996 [4276] | 268 | | 103 | 187 | Other | | Hx: 16%
Survivors | 165 | Median: 63 | ~ | ~ | ~ | Mean: 7 | ~ | Mean: 27.7 | Mean: 7.3 | Hx CHD: 34%
| | IQR: 56–69 | | | | IQR: 2–11 | | IQR: 25.5–30.8 | IQR: 5.7–10.8 | Hx CVD: 4.3%
| | | | | | | | | | Hx PVD: 33%
Deceased Subjects | 103 | Median: 68 | ~ | ~ | ~ | Mean: 9 | ~ | Mean: 26.7 | Mean: 9.2 | Hx CHD: 58%
| | IQR: 64–72 | | | | IQR: 2–14 | | IQR: 24.1–29.6 | IQR: 6.4–12.2 | Hx CVD: 15.3%
| | | | | | | | | | Hx PVD: 53%
Macrovascular Deaths | 58 | Median: 67 | ~ | ~ | ~ | Mean: 8 | ~ | Mean: 26.3 | Mean: 9.7 | Hx CHD: 61%
| | IQR: 64–72 | | | | IQR: 2–13 | | IQR: 23.9–29.9 | IQR: 7.2–12.1 | Hx CVD: 18.9%
| | | | | | | | | | Hx PVD: 60%
Lehto et al., 1996b [4313] | 1059 | | 581 | 478 | ~
Men no stroke | 520 | Mean: 57 | 520 | 0 | ~ | Mean: 8.1 | Hx: 23% | Mean: 28.3 | ~ | ~
| | SE: 0.2 | | | | SE: 0.2 | | SE: 0.2
Men with stroke | 61 | Mean: 58.5 | 61 | 0 | ~ | Mean: 8.2 | Hx: 32.8% | Mean: 28.3 | ~ | ~
| | SE: 0.5 | | | | SE: 0.6 | | SD: 0.4
Women no stroke | 414 | Mean: 59 | 0 | 414 | ~ | Mean: 7.8 | Hx: 6.5% | Mean: 30.5 | ~ | ~
| | SE: 0.2 | | | | SE: 0.2 | | SD: 0.3
Women with stroke | 64 | Mean: 60.1 | 0 | 64 | ~ | Mean: 9.2 | Hx: 6.3% | Mean: 29.4 | ~ | ~
| | SE: 0.5 | | | | SE: 0.4 | | SD: 0.6
Moss et al, 1994b [4338] | 2366
Young onset | 943 | Mean: 29.1 | 51% | 49% | W: 98.9% | Mean: 14.6 | Hx: 24.5% | Mean:23.6 | ~ | ~
| | SD: 13.3 | | | | SD: 10.5 | | SD: 4.3
Older onset | 1265 | Mean: 66.6 | 46% | 54% | W: 98.6% | Mean: 11.6 | Hx: 14.5% | Mean: 28.8 | ~ | ~
| | SD: 11.4 | | | | SD: 6.1 | | SD: 5.7
Fu et al., 1993 [4403] | 479 | Mean: 61.2 | 198 | 281 | Asian: 100% | ~ | Hx: 122 | ~ | ~ | ~
| | SD: 9.7

* Abbreviations: BMI=Body Mass Index, FG=Fasting Glucose, CVD=Cardiovascular Disease, CHD=Coronary Heart Disease,PVD=Peripheral Vascular Disease, W=Caucasian, AA=African American, NA=Native American, Oth=Other, AC=Afro-Caribbean,Hx=History, IQR=Interquartile Range, SE=Standard Error, SD=Standard Deviation

§=weeks

Table 3. Baseline Data for All Study Participants; Randomized Controlled Trials

Reference and Study Group | Total N | Age, Y | Gender | | Race/Ethnicity % | Diabetes Duration(Y) | Smoking n (%) | BMI* (kg/m^2^) | FG* | Prior CVD* n (%)
| | | M n (%) | F n (%)
Shichiri et al., 2000 [247] | 110 | | | | Asian: 100%
“1° Standard” | 27 | Mean: 49 | 13 | 14 | | Mean: 6 | ~ | Mean: 21.2 | ~ | ~
| | SD: 14 | | | | SD: 4.9 | | SD: 2.2
“1° Intensive” | 28 | Mean: 47 | 15 | 13 | | Mean: 6.5 | ~ | Mean: 21.6 | ~ | ~
| | SD: 9 | | | | SD: 6.1 | | SD: 1.8
“2° Standard” | 28 | Mean: 53 | 13 | 15 | | Mean: 10.4 | ~ | Mean: 19.6 | ~ | ~
| | SD: 14 | | | | SD: 4.8 | | SD: 2.8
“2° Intensive” | 27 | Mean: 49 | 13 | 14 | | Mean: 10.7 | ~ | Mean: 19.5 | ~ | ~
| | SD: 12 | | | | SD: 4.6 | | SD: 1.9
Gaede et al., 1999 [416] | 149
“Standard” | 80 | Mean: 55.2 | 56 | 24 | ~ | Median: 6 | Past: 33 | ~ | Mean: 10.5mmol/L | CHD: 23
| | SD: 7.2 | | | | IQR: 4–10 | Current: 27 | | SD: 3 | CVD: 3
| | | | | | | Never: 20 | | | PVD: 2
“Intensive” | 80 | Mean: 54.9 | 63 | 17 | ~ | Median: 5.5 | Past: 27 | ~ | Mean: 10.1mmol/L | CHD: 18
| | SD: 7.2 | | | | IQR: 2–8.8 | Current: 20 | | SD: 3.1 | CVD: 2
| | | | | | | Never: 21 | | | PVD: 1
Ohkubo et al., 1995 [888] | 102
1° Conventional | 25 | Mean: 49 | 49 | 53 | ~ | Mean: 6.7 | ~ | Mean: 21 | ~ | ~
| | SD: 1.4 | | | | SD: 6.3 | | SD: 2.3
2° Conventional | 25 | Mean: 47 | 12 | 13 | ~ | Mean: 6.2 | ~ | Mean: 21.7 | ~ | ~
| | SD: 9 | | | | SD: 5 | | SD: 1.8
1° Intensive | 26 | Mean: 52 | 11 | 14 | ~ | Mean: 10.3 | ~ | Mean: 19.2 | ~ | ~
| | SD: 15 | | | | SD: 4.9 | | SD: 2.8
2° Intensive | 26 | Mean: 49 | 14 | 12 | ~ | Mean: 10.2 | ~ | Mean: 19.3 | ~ | ~
| | SD: 13 | | | | SD: 4.2 | | SD: 1.7
Reichard et al., 1995 [921] | 89 | Mean: 31 | | | | Mean: 17
| | SD: 1 | | | | SD: 1
“Standard” | 48 | Mean: 32 | ~ | ~ | ~ | Mean: 16 | ~ | Mean: 22.8 | ~ | ~
| | SD: 7 | | | | SD: 4 | | SD: 2.2
“Intensive” | 54 | Mean: 30 | ~ | ~ | ~ | Mean: 18 | ~ | Mean: 22.6 | ~ | ~
| | SD: 8 | | | | SD: 6 | | SD: 2.1
Reichard et al., 1993 [1069] | 102
“Standard” | 48 | Mean: 32 | 28 | 26 | ~ | Mean: 16 | ~ | Mean: 22.8 | | ~
| | SD: 7 | | | | SD: 4 | | SD: 2.2
“Intensive” | 54 | Mean: 30 | 26 | 22 | ~ | Mean: 18 | ~ | Mean: 22.6 | ~ | ~
| | SD: 8 | | | | SD: 6 | | SD: 2.1
Reichard et al., 1991 [1266] | 96
“Conventional” | 44 | Mean: 31.6 | 27 | 25 | ~ | Mean: 16.1 | ~ | Mean: 22.8 | ~ | ~
| | SD: 1 | | | | SD: 1 | | SD: 0.4
“Intensified Conventional” | 52 | Mean: 29.5 | 22 | 22 | ~ | Mean: 18.1 | ~ | Mean: 22.5 | ~ | ~
| | SD: 1.1 | | | | SD: 0.7 | | SD: 0.3
United Kingdom Prospective Diabetes Study (UKPDS) Group, 1998 [2113] | 4209
“Standard” | 1138 | Mean: 53.4 | 705 | 433 | W: 81% | ~ | Past: 35% | Mean: 27.8 | Median: 8mmol/L | ~
| | SD: 8.6 | | | Asian: 11% | | Current: 31% | SD: 5.5 | IQR: 7.1–0.6
| | | | | AC: 7% | | Never: 34%
| | | | | NOS: 1%
“Intensive” | 2729 | Mean: 53.2 | 649 | 444 | W: 81% | ~ | Past: 35% | Mean: 27.5 | Median: 8.1mmol/L | ~
| | SD: 8.6 | | | Asian: 0% | | Current: 30% | SD: 5.1 | IQR: 7.1–9.8
| | | | | AC: 8% | | Never: 35%
| | | | | NOS: 1%
DCCT, 1995 [2438] | 1441
“1° Standard” | 378 | Mean: 26 | 54% | 46% | W: 96% | Mean: 2.6 | ~ | ~ | ~ | ~
| | SD: 8 | | | | SD: 1.4
“1° Intensive” | 348 | Mean: 27 | 49% | 51% | W: 96% | Mean: 2.6 | ~ | ~ | ~ | ~
| | SD: 7 | | | | SD: 1.4
“2° Standard” | 352 | Mean: 27 | 54% | 46% | W: 97% | Mean: 8.6 | ~ | ~ | ~ | ~
| | SD: 7 | | | | SD: 3.7
“2° Intensive” | 363 | Mean: 27 | 53% | 47% | W: 97% | Mean: 8.9 | ~ | ~ | ~ | ~
| | SD: 7 | | | | SD: 3.8
DCCT, 1993 [4638] | 1441
“1° Standard” | 378 | Mean: 26 | 54% | 46% | W: 96% | Mean: 2.6 | Current: 17% | ~ | Mean: 229 mg/dl | ~
| | SD:8 | | | | SD: 1.4 | | | SD: 80
“1° Intensive” | 348 | Mean: 27 | 49% | 51% | W: 96% | Mean: 2.6 | Current: 19% | ~ | Mean: 234 mg/dl | ~
| | SD: 7 | | | | SD: 1.4 | | | SD: 86
“2° Standard” | 352 | Mean: 27 | 54% | 46% | W: 97% | Mean: 8.6 | Current: 19% | ~ | Mean: 232 mg/dl | ~
| | SD: 7 | | | | SD: 3.7 | | | SD: 78
“2° Intensive” | 363 | Mean: 27 | 53% | 47% | W: 97% | Mean: 8.9 | Current: 18% | ~ | Mean: 234 mg/dl | ~
| | SD: 7 | | | | SD: 3.8 | | | SD: 81

* Abbreviations: BMI= Body Mass Index, FG=Fasting Glucose, CVD=Cardiovascular Disease, CHD=Coronary Heart Disease, PVD=Peripheral Vascular Disease, CBVD=Cerebrovascular Disease, W=Caucasian, 1°=primary prevention; 2°=secondary prevention; AA=African American, NA=Native American, Oth=Other, AC= Afro-Caribbean, IQR=Interquartile Range, SE=Standard Error, SD=Standard deviation

Table 4. Diagnosis of Diabetes; Cohort Studies

Reference | DM type | Not mentioned | Hypoglycemic Rx use | Insulin rx | Chart review | Previous clinical trial | Self report of previous physician diagnosis | Previous physician diagnosis | Ketoacidosis | Fasting Glucose | Non Fasting Glucose | Age at diagnosis | C-peptide Concentration | WHO criteria year | Additional Comments
Olson et al., 2002 [7] | 1 | | | X | | | | X | | | | <17years
White et al., 2002 [19] | 1 | | | | | X
Scott et al., 2001 [25] | 1 | | | | | | | X | | | | | | | • Attendees in diabetic clinic
Chaturvedi et al., 2001a [84] | 1 | | | X | | | | | | | | <36years
Chaturvedi et al., 2001b [140] | 1 | | | X | | | | | | | | <36years
Hovind et al., 2001 [154] | 1 | | | | | | X | | | | | | | | • Attendees of diabetes center
Muhlhauser et al., 2000a [178] | 1 | | | | X | | | | | | | | | | • Use of insulin prior to age 31
| | | | | | | | | | | | | | | • Patient registries of diabetic individuals
Makimattila et al., 2000 [184] | 1 | | | | | | | X | | | | <15years
Muhlhauser et al., 2000b [185] | 1 | | | | | X | | X | | | | <31years | | | • Use of insulin prior to age 31
Stella et al., 2000 [224] | 1 | X | | X | | | | X | | | | <17 years
Nosadini et al., 2000 [245] | 2 | X | | | | | | | | >140 mg/dl | | | | | • OGTT > 200 mg/dl at 2 hours
Sawicki et al., 2000 [289] | 1 | | | | | | X
DCCT, 2000 [292] | 1 | | | | | X
Warram et al, 2000 [304] | 1 | | | X | | | | | | | | <41years | | | • Diabetes Specialty clinic
The Microalbuminuria Collaborative Study Group, 1999 [310] | 1 | | | X | | | | | X | | | <40years
Oue et al., 1999 [315] | 2 | | | | | | | | | | | | | WHO (year not provided)
Villar et al., 1999 [325] | 2 | | | | | | | | | | | ≤35years
| 1 | | | X | | | | | | | | ≥35years | <0.6pmol/L | | • Abrupt onset
| | | | | | | | | | | | | | | • BMI<25kg/m^2^
| | | | | | | | | | | | | | | • Ab to islet cells or glutamic acid decarboxylase
Klein et al., 1999 [387] | 1 | | | X | | | | X | | | | <30years
Lehto et al., 1999 [397] | 1 | | | | | | | | X | | | | <0.20nmol/L
Molyneaux et al., 1998 [424] | 2 | | | | | | | X | | | | | | 1985
Niskanen et al., 1998 [457] | 2 | | | | | | | X | | | | | | 1980
Bojestig et al., 1998 [460] | 1 | | | | | | | X | | | | <15years
Florkowski et al., 1998a [481] | 2 | | | | | | | | | | | >30years | | | • Not requiring insulin in first year following diagnosis
Jones et al., 1998 [482] | 1 | | | | | | | X | | | | | | | • Diabetes Specialty clinic
Yokoyama et al., 1998 [503] | 2 | | | | | X
Florkowski et al., 1998b [519] | 2 | | | | | | | | | | | >30years | | | • Not requiring insulin in first year following diagnosis
Ravid et al., 1998 [531] | 2 | | | | | | | | | | | >40years | | 1980 | • Not requiring insulin in first 6 months following diagnosis
Park et al., 1998 [534] | 2 | | | | | | | | | | | | | | • Diabetes Specialty clinic
Mulec et al., 1998 [540] | 1 | X
Guillausseau et al., 1998 [556] | 2 | | | | | | | | | | | | | 1985 | • No hx of Ketoacidosis
| | | | | | | | | | | | | | | • No insulin treatment for atleast 3 years after diagnosis
Earle et al., 1997 [566] | 1 | | | X | | | | | | | | <40years | | | • Not requiring insulin in first year following diagnosis
d'Annunzio et al., 1997 [587] | 1 | | | | | | | | | | | | | 1985
Yokoyama et al., 1997 [653] | 2 | | | | | | | X | | | | | | | • Diabetes Specialty clinicS
Gall et al., 1997 [654] | 2 | | X | X | | | | | | | | >40years | >=0.6pmolmL | | • BMI above normal (> 25 kg/m^2^ in women; > 27 kg/m^2^ in men)
Alaveras et al., 1997 [681] | 1 | | | | | | | X | | | | | | | • Diabetes specialty clinic
Reichard et al., 1996 [699] | 1 | | | | | X | | | | | | <30years | | | • Use of insulin within first year of diagnosis
DCCT, 1996 [718] | 1 | | | | | | | | | | | | | | • Deficient C-peptide
Niskanen et al., 1996 [749] | 2 | | | | | | | X | | | | | | 1980 | • No Ketoacidosis at diagnosis
| | | | | | | | | | | | | | | • No insulin rx during followup
Lloyd et al., 1996 [777] | 1 | | | X | | | | X | | | | <17 years
Klein et al., 1996 [809] | 2 | | | | | X
| 1 | | | | | X
Gall et al., 1995 [827] | 2 | | X | | | | | | | | | >40years | ≥0.6pmol/ml | | • BMI>=27kg/m^2^ for men and >=25kg/m^2^ for women
Klein et al., 1995a [853] | 1 | | | | | | | | | >=7.8mmol/L | >=11.1mmol/L | ≥30years
| 2 | | | | | | | | | | | <30years
Lloyd et al., 1995 [870] | 1 | | | X | | | | X | | | | <17years
Izumi et al., 1995 [871] | 1 | | | | | | | X | | | | | | | • Attendees of diabetes camp
Powrie et al., 1994 [929] | 1 | | | | | | | X
Danne et al., 1994 [934] | 1 | | | | | | | X | | | | Range: 1–18years | | | • Diabetes Specialty clinic
Rudberg et al., 1993 [1023] | 1 | | | | | | | X
Klein et al., 1993 [1103] | Older onset taking insulin | | | X | | | | | | ≥7.8mm | ≥11.1mm | ≥30years
| Older onset not taking insulin | | | | | | | | | ≥7.8mm | ≥11.1 mm | ≥30years
Haneda et al., 1992 [1172] | 2 | X
Reichard et al., 1992 [1188] | 1 | | | | | X
Rudberg et al., 1992 [1204] | 1
Chase et al., 1989 [1444] | 1 | | | | | | | X
Porta et al., 2001 [1769] | 1 | | | X | | | | | | | | <36years
Zhang et al., 2001 [1833] | 1 | X | | | | X
Stratton et al., 2001 [1863] | 2 | | | | | X
Yoshida et al., 2001 [1864] | 2 | | | | | | | | | | | | | 1985
Voutilainen-Kaunisto et al., 2001 [1867] | 2 | | | | | | | X | | | | | | 1980 | • No ketosis
| | | | | | | | | | | | | | | • No insulin needed during follow-up of at least 3 years
Okudaira at al., 2000 [1899] | 2 | | | | | | | | | | | | | | • No ketosis
| | | | | | | | | | | | | | | • No insulin use for more than 1 year after diabetes diagnosis
| | | | | | | | | | | | | | | • Preseved insulin secretion even when using insulin
| | | | | | | | | | | | | | | • Diagnosed before age of 30
Christen et al., 1999 [1999] | 1 | | | | | X | | | | | | <30years
Dyck et al., 1999 [2022] | 2 | | | | | | | X | | | | | | | • Natural Diabetic data GRp criteria
Cohen et al., 1999 [2039] | 1 | | | | | | | X | X | ≥120 mg/dl | ≥200 mg/dl
Moss et al., 1999 [2047] | 2 | | | | | | | | | >=7.8mmol/L | >=11.1mmol/L
| 1 | | | X | | | | | | | | <30years
Klein et al., 1998 [2108] | 1 | | | X | | X | | | | | | <30years
Moss et al., 1998 [2145] | 1 | | | X | | | | | | | | <30years
Arfken et al., 1998 [2157] | 1 | | X | | | | | | | | ≤40
Kim et al., 1998 [2171] | 2 | | X | | | | | | | | | >30years | | | • No ketoacidosis
Tudor et al., 1998 [2173] | 2 | | X | | | | | X | | | | | ≥0.1pmol/ml
Nakagami et al., 1997 [2259] | 2 | | | | | | | | | | | | | 1985 | • Previous history of diabetes
Klein et al., 1997 [2270] | 1
Sands et al., 1997 [2275] | 2 | | X | | | | | | | | | | | WHO (year not provided)
Henricsson et al., 1997 [2281] | 2 | X | | | | | | X
Vitale et al., 1997 [2282] | 1 | | | | | | | X
Moss et al., 1996 [2326] | 2 | | | | X | | | X | | ≥140mg/dl | ≥200mg/dl | ≥30years
| 1 | | | X | X | | | X | | | | <30years
Lehto et al., 1996a [2330] | 2 | | | | | | | | | | | | ≥0.2mmol/L | 1985
Kovacs et al., 1995 [2372] | 1 | | | | | | | X | | | | | | | • Admission to Inpatient Diabetes Unit
Bonney et al., 1995 [2379] | 1 | | | | | | | X
Yokoyama et al., 1995 [2386] | 1 | | | X | | | | | X | | | <30years
Vitale et al., 1995 [2391] | 1 | | | | | | | X
Chen et al., 1995 [2392] | 2 | | X | X | | | | | | | | | | 1985
Klein et al., 1995b [2437] | 2 | | | | | | | | | | | >30years
| 1 | | | X | | | | | | | | <30years
Klein et al., 1994 [2458] | 2 | | | | | | | | | ≥140mg/dl | ≥200mg/dl | ≥30years
| 1 | | | X | | | | | | | | <30years
Moss et al., 1994a [2482] | Older onset Taking insulin | | | | | | | | | ≥7.8mmol/L | >=11.1mmol/L
| Older onset not taking insulin | | | | | | | | | ≥7.8mmol/L | >=11.1mmol/L
| 1 | | | X | | | | | | | | <30years
Morisaki et al, 1994 [2502] | 2 | | | | | | | | | | | | | WHO (year not provided)
Araki et al, 1993 [2535] | 2 | | | | | | | X | | | | >60years
Marshal et al, 1993 [2537] | 1 | | | | | | | X
Moss et al, 1992 [2636] | 2 | | | | | | | | | | | ≥30years
| 1 | | | X | | | | | | | | <30years
Klein et al, 1991 [2691] | 1 | | | X | | X | | X
Klein et al, 1989 [2787] | 2 | | | | | | | | | ≥7.8mmol/L | ≥11.1mmol/L | ≥30years
| 1 | | | X
Janka et al, 1989 [2809] | 1 | | | X | | X
Klein et al, 1988 [2832] | 2 | | | | | | | X | | ≥7.8mmol/L | ≥11.1mmol/L | ≥30years
| 1 | | | X | | | | X | | | | <30years
Waltman et al, 1984 [3029] | 1 | | | X | | X | | | | | | | | | • From nationwide study group of juvenile onset diabetes
Toyry et al., 1996 [3527] | 2 | | | | | | | X | | | | | | 1980
Nichols et al., 2001 [4025] | 2 | | | | | | | X | | | | | | | • Kaiser Permanente Diabetes Registry
Yamasaki et al., 2000 [4081] | 2 | | | | | | | | | | | >30years | | 1980 | • No hx of ketoacidosis
| | | | | | | | | | | | | | | • No ketonuria
| | | | | | | | | | | | | | | • Insulin therapy (if any) started after at least 5 years.
Stratton et al., 2000 [4087] | 2 | | | | | X | | | | >=6mmol/L
Adler et al., 1999 [4124] | 2 | | | | | | | | | >6mmol/L
Epidemiology of Diabetes Infection and Complications (EDIC) Research Group, 1999 [4147] | 1 | | | | | X
Turner et al, 1998 [4217] | 2 | | | | | | | | | >6mmol/L
Lehto et al., 1997 [4240] | 2 | | | | | | | | | | | | ≥0.2nmol/L | WHO (year not provided)
Standl et al., 1996 [4276] | 2 | | | | | | | X | | | | | | 1985
Lehto et al., 1996b [4313] | 2 | | | | | | | | | | | | ≥0.2nmol/L | 1985
Moss et al, 1994b [4338] | 2 | | | | X | | | X | | >140mg/dl | >200 mg/dl | ≥30years
| 1 | | | X | X | | | X | | | | <30years
Fu et al., 1993 [4403] | 2 | | X

Table 5. Diagnosis of Diabetes; Randomized Controlled Trials

Reference | DM type | Insulin rx | Previous Clinical Trial | Previous physician diagnosis | Fasting Glucose | Age at diagnosis | HbA1c | C-peptide concentrations | WHO Criteria year | Additional Comments
Shichiri et al., 2000 [247] | 2 | | | | | | | >20ug | | • No history of ketoacidosis
| | | | | | | | | | • No islet cell antibodies
Gaede et al., 1999 [416] | 2 | | | | | | | | WHO 1985
Ohkubo et al., 1995 [888] | 2 | | | | | | >20 | | | • No history of ketoacidosis
| | | | | | | | | | • No islet cell antibodies
Reichard et al., [921] | 1 | X | | X | | ≤30
Reichard et al., 1993 [1069] | 1
Reichard et al., 1991 [1266] | 1 | X | X | | | ≤30
United Prospective Diabetes Study (UKPDS) Group, 1998 [2113] | 2 | | | X | >6mmol/L
DCCT, 1995 [2438] | 1 | X | | | | | | Undetectable
DCCT, 1993 [4638] | 1 | | | | | | | Deficient

Table 6. Retinopathy: Cohort Studies: Incident Retinopathy, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Linear regression | Comments
Chaturvedi et al., 2001b [140] | 1 | 7.3 | 764 | ALL | Immunoassay | Yes | | RR: 1.93 (1.52, 2.44) | | Fundus photography
| | | | *Mean: 6.33 | HbA1c
| | | | Retinopathy:
| | | | Mean: 6.9
| | | | SD: 0.1
| | | | No Retinopathy:
| | | | Mean: 5.6
| | | | SD: 0.1
Bojestig et al., 1998 [460] | 1 | 20 | 197 | ALL | HPLC | No | | | | Fundus photography
| | | | | HbA1c
| | | | ≤8.1 | | | 1.9%
| | | | 8.2–9.4 | | | 9.0%
| | | | >9.5 | | | 55.0%
DCCT, 1996 [718] | 1 | 6.5 | 1273 | ALL | HPLC | Yes | | RRR for 10% change in GHB exposure: 37% (27%, 45%) Adj. | | Severe NPDR
| | | | *Mean: 7.99 | HbA1c | | | | | Adj: Endpoint at baseline and treatment
| | | | Conventional Mean over f/u ~9 | | | | RRR for 10% change in GHB exposure: 41% (30%, 50%) | | Adj: Endpoint at baseline
| | | | Intensive Mean over f/u ~7 | | | | RRR for 10% change in GHB exposure: 26% (2%, 44%) | | Adj: Endpoint at baseline
Chase et al., 1989 [1444] | 1 | 8 | 230 | ALL | HPLC | No | | | | Fundus photography
| | | | | HbA1c
| | | | ≤10.8 | | | 27%
| | | | 10.9–12.3 | | | 51%
| | | | ≥12.4 | | | 41%
Zhang et al., 2001 [1833] | 1 | 6.5 | 319 | ALL | NOS | NOS
| | | | | HbA1c
| | | | <6.17 | | | 0%
| | | | >9.49 | | | 1.8%
Klein et al., 1997 [2270] | 1 | 4 | 354 | ALL | HPLC | No | | | | Fundus photography
| | | | | HbA1c
| | | | ≤11.9 | | | 3.4%
| | | | ≥12.0 | | | 10.5%
Bonney et al., 1995 [2379] | 1 | 1.3 | 203 | ALL | In-house colorimetric | No | | | | Fundus photography
| | | | | HbA1c | | | | | Adj: Age, gender, DM duration, BP, age at diagnosis, glycemic control, lipids
| | | | <8.4 | | | | RR: 1.0 Adj.
| | | | ≥8.4 | | | | 4.02 (2.13, 7.58)
d'Annunzio et al., 1997 [587] | 1 | 3 | 100 | ALL | HPLC | No | | RH: 2.58 (1.47, 4.52) | | Fluorescein angiography
| | | | | HbA1 | | | Adj Model 1 | | Adj Model 1: Puberty at IDDM onset
| | | | | | | | RH: 3.07 (1.69, 5.56) | | Adj Model 2: Age at IDDM onset
| | | | | | | | Adj Model 2
| | | | ≤7.0 | | | | RH: 1.0
| | | | 7.1–9.0 | | | | 2.39 (0.54, 10.51)
| | | | >9.0 | | | | 7.71 (1.65, 36.12)
Klein et al., 1996 [809] | 1 | 10 | 765 | Mean: 10.8 | Microcolumn technique | No | 89.3% | | | Fundus photography
| | | | SD not reported | HbA1
Danne et al., 1994 [934] | 1 | 13 | 346 | ALL | Microcolumn technique | No | | | | Background retinopathy or greater Fluorescein angiography
| | | | | HbA1
| | | | ≤8.0 | | | 1.03%
| | | | 8.1–9.0 | | | 1.64%
| | | | 9.1–10.0 | | | 4.31%
| | | | ≥10.0 | | | 5.40%
Kovacs et al., 1995 [2372] | 1 | 10 | 66 | ALL | HPLC | No | | | | Fundus photography
| | | | | HbA1
| | | | ≤14.2
| | | | ≥14.3 | | | | | 6.051 (p<0.001)
Klein et al., 1994 [2458] | 1 | 10 | 682 | ALL | Resin Microcolumn technique | No | 89.3% | OR: 1.6 (1.4, 1.9) Adj. | | Fundus photography Incidence of any retinopathy
| | | | Mean: 10.8 | HbA1 | | | | | Adj: Age, gender, DM duration, change in GHB
| | | | SD: 2.1
| | | | 5.6–9.4 | | | 80% | RR: 1.0 (Crude)
| | | | 9.5–10.5 | | | 95% | 1.5 (1.2, 1.9)
| | | | 10.6–12.0 | | | 92% | 1.5 (1.2, 1.9)
| | | | 12.1–19.5 | | | 98% | 1.9 (1.5, 2.4)
Klein et al, 1988 [2832] | 1 | 4 | 1780 | ALL | Microcolumn technique | NOS | | OR: 1.4 (1.2, 1.5) Adj | | Fundus photography
| | | | Mean: 12.5 | | | | | | Adj: Age, gender, DM duration
| | | | SD: 2.6 | GHB

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 7. Retinopathy: Cohort Studeies: Incident Retinopathy, type 2diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Linear regression | comments
Molyneaux et al., 1998 [424] | 2 | 2.3 | 963 | Mean: 9.5 | HPLC | Yes | 5.7% per 1 year | RRR: 24% (16%, 32%) Adj. | | RRR for 1.1 unit change in HbA1c
| | | | IQR: (6.7, 7.8) | HbA1c | | | | | Adj: Unclear
Stratton et al., 2001 [1863] | 2 | 6 | 1919 | ALL | HPLC | Yes | 22% | | | Fundus photography; scatter photocoagulation; microaneurysms by EDTRS criteria
| | | | | HbA1c
| | | | ≤6.2 | | | | RR: 1.0 Adj. | | Adj: Age, gender, race, weight, BP, smoking
| | | | 6.2–7.5 | | | | 1.4 (1.1, 1.8)
| | | | ≥7.5 | | | | 2.5 (2.0, 3.2)
Voutilainen-Kaunisto et al., 2001 [1867] | 2 | 10 | 85 | ALL | HPLC | No | | | | Fundus photography
| | | | | HbA1c
| | | | ≤8.1 | | | 18.4%
| | | | 8.2–9.6 | | | 34.2%
| | | | ≥9.7 | | | 47.4%
Okudaira at al., 2000 [1899] | 2 | 5.4 | 394 | Mean: 8.5 | HPLC | Yes | 48.1 events per 1000 person years | RH: 1.25 (1.12, 1.39) Crude | | Adj: Age, DM duration, weight, BP, smoking, lipids, family hx of DM, family hx of vascular disease
| | | | SD: 2.2 | HbA1c | | | RH: 1.29 (1.15, 1.44) Adj
Nakagami et al., 1997 [2259] | 2 | 10 | 137 | Mean: 9.5 | HPLC | No | | | 0.1967 (p=0.1545) Adj. | Adj: Age, race, adiposity, BP, glycemic control
| | | | SD: 3 | HbA1c
| | | | ≤5.9 | | | 0%
| | | | 6–6.9 | | | 17.2%
| | | | 7–7.9 | | | 14.3%
| | | | 8–8.9 | | | 41.9%
| | | | ≥9 | | | 54.8%
Chen et al., 1995 [2392] | 2 | 4 | 464 | ALL | HPLC | No
| | | | | HbA1c
| | | | ≤6.18 | | | 8.4%
| | | | 6.19–7.2 | | | 16.7%
| | | | 7.21–8.4 | | | 20.0%
| | | | ≥8.4 | | | 40.0%
Guillausseau et al., 1998 [556] | 2 | 13 | 64 | Mean: 8.6 | HPLC | No | | | | Fluorescein angiography
| | | | SD: 1.5 | HbA1
| | | | ≤8.4 | | | | RR: 1.0 Adj. | | Adj: Unclear
| | | | >8.4 | | | | 2.5 (0.8, 8.0
Klein et al., 1996 [809] | 2 | 10 | 533 | ALL | Microcolumn technique | No | | | | Fundus photography
| | | | | HbA1
| | | | Insulin use: | | | 79.2%
| | | | Mean: 10.2
| | | | SD not reported
| | | | No insulin use: | | | 66.9%
| | | | Mean: 8.9
| | | | SD not reported
Kim et al., 1998 [2171] | 2 | 5 | 130 | ALL | HPLC | No | 44 events per 1000 person years
| | | | *Mean: 11.27 | HbA1
| | | | ≤8.5 | | | 5.1%
| | | | 8.6–9.8 | | | 15.6%
| | | | 9.9–11.6 | | | 35%
| | | | ≤11.7 | | | 37%
Klein et al., 1994 [2458] | 2 | 10 | 834 | ALL | HPLC | No | | | | Fundus photography
| | | | | HbA1
| | | | Insulin use: | | | 79.2% | OR: 1.3 (1.1, 1.6) Adj. | | Adj: Age, gender, DM duration, change in GHB
| | | | Mean: 1.0.2
| | | | SD: 1.8
| | | | 5.9–8.8 | | | 70% | RR: 1.0 (Crude)
| | | | 8.9–10.2 | | | 81% | 1.1 (0.7, 1.7)
| | | | 10.3–11.5 | | | 80% | 1.1 (0.7, 1.8)
| | | | 11.6–17.0 | | | 100% | 1.9 (1.3, 2.9)
| | | | No Insulin use: | | | 66.9% | OR: 1.6 (1.4, 1.8) Adj. | | Adj: Age, gender, DM duration, change in GHB
| | | | Mean: 8.9
| | | | SD: 1.9
| | | | 5.4–7.6 | | | 47% | RR: 1.0 (Crude)
| | | | 7.7–8.6 | | | 57% | 1.4 (0.9, 2.2)
| | | | 8.7–10.0 | | | 84% | 2.5 (1.7, 3.5)
| | | | 10.1–20.0 | | | 90% | 1.7 (1.9, 4.0)
Araki et al, 1993 [2535] | 2 | 5 | 110 | Mean: 9.6 | NOS | No | 68.2%
| | | | SD: 2.5 | HbA1
| | | | ≤7.9 | | | 40.2% | RR: 1.0
| | | | ≥8.0 | | | 82.8% | 1.54 (1.20, 1.98)
Florkowski et al., 1998a [481] | 2 | 6 | 447 | Mean: 63.1 | Automated fluorimetric method | No | 33% | OR: 1.78 (1.15, 2.85) Adj | | Adj: Gender, DM duration, BP, smoking, lipids, albuminuria, hypertension, cholesterol
| | | | SD: 18.7 | GHG
| | | | Not %
Tudor et al., 1998 [2173] | 2 | 4.8 | 169 | ALL | HPLC | No | 67.3 per 1000 person years | OR: 1.45 (1.06, 1.97) | | Adj Model 1: Age, gender, race, DM duration, baseline retinopathy, adiposity, BP, insulin use, smoking, glycemic control, lipids
| | | | *Mean: 9.41 | GHB | | | OR: 1.50 (0.96, 2.36) Adj Model 1 | | Adj Model 2: Model 1 except adiposity and lipids
| | | | | | | | OR: 1.46 (0.99, 2.17) Adj Model 2 | | Adj Model 3: Unclear
| | | | | | | | OR: 1.20 (0.99, 1.33) Adj Model 3
| | | | Non-Hispanic (White) Subjects
| | | | Mean: 9.0
| | | | SD: 2
| | | | Hispanic Subjects
| | | | Mean: 9.6
| | | | SD: 2.2
Klein et al, 1988 [2832] | 2 | 4 | 1780 | ALL | Microcolumn technique | NOS
| | | | | GHB
| | | | Insulin use: | | | | OR: 1.2 (1.1, 1.5) Adj. | | Adj: Age, gender, DM duration
| | | | Mean: 11.8
| | | | SD: 2.2
| | | | No insulin use: | | | | OR: 1.3 (1.2, 1.5) | | Adj: Age, gender, DM duration
| | | | Mean: 10.2
| | | | | SD: 2.3

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 8. Retinopathy: Cohort Studies: Incident Proliferate Retinopathy/Macular Edema, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
White et al., 2002 [19] | 1 | 4 | 175 | ALL | HPLC | Yes | | | Fundus photography; EDTRS criteria for Macular edema and proliferative retinopathy
| | | | | HbA1c
| | | | Conventional | | | Macular edema: 5.5%
| | | | Mean: 8.4 | | | Proliferative retinopathy: 8.7%
| | | | SD: 1.6 | | | Focal/scatter therapy: 5.6%
| | | | Intensive | | | Macular edema: 2.9%
| | | | Mean: 8.4 | | | Proliferative retinopathy: 1.4%
| | | | SD: 1.7 | | | Focal/scatter therapy: 0%
DCCT, 2000 [292] | 1 | 4 | 1177 | ALL | HPLC | Yes | | | Fundus photography; EDTRS criteria for Macular edema and proliferative retinopathy
| | | | | HbA1c
| | | | Conventional | | | Macular edema: 8% | RRR: 0 Adj. | Adj for retinopathy status at baseline.
| | | | Median: 8.2 | | | Proliferative retinopathy: 9%
| | | | | | | Focal/scatter therapy: 6%
| | | | Intensive | | | Macular edema: 2% | Macular edema: 77% (52%, 89%)
| | | | Median: 7.9 | | | Proliferative retinopathy: 2% | Proliferative retinopathy: 74% (46%, 87%)
| | | | | | | Focal/scatter therapy: 1% | Focal/scatter therapy: 77% (45%, 91%)
Porta et al., 2001 [1769] | 1 | 7.3 | 1249 | ALL | Immunoassay | Yes | 17.3 events over 1000 person years (13.6, 21.1) | OR: 3.03 (2.49, 3.69) | Fundus photography
| | | | *Mean: 6.55 | HbA1c | | | Adj Model 1 | Adj model 1: DM duration, adiposity, BP, age at diagnosis
| | | | | | | | OR: 3.24 (2.62, 4.00) | Adj model 2: model 1 + baseline retinopathy
| | | | | | | | Adj Model 2 | Adj model 3: model 2 + AER
| | | | | | | | OR: 2.97 (2.40, 3.68)
| | | | | | | | Adj Model 3
| | | | Progressors:
| | | | Mean: 8.3
| | | | SD: 0.2
| | | | Non-Progressors
| | | | Mean: 6.3
| | | | SD: 0.1
Vitale et al., 1997 [2282] | 1 | 7.3 | 175 | Median: 12 | NOS | No | 8.6% | RH: 1.26 (1.05, 1.51) | Fundus photography; EDTRS criteria for proliferative retinopathy
| | | | Range: 6.8, 19.3) | HbA1c
Yokoyama et al., 1995 [2386] | 1 | 7 | 324 | ALL | NOS | NOS | | | Fundus photography
| | | | | HbA1c
| | | | ≤8.1 | | | | RR: 1.0
| | | | 8.2–10.2 | | | | 4.6 (1.6, 13.3)
| | | | ≥10.2 | | | | 7.9 (2.6, 23.4)
Vitale et al., 1995 [2391] | 1 | 6.1 | 189 | Median: 12.2 | NOS | No | | RR: 1.44 (1.28, 1.63) | Fundus photography; EDTRS criteria for macular edema
| | | | Range: (6.4, 21.5) | HbA1c
Lloyd et al., 1996 [777] | 1 | 4 | 658 | ALL | NOS | NOS | 16%
| | | | | HbA1c
| | | | ≤7.5 | | | | RR: 1.0 (Adj) | Adj: DM duration
| | | | ≥7.6 | | | | 3.9 (p<0.001)
Klein et al., 1996 [809] | 1 | 10 | 765 | Mean: 10.8 | Microcolumn technique | No | Macular edema: 20.1% | Macular edema: | OR for 2 units change:
| | | | SD not reported | HbA1 | | Proliferative retinopathy: 29.8% | OR: 0.53 (0.43, 0.72) | Adj: Age, DM duration, retinopathy level
| | | | | | | | Proliferative retinopathy: | Fundus photography
| | | | | | | | OR: 0.58 (0.48, 0.72)
Lloyd et al., 1995 [870] | 1 | 2 | 322 | ALL | HPLC | No | | | Fundus photography
| | | | | HbA1
| | | | ≤9.0 | | | | RR: 1.0
| | | | 9.1–9.9 | | | | 1.0 (0.3, 3.9)
| | | | 10.0–11.1 | | | | 2.2 (0.7, 6.6)
| | | | ≥11.2 | | | | 4.0 (1.4, 11.1)
| | | | | | | | RR: Level 4 vs level 1 5.75 (1.54, 21.4) | Adj: DM duration, baseline retinopathy
Klein et al., 1998 [2108] | 1 | 14 | 634 | Mean: 10.6 | NOS | No | | Macular edema: 1.49 (1.34, 1.65) | Macular edema: Adj model 1: Baseline retinopathy, change in HbA1, proteinuria
| | | | SD: 2 | HbA1 | | | Adj. Model 1 1.48 (1.31, 1.67) | Adj model 2: Model 1 + >30 aspirin/mo
| | | | | | | | Adj. Model 2
| | | | | | | | Prolif. retinopathy 1.86 (1.67, 2.08) | Proliferative retinopathy: Adj model 1: Baseline retinopathy, smoking, change in HbA1, HTN
| | | | | | | | Adj. Model 1 1.81 (1.60, 2.05) | Adj model 2: Model 1 + >30 aspirin/mo
| | | | | | | | Adj. Model 2 | Proliferative retinopathy by EDTRS; fundus photography
| | | | 5.9–9.4 | | | Macular edema: 12.7% | Macular edema: 1.0
| | | | | | | | Proliferative retinopathy: 1.0
| | | | 9.5–10.5 | | | Macular edema: 22.6% | Macular edema: 1.9 (1.12, 3.25)
| | | | | | | | Proliferative retinopathy: 2.81 (1.77, 4.47)
| | | | 10.6–12 | | | Macular edema: 33.9% | Macular edema: 3.11 (1.95,4.95)
| | | | | | | | Proliferative retinopathy: 4.42 (2.90, 6.72)
| | | | 12.1–19.5 | | | Macular edema: 36.8% | Macular edema: 3.37 (2.12,5.34)
| | | | | | | | Proliferative retinopathy: 6.23 (4.21, 9.22)
Arfken et al., 1998 [2157] | 1 | 7 | 312 | Mean: 10.4 | HPLC | No | 29 events | OR: 1.92 (1.36, 2.70) Adj. | OR: For 2 units change in HbA1
| | | | SD not reported | HbA1 | | | | Adj: Race, endpoint at baseline and follow-up
| | | | | | | | | Fundus photography
| | | | African Americans: | | | 17.5% | 1.68 (1.0, 2.85) Adj. | Adj: Race, endpoint at baseline and follow-up
| | | | Mean: 11.3
| | | | SD: 2.8
| | | | Caucasians: | | | 10.2% | 2.17 (1.34, 3.50) Adj. | Adj: Race, endpoint at baseline and follow-up
| | | | Mean: 10
| | | | SD: 2.1
Klein et al., 1994 [2458] | 1 | 10 | 682 | Mean: 10.8 | Resin | No | 29.8% | OR: 1.9 (1.7, 2.2) Adj. | Proliferative retinopathy; fundus photography
| | | | SD: 2.1 | Microcolumn technique | | | | Adj: Age, gender, DM duration, endpoint at baseline, change in GHB
| | | | | HbA1
| | | | 5.6–9.4 | | | 9% | RR: 1.0
| | | | 9.5–10.5 | | | 23% | 2.6 (1.6, 4.6)
| | | | 10.6–12.0 | | | 41% | 6.5 (2.5, 8.8)
| | | | 12.1–19.5 | | | 50% | 7.1 (4.6, 11.1)
Klein et al., 1995b [2437] | 1 | 10 | 688 | ALL | Quick step hemoglobin system | NOS | | OR: 1.56 (1.38, 1.76) Adj. | Adj: DM duration, endpoint at baseline, and GHBx4 years
| | | | Range: 5.6–19.5 | GHB | | | | Macular edema by EDTRS criteria; Fundus photography
| | | 187 | 5.6–9.4 | | | 8.7% | OR: 1.0 (Crude)
| | | 153 | 9.5–10.5 | | | 17.2% | 2.2 (1.1, 4.1)
| | | 167 | 10.6–12.0 | | | 28.1% | 4.0 (2.3, 7.2)
| | | 154 | 12.1–19.5 | | | 28.1% | 4.0 (2.2, 7.1)
Klein et al, 1989 [2787] | 1 | 4 | 610 | ALL | NOS | NOS
| | | | | GHB
| | | | Quartile 1: 6–10.8 | | | | RR: 1.0 (Crude) | Adj: Unclear
| | | | | | | | | Macular edema
| | | | | | | | | Fundus photography
| | | | Quartile 4: 14.2–23.3 | | | | 8.9 (2.7, 29.4)
Klein et al, 1988 [2832] | 1 | 4 | 1780 | Mean: 12.5 | Microcolumn technique | NOS | | OR: 1.5 (1.4, 1.8) Adj. | Adj: Age, gender, DM duration, retinopathy severity
| | | | SD: 2.6 | GHB | | | | Incident proliferative retinopathy
| | | | | | | | | Fundus photography

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 9. Retinopathy: Cohort Studies: Incident Proliferate Retinopathy/Macular Edema, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Linear regression | Comments
Stratton et al., 2001 [1863] | 2 | 6 | 1919 | ALL | HPLC | Yes | | | | Fundus photography; scatter photocoagulation; microaneurysms by EDTRS criteria
| | | | | HbA1c
| | | | ≤6.2 | | | | RR: 1.0 | | Adj: Age, gender, race, weight, BP, smoking, lipids
| | | | | | | | Adj.
| | | | 6.2–7.5 | | | | 4.1 (6.3, 10.5)
| | | | ≥7.5 | | | | 8.1 (6.3, 10.5)
Okudaira at al., 2000 [1899] | 2 | 5.7 | 394 | Mean: 8.5 | HPLC | Yes | 17.9 events per 1000 person years | 1.5 (1.31, 1.74) Crude | | Adj: Age, gender, DM duration, endpoint at baseline, smoking, lipids, family hx. of DM, family hx of vascular disease
| | | | SD: 2.2 | HbA1c | | | 1.67 (1.41, 1.97)
| | | | | | | | Adj
Nakagami et al., 1997 [2259] | 2 | 10 | 137 | Mean: 9.5 | HPLC | No | | | 0.5568 (p=0.0149) | Adj: Age, gender, adiposity, BP, glycemic control
| | | | SD: 3 | HbA1c | | | | Adj.
Chen et al., 1995 [2392] | 2 | 4 | 464 | ALL | HPLC | No
| | | | | HbA1c
| | | | ≤6.18 | | | 0%
| | | | 6.19–7.2 | | | 6.3%
| | | | 7.21–8.4 | | | 6.7%
| | | | ≥8.14 | | | 9.3%
Klein et al., 1996 [809] | 2 | 10 | 533 | ALL | Microcolumn technique | No | | | | OR: For 2 units change: Fundus photography
| | | | | HbA1
| | | | Insulin use: | | | Macular edema: 25.4% | Macular edema: | | Adj: Age, DM duration, retinopathy level
| | | | Mean: 10.2 | | | | OR: 1.06
| | | | SD not reported | | | | (0.67, 1.69) Adj.
| | | | | | | | Proliferative retinopathy:
| | | | | | | Proliferative retinopathy: 23.6% | OR: 0.69 (0.47, 1.04) Adj.
| | | | No insulin use: | | | Macular edema: 13.9% | Macular edema: 0.62
| | | | | | | | (0.43, 0.89) Adj.
| | | | Mean: 8.9 | | | | Proliferative retinopathy: 0.50
| | | | | | | | (0.33, 0.78) Adj.
| | | | SD not reported | | | Proliferative retinopathy: 9.7%
Kim et al., 1998 [92171] | 2 | 5 | 56 | ALL | HPLC | No | 37.5% | RH: 1.297 | | Adj: Age, DM duration, adiposity, AER Fluorescein angiography
| | | | *Mean 12.24 | HbA1 | | | (1.045, 1.610) Adj.
| | | | ≤8.5 | | | 0%
| | | | 8.6–9.8 | | | 7.7%
| | | | 9.9–11.6 | | | 18%
| | | | ≥11.7 | | | 39%
Klein et al., 1994 [2458] | 2 | 10 | 834 | ALL | HPLC | No | | | | Proliferative retinopathy
| | | | | HbA1 | | | | | Funds photography
| | | | Insulin use: | | | 23.6% | OR: 1.5 (1.2, 1.9) Adj. | | Adj: Age, gender, DM duration, endpoint at baseline, change in GHB
| | | | Mean: 1.0.2
| | | | SD: 1.8
| | | | 5.9–8.8 | | | 12% | RR: 1.0 (Crude)
| | | | 8.9–10.2 | | | 18% | 1.2 (0.5, 2.9)
| | | | 10.3–11.5 | | | 24% | 2.0(1.0, 4.3)
| | | | 11.6–17.0 | | | 38% | 3.1 (1.5, 6.1)
| | | | No Insulin use: | | | 9.7% | OR: 1.9 (1.5, 2.5) Adj. | | Adj: Age, gender, DM duration, endpoint at baseline, change in GHB
| | | | Mean: 8.9
| | | | SD: 1.9
| | | | 5.4–7.6 | | | 2% | RR: 1.0 (Crude)
| | | | 7.7–8.6 | | | 2% | 1.2 (0.2, 8.3)
| | | | 8.7–10.0 | | | 10% | 4.0 (1.0, 16.6)
| | | | 10.1–20.0 | | | 30% | 13.8 (4.8, 39.5)
Klein et al., 1995b [2437] | 2 | 10 | 773 | ALL | NOS | NOS | | OR: 1.65 (1.42, 1.92) Adj. | | Adj: Unclear, DM duration, endpoint at baseline, and GHB × 4 yrs
| | | | Range: 5.4–20.8 | GHB | | | | | Macular edema by EDTRS
| | | | | | | | | | Fundus photography
| | | 212 | 5.4–8.1 | | | 3.7% | 1.0 (Crude)
| | | 181 | 8.2–9.4 | | | 12.6% | 3.5 (1.4, 8.6)
| | | 179 | 9.5–10.8 | | | 25.9% | 7.1 (3.3,15.4)
| | | 145 | 10.9–20.8 | | | 39.7% | 13.7(6.8, 27.8)
Klein et al, 1989 [2787] | 2 | 4 | 652 | ALL | NOS | NOS
| | | | | GHB
| | | | Quartile 1: | | | | RR: 1.0 Adj. | | Adj: Unclear
| | | | 6.2–9.2 | | | | | | Macular edema
| | | | | | | | | | Fundus photography
| | | | Quartile 4: | | | | 12.5 (3.0, 51.8)
| | | | 12.7–23.6
Klein et al, 1988 [2832] | 2 | 4 | 1780 | Insulin use: | Microcolumn technique | NOS | | OR: 1.3 (1.0, 1.6) Adj. | | Adj: Age, gender, DM duration, retinopathy severity
| | | | Mean: 11.8 | GHB | | | | | Incident proliferative retinopathy
| | | | SD: 2.2
| | | | *Not given for no insulin group

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 10. Retinopathy: Cohort Studies: Progression of Retinopathy, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
White et al., 2002 [19] | 1 | 4 | 175 | ALL | HPLC | Yes | | | Fundus photography
| | | | | HbA1c
| | | | Conventional | | | Prog. of retinopathy: 13.6% | Prog of retinopathy:
| | | | Mean: 8.4 | | | Prog to proliferative: 14.5% | ROR: 0
| | | | SD: 1.6 | | | | Prog to proliferative:
| | | | | | | | ROR: 0
| | | | Intensive | | | Prog. of retinopathy: 7.1% | Prog of retinopathy:
| | | | Mean: 8.4 | | | Prog. of retinopathy: 7.1% | ROR: 77 (39, 92)
| | | | SD: 1.7 | | | | Prog to proliferative:
| | | | | | | | ROR: 78(34, 92)
DCCT, 2000 [292] | 1 | 4 | 1177 | ALL | HPLC | Yes | | | Fundus photography
| | | | | HbA1c
| | | | Conventional | | | Prog. of retinopathy: (>3 steps): 21% | Prog. of retinopathy: (>3 steps) | Adj: retinopathy severity at baseline
| | | | Median: 8.2 | | | Prog to severe non-proliferative: 10% | RRR: 0 Adj.
| | | | | | | | Prog to severe non-proliferative:
| | | | | | | | RRR: 0 Adj.
| | | | Intensive | | | Prog. of retinopathy: (>3 steps): 6% | Prog. of retinopathy: (>3 steps)
| | | | Median: 7.9 | | | Prog to severe on-proliferative: 2% | RRR: 75% (64%, 83%)
| | | | | | | | Prog to severe non-proliferative:
| | | | | | | | RRR: 76% (52, 88%)
DCCT, 1996 [718] | 1 | 6.5 | 1273 | ALL | HPLC | Yes | | RRR: 39% (34%, 44%) | For 10% change in HbA1c
| | | | *Mean: 7.99 | HbA1c | | | | Adj: Endpoint at baseline, rx
| | | | <8 | | | | 53% (37%, 66%)
| | | | >8 | | | | 35% (28%, 42%)
| | | | Conventional | | | | 37% (31%, 43%)
| | | | Mean over f/u ~9
| | | | <8 | | | | 69% (29%, 87%)
| | | | >8 | | | | 34% (26%, 41%)
| | | | Intensive | | | | 43% (33%, 51%)
| | | | Mean over f/u ~7
| | | | <8 | | | | 49% (27%, 65%)
| | | | >8 | | | | 37% (17%, 53%)
Reichard et al., 1992 [1188] | 1 | 5 | 96 | ALL | HPLC | No | | | Adj: Unclear
| | | | | HbA1c | | | | Fundus photography
| | | | <8.9 | | | | ROR: 0.10 (0.01, 0.90)
| | | | >9.0 | | | | ROR: 1.0
Zhang et al., 2001 [1833] | 1 | 7 | 319 | ALL | NOS | NOS
| | | | | HbA1c
| | | | <6.17 | | | 9.8%
| | | | >9.49 | | | 22.9%
Chase et al., 1989 [1444] | 1 | 8 | 230 | ALL | HPLC | No | | | Fundus photography
| | | | | HbA1c
| | | | ≤10.8 | | | 15%
| | | | 10.9–12.3 | | | 20%
| | | | ≥12.4 | | | 37%
Janka et al, 1989 [2809] | 1 | 4 | 153 | ALL | NOS | No | | | Fundus photography
| | | | | HbA1c
| | | | 6.2–8.3 | | | 2.9% | OR: 1.0 Adj. | Adj: Age, gender, DM duration, endpoint at baseline, weight, BP, smoking, creatinine, insulin dose
| | | | 8.4–9.0 | | | 12.5% | 5.3 (0.5, 52.4)
| | | | 9.1–9.8 | | | 25.0% | 16.4 (1.7, 155)
| | | | 9.9–13.6 | | | 44.4% | 26.1 (3.0, 224.6)
Waltman et al, 1984 [3029] | 1 | 5 | 61 | Mean: 8.91 | NOS | No | | | Fundus photography; Fluorescein angiography
| | | | SE: 0.25 | HbA1c
| | | | ≤8.4 | | | 19.2%
| | | | ≥8.5 | | | 34.4%
Klein et al., 1996 [809] | 1 | 10 | 765 | Mean: 10.8 | Microcolumn technique | No | 75.8% | | Fundus photography
| | | | SD not reported | HbA1
Lloyd et al., 1995 [870] | 1 | 2 | 322 | ALL | HPLC | No | | | Fundus photography
| | | | | HbA1
| | | | ≤9.0 | | | | RR: 1.0 (Crude)
| | | | 9.1–9.9 | | | | 1.4 (0.6, 4.0)
| | | | 10.0–11.1 | | | | 2.0 (1.0. 5.7)
| | | | ≥11.2 | | | | 2.3 (1.2, 7.0) | Adj: DM duration, baseline retinopathy, follow-up
| | | | | | | | RR: Level 4 vs level 1 2.19
| | | | | | | | (1.07,4.50) Adj.
Klein et al., 1998 [2108] | 1 | 14 | 634 | Mean: 10.6 | NOS | No | | OR: 1.69 (1.53, 1.85) Adj Model | Adj model 1: Gender, baseline retinopathy, BP, change in DBP, change in HbA1 (whole cohort)
| | | | SD: 2 | HbA1 | | | OR: 1.78 (1.58, 2.01) Adj Model 2 | Adj model 2: Model 1 if age≥18 years
| | | | | | | | | Fundus photography
| | | | 5.9–9.4 | | | 75.4% | RR: 1.0 (Crude)
| | | | 9.5–10.5 | | | 79.5% | 1.37 (1.12, 1.68)
| | | | 10.6–12 | | | 95.2% | 1.99 (1.67, 2.38)
| | | | 12.1–19.5 | | | 95% | 2.64 (2.18, 3.20)
Marshal et al, 1993 [2537] | 1 | 2.7 | 277 | Mean: 11.2 | HPLC | No | 22% | RR: 1.196 (1.11, 1.29) Adj. | Adj: Age, gender, DM duration, BP, smoking, lipids, family hx of HTN Fundus photography; fluorescein angiography
| | | | SD: 2.1 | HbA1 | | | 1.237 (1.15, 1.33)
Sawicki et al., 2000 [289] | 1 | 6 | 601 | Mean: 7.8 | HPLC | No | | OR: 1.65 (1.4, 1.9) | Adj model 1: SBP
| | | | SD: 1.3 | HbA1 | | | 1.68 (1.4, 2.0) | Adj model 2: DBP
| | | | | | | | Model 1
| | | | | | | | 1 1.65 (1.4, 1.9)
| | | | | | | | Model 2
Klein et al., 1994 [2458] | 1 | 10 | 682 | Mean: 10.8 | HPLC | No | 75.8% | OR: 1.7 (1.6, 1.9) Adj. | Fundus photography
| | | | SD: 2.1 | HbA1 | | | | Adj: Age, gender, DM duration, endpoint at baseline, change in GHB
| | | | 5.6–9.4 | | | 58% | RR: 1.0 (Crude)
| | | | 9.5–10.5 | | | 74% | 1.5 (1.2, 1.9)
| | | | 10.6–12.0 | | | 86% | 2.1 (1.2, 1.9)
| | | | 12.1–19.5 | | | 92% | 2.9 (2.3, 3.5)
Cohen et al., 1999 [2039] | 1 | 3.42 | 485 | ALL | NOS | No | | | Fundus photography
| | | | | GHB
| | | | <10.0 | | | | RR: 1.0 Adj. | Adj: Age, gender, DM duration, retinopathy status at baseline, weight, BP, smoking, sorbinil
| | | | 10.1–11.1 | | | | 2.0 (1.0, 4.1)
| | | | 11.2–12.2 | | | | 1.6 (0.8, 3.3)
| | | | 12.3–13.5 | | | | 3.7 (2.0, 7.0)
| | | | >13.6 | | | | 4.4 (2.2, 8.5)
Klein et al, 1988 [2832] | 1 | 4 | 1780 | Mean: 12.5 | Microcolumn technique | NOS | | OR: 1.5 (1.3, 1.6) Adj. | Adj: Age, gender, DM duration, retinopathy severity Fundus photography
| | | | SD: 2.6 | GHB

GHB emposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR= Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval unless otherwise indicated.

Table 11. Retinopathy: Cohort Studies: Progression of Retinopathy, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Yoshida et al., 2001 [1864] | 2 | 7 | 787 | Mean: 8.6 | HPLC | No | 16.8% | RR: 1.47 | Adj: Age, gender, DM duration, adiposity, BP, lipids, therapy
| | | | SD: 1.9 | HbA1c | | | (1.35, 1.61) Adj.
Okudaira at al., 2000 [1899] | 2 | 5.7 | 394 | Mean: 8.5 | HPLC | Yes | 57.7 events per 1000 pyrs | RH: 1.42 | Adj: Age, gender, DM duration, endpoint at baseline,,smoking, lipids, family hx. DM, family hx vascular disease
| | | | SD: 2.2 | HbA1c | | | (1.23, 1.66) Crude
| | | | | | | | RH: 1.43
| | | | | | | | (1.23, 1.67) Adj.
Henricsson et al., 1997 [2281] | 2 | 3.1 | 1378 | ALL | HPLC | No | | | Fundus photography
| | | | | HbA1c
| | | | ≤7.23 | | | 2.0/100 py | RR: 1.0
| | | | ≥7.24 | | | 6.6/100 py | 1.74 (1.42, 2.13) Adj. | Adj: Age, gender, DM duration
Chen et al., 1995 [2392] | 2 | 4 | 464 | ALL | HPLC | No
| | | | | HbA1c
| | | | ≤6.18 | | | 17.7%
| | | | 6.19–7.2 | | | 25%
| | | | 7.21–8.4 | | | 30%
| | | | ≥8.4 | | | 43.2%
Morisaki et al, 1994 [2502] | 2 | 5 | 114 | ALL | HPLC | No
| | | | | HbA1c
| | | | ≤6.9 | | | 2%
| | | | 7–7.9 | | | 20%
| | | | 8–8.9 | | | 40%
| | | | ≥9.0 | | | 61%
Klein et al., 1996 [809] | 2 | 10 | 533 | ALL | Microcolumn technique | No | | | Fundus photography
| | | | | HbA1
| | | | Insulin use: | | | 68.7%
| | | | Mean: 10.2
| | | | SD not reported
| | | | No insulin use: | | | 52.9%
| | | | Mean: 8.9
| | | | SD not reported
Klein et al., 1994 [2458] | 2 | 10 | 834 | ALL | HPLC | No | | | Fundus photography
| | | | | HbA1
| | | | Insulin use: | | | 68.7% | OR: 1.4 (1.2, 1.6) Adj. | Adj: Age, gender, DM duration, endpoint at baseline, change in GHB
| | | | Mean: 1.0.2
| | | | SD: 1.8
| | | | 5.9–8.8 | | | 55% | RR: 1.0 (Crude)
| | | | 8.9–10.2 | | | 59% | 1.1 (.8, 1.6)
| | | | 10.3–11.5 | | | 73% | 1.4 (1.0, 1.9)
| | | | 11.6–17.0 | | | 87% | 2.1 (1.6, 2.8)
| | | | No Insulin use: | | | 52.9% | OR: 1.8 (1.5, 2.0) Adj. | Adj: Age, gender, DM duration, endpoint at baseline, change in GHB
| | | | Mean: 8.9
| | | | SD: 1.9
| | | | 5.4–7.6 | | | 31% | RR: 1.0 (Crude)
| | | | 7.7–8.6 | | | 46% | 1.8 (1.2, 2.7)
| | | | 8.7–10.0 | | | 67% | 2.8 (1.9, 4.2)
| | | | 10.1–20.0 | | | 80% | 4.3 (3.0, 6.2)
Klein et al, 1988 [2832] | 2 | 4 | 1780 | ALL | Microcolumn technique | NOS | | | Fundus photography
| | | | | GHB
| | | | Insulin use: | | | | OR: 1.3 (1.1, 1.4) Adj. | Adj: Age, gender, DM duration and retinopathy severity
| | | | Mean: 11.8
| | | | SD: 2.2
| | | | No insulin use: | | | | OR: 1.4 (1.3, 1.6) Adj. | Adj for age, gender, DM duration and retinopathy severity
| | | | Mean: 10.2
| | | | SD: 2.3

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 12. Retinopathy: Cohort Studies: Blindness/ Visual Acuity, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Muhlhauser et al., 2000b [185] | 1 | 10 | 3674 | ALL | HPLC | No
| | | | | HbA1c
| | | | Normal protein: | | | 0.4%
| | | | Mean: 8.1
| | | | SD: 1.9
| | | | Microalbuminuria: | | | 1.2%
| | | | Mean: 8.3
| | | | SD: 1.9
| | | | Macroalbuminuria: | | | 5.8%
| | | | Mean: 8.4
| | | | SD: 1.7
Muhlhauser et al., 2000a [178] | 1 | 10 | 3570 | ALL | HPLC | No | | | Fundus photography
| | | | | HbA1
| | | | <7 | | | 0.6%
| | | | 7–9 | | | 1.1%
| | | | >9 | | | 2.1%
Klein et al., 1996 [809] | 1 | 10 | 765 | Mean: 10.8 | Microcolumn technique | No | 9.2% | | Fundus photography
| | | | SD not reported | HbA1
Moss et al., 1998 [2145] | 1 | 14 | 634 | ALL Mean: 10.6 | Microcolumn technique | No | | OR: 1.46 (1.28, 1.66) Adj. | Adj: Age, retinopathy, proteinuria, change in HbA1 Visual acuity by EDTRS criteria
| | | | SD: 2 | HbA1
| | | | 6.0–10.8 | | | 5.6%
| | | | 10.9–12.2 | | | 16.1%
| | | | 12.3–14 | | | 14.3%
| | | | 14.1–23.3 | | | 22.0%
Moss et al., 1994a [2482] | 1 | 10 | 996 | ALL Range: | Microcolumn technique GHB | No | Blindness: 1.8% | Doubling of visual angle: | Adj: Age, gender, DM duration, smoking, proteinuria, retinopathy level, macular edema
| | | | 6.0–23.3 | | | Visual impairment: 9.4% | OR: 1.28 (1.15, 1.42) Adj. | Fundus photography
| | | | | | | Doubling of visual angle: 9.2%
| | | 211 | 6.0–10.8 | | | Doubling of visual angle: 3.3%
| | | 210 | 10.9–12.2 | | | 7.6%
| | | 214 | 12.3–14.1 | | | 11.5%
| | | 201 | 14.2–23.3 | | | 15.0%

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 13. Retinopathy: Cohort Studies: Blindness / Visual Acuity, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Moss et al., 1994a [2482] | 2 | 10 | 996 | ALL | Microcolumn technique GHB | No | | | Fundus photography
| | | | Insulin use: | | | Blindness: 4.0% | Doubling of visual angle: | Adj: Age, gender, DM duration, smoking, proteinuria, retinopathy level, macular edema
| | | | Range: 6.9–19.2 | | | Visual impairment: 37.2% | OR: 1.27 (1.10, 1.46) Adj.
| | | | | | | Doubling of visual angle: 32.8%
| | | 110 | 6.9–10.1 | | | Doubling of visual angle: 24.5%
| | | 105 | 10.2–11.8 | | | 25.7%
| | | 105 | 11.9–13.4 | | | 38.6%
| | | 111 | 13.5–19.2 | | | 40.3%
| | | | No insulin use: | | | Blindness: 4.8% | Doubling of visual angle: | Adj: Age, gender, DM duration, smoking, proteinuria, retinopathy level, macular edema
| | | | Range: 6.2–23.6 | | | Visual impairment: 23.9% | OR: 1.15 (1.01, 1.29) Adj.
| | | | | | | Doubling of visual angle: 21.4%
| | | 115 | 6.2–8.5 | | | Doubling of visual angle: 21.5%
| | | 121 | 8.6–9.8 | | | 19.5%
| | | 120 | 9.9–11.5 | | | 15.2%
| | | 102 | 11.7–23.6 | | | 31.9%

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 14. Retinopathy: Cohort Studies: Cataract Extraction, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Stratton et al., 2000 [4087] | 2 | 10 | 3642 | Mean: 7.1 | HPLC | No | | RRR: 9% (2%, 16%) Adj. | For 1% decrease in HbA1c
| | | | SD: 1.8 | HbA1c | | | | Adj: Gender, race, BP, smoking, age at diagnosis, lipids, albuminuria
| | | | Updated whole group | | | | RRR: 19% (11%, 26%) | For 1% decrease in HbA1c
| | | | | | | | | Adj: Gender, race, BP, smoking, age at diagnosis, lipids, albuminuria
| | | | <6 | | | 4.1 (2.5, 6.5) per 100 person years
| | | | Median: 5.6%
| | | | 6–7 | | | 4.5(3.0, 6.9) per 100 person years
| | | | Median: 6.5%
| | | | 7–8 | | | 4.9 (3.1, 6.9) per 100 person years
| | | | Median: 7.5%
| | | | 8–9 | | | 6.9 (4.4, 10.8) per 100 person years
| | | | Median: 8.4%
| | | | 9–10 | | | 6.6 (3.8, 11.6) per 100 person years
| | | | Median: 9.4%
| | | | ≥10 | | | 14.4 (8.1, 25.7) per 100 person years
| | | | Median: 10.6%
Klein et al., 1996 [809] | 2 | 10 | 533 | ALL | Microcolumn technique | No | | | Fundus photography
| | | | | HbA1
| | | | Insulin use: | | | 32.8%
| | | | Mean: 10.2
| | | | SD not reported
| | | | No insulin use: | | | 21.4%
| | | | Mean: 8.9
| | | | SD not reported

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 15. Retinopathy: Randomized Controlled Trials: Incident Retinopathy, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Gaede et al., 1999 [416] | 1 | 4 | 149 | ALL | HPLC | NOS
| | | | | HbA1c
| | | | Conventional | | | 25.6%
| | | | Mean: 8.8
| | | | SD: 1.7
| | | | Intensive: | | | 15.6%
| | | | Mean: 8.4
| | | | SD: 1.6
Reichard et al., 1993 [1069] | 1 | 7.5 | 102 | ALL | HPLC | No | | OR: 2.9 (1.5, 5.7) Adj | Adj: DM duration, retinopathy, BP, insulin use, smoking, albuminuria
| | | | *Mean: 7.91 | HbA1c
| | | | Conventional
| | | | Mean: 8.7 SD: 1.1
| | | | Intensive
| | | | Mean: 7.2 SD: 0.6
DCCT, 1993 [4638] | 1 | 6.5 | 1441 | ALL | HPLC | Yes | | | Development OR progression of retinopathy
| | | | F/u mean for intensive: 7 | HbA1c
| | | | F/u mean for conventional:9
| | | | 1° Conventional | | | 4.7% over 100 person years
| | | | Mean: 8.8 SD: 1.7
| | | | 1° Intensive | | | 3.4% over 100 person years
| | | | Mean: 8.8 SD: 1.6
| | | | 2° Conventional | | | 2.4% over 100 person years | RRR: 0% | Progression to severe non-proliferative OR proliferative retinopathy
| | | | Mean: 8.9 SD: 1.5
| | | | 2° Intensive | | | 1.1% over 100 person years | 47% (14%, 67%) | Progression to severe non-proliferative OR proliferative retinopathy
| | | | Mean: 9.0 SD: 1.5

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 16. Retinopathy: Randomized Controlled Trials: Incident Retinopathy, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Comments
Gaede et al., 1999 [416] | 2 | 4 | 160 | ALL | HPLC | No
| | | | | HbA1c
| | | | Standard: | | | 26%
| | | | Mean: 8.8
| | | | SD: 1.7
| | | | Intensive: | | | 16%
| | | | Mean: 8.4
| | | | SD: 1.6
Ohkubo et al., 1995 [888] | 2 | 6 | 102 | ALL | HPLC | No
| | | | | HbA1c
| | | | 1° Conventional End of f/u: | | | 32% over 100 person years
| | | | Mean: 9.4
| | | | SD: 1.5
| | | | 1° Intensive End of f/u: | | | 7.7% over 100 person years
| | | | Mean: 7.1
| | | | SD: 1.1

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 17. Retinopathy: Randomized Controlled Trials: Incident Proliferative Retinopathy, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Reichard et al., 1993 [1069] | 1 | 7.5 | 89 | ALL | HPLC | No | | OR: 2.4 (1.4, 4.3) Adj. Model 1 | Adj model 1: DM duration, baseline retinopathy, BP, insulin use, smoking, albuminuria, treatment
| | | | *Mean: 7.91 | HbA1c | | | OR: 1.7 (1, 2.8) Adj. Model 2 | Adj model 2: Model 1 except treatment
| | | | Conventional | | | 52%
| | | | Mean: 8.7
| | | | SD: 1.1
| | | | Intensive | | | 27%
| | | | Mean: 7.2
| | | | SD: 0.6
DCCT, 1993 [4638] | 1 | 6.5 | 1441 | ALL | HPLC | No
| | | | F/u mean for intensive: 7 | HbA1c
| | | | F/u mean for conventional: 9
| | | | 2° Conventional | | | 3 per 100 person years | RRR: 0%
| | | | Mean: 8.9
| | | | SD: 1.5
| | | | 2° Intensive | | | 2 per 100 person years | 23% (-13%, 48%)
| | | | Mean: 9.0
| | | | SD: 1.5

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 18. Retinopathy: Randomized Controlled Trials: Incident Proliferative Retinopathy, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate
Shichiri et al., 2000 [247] | 2 | 8 | 110 | ALL | HPLC | No
| | | | | HbA1c
| | | | Standard: | | | | RRR: 0
| | | | Mean: 9.0
| | | | SD: 1.5
| | | | Intensive: | | | | 50%
| | | | Mean: 9.3
| | | | SD: 1.5
Gaede et al., 1999 [416] | 2 | 4 | 160 | ALL | HPLC | No
| | | | | HbA1c
| | | | Standard: | | | 12%
| | | | Mean: 8.8
| | | | SD: 1.7
| | | | Intensive: | | | 9.1%
| | | | Mean: 8.4
| | | | SD: 1.6
United Kingdom Prospective Diabetes Study (UKPDS) Group, 1998 [2113] | 2 | 10 | 4209 | ALL | HPLC | Yes
| | | | | HbA1c
| | | | Over f/u: | | | | RR: 1.0
| | | | Conventional:
| | | | Median: 7.9
| | | | IQR: (6.9, 8.8)
| | | | Over f/u: | | | | Scatter photocoagulation:
| | | | Intensive: | | | | 0.71 (0.53, 0.96)
| | | | Median: 7 | | | | Vitreous hemorrhage
| | | | IQR: (6.2, 8.2) | | | | 0.77 (0.28, 2.11)

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 19. Retinopathy: Randomized Controlled Trials: Progression of Retinopathy, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Gaede et al., 1999 [416] | 1 | 4 | 149 | ALL | HPLC | NOS
| | | | | HbA1c
| | | | Conventional | | | 42% | OR: 1.0 (Adj) | Adj: Age, gender, DM duration, endpoing at baseline
| | | | Mean: 8.8
| | | | SD: 1.7
| | | | Intensive Mean | | | 25% | 0.45 (0.21, 0.95)
| | | | Mean: 8.4
| | | | SD: 1.6
Reichard et al., 1991 [1266] | 1 | 5 | 96 | ALL | HPLC | No | | OR: 2.2 (1.3, 3.7) Adj. | Adj: Unclear
| | | | *Mean; 8.01 | HbA1c
| | | | Conventional:
| | | | Mean: 8.7 (SD: 0.1)
| | | | Intensive:
| | | | Mean: 8.7 (SD: 0.1)
DCCT, 1995 [2438] | 1 | 7 | 1441 | ALL | HPLC | Yes
| | | | Mean over f/u for intensive: ~7 | HbA1c
| | | | Mean over f/u for conventional: ~9
| | | | 1° Conventional | | | | RRR: 0%
| | | | Mean: 8.8
| | | | SD: 1.7
| | | | 1° Intensive | | | | 78.5% (64.9%, 86.9%)
| | | | Mean: 8.8
| | | | SD: 1.6
| | | | 2° Conventional | | | | RRR: 0%
| | | | Mean: 8.9
| | | | SD: 1.5
| | | | 2° Intensive | | | | 64.5% (49.8%, 74.8%)
| | | | Mean: 9
| | | | SD: 1.5
DCCT, 1993 [4638] | 1 | 6.5 | 1441 | ALL | HPLC | No
| | | | Mean over follow-up ~7% for intensive and ~9% for conventional | HbA1c | | | RRR: 0%
| | | | 1° Conventional | | | 4.7/100 personyears | RRR: 0%
| | | | Mean: 8.8
| | | | SD: 1.7
| | | | 1° Intensive | | | 1.2/100 personyears | 76% (62%, 85%)
| | | | Mean: 8.8
| | | | SD: 1.6
| | | | 2° Conventional | | | 7.8/100 personyears | RRR: 0%
| | | | Mean: 8.8
| | | | SD: 1.5
| | | | 2° Intensive | | | 3.7/100 personyears | 54% (39%, 66%)
| | | | Mean: 8.8
| | | | SD: 1.5

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 20. Retinopathy: Randomized Controlled Trials: Progression of Retinopathy, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Shichiri et al., 2000 [247] | 2 | 8 | 110 | ALL | HPLC | No
| | | | | HbA1c
| | | | 1° Conventional | | | 47.8% | RRR: 0%
| | | | Mean: 8.8 | | | 6 events per 100 person years
| | | | SD: 1.4
| | | | 1° Intensive | | | 15.4% | 68%
| | | | Mean: 9.5 | | | 1.9 events per 100 person years
| | | | SD: 1.7
| | | | 2° Conventional | | | 56% | RRR: 0%
| | | | Mean: 9 | | | 7 events over 100 person years
| | | | SD: 1.5
| | | | 2° Intensive | | | 24% | 57%
| | | | Mean: 9.3 | | | 3 evetns over 100 person years
| | | | SD: 1.5
Gaede et al., 1999 [416] | 2 | 4 | 160 | | HPLC | No
| | | | | HbA1c
| | | | Standard: | | | 42% | OR: 1.0 Adj. | Adj: Age, gender, DM duration, baseline retinopathy
| | | | Mean: 8.8
| | | | SD: 1.7
| | | | Intensive: | | | 25% | 0.45 (0.21, 0.95)
| | | | Mean: 8.4
| | | | SD: 1.6
Ohkubo et al., 1995 [888] | 2 | 6 | 102 | ALL | HPLC | Yes
| | | | Mean over f/u for intensive: | HbA1c
| | | | 7.1 SD: 1.1
| | | | Mean over f/u for conventional:
| | | | 9.4
| | | | SD: 1.5
| | | | 1° Conventional | | | Worsening: 38% over 100 person years
| | | | Mean: 8.9
| | | | SD: 1.8
| | | | 1° Intensive | | | Worsening: 13.4% over 100 person years
| | | | Mean: 9.2
| | | | SD: 1.8
| | | | 2° Conventional | | | Progression: 44% over 100 person years
| | | | Mean: 9
| | | | SD: 1.9
| | | | 2° Intensive | | | Progression: 19.2% over 100 person years
| | | | Mean: 9.4
| | | | SD: 1.8

GHB exposure is expressed as a %; *indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 21. Retinopathy: Randomized Controlled Trials: Blindness / Visual Acuity, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Reichard et al., 1993 [1069] | 1 | 7.5 | 89 | ALL | HPLC | No | | OR: 2.2 (1.2, 3.9) Adj. | Adj: DM duration, retinopathy, BP, insulin use, smoking, albuminuria
| | | | *Mean: 7.91 | HbA1c
| | | | Conventional | | | 14%
| | | | Mean: 8.7
| | | | SD: 1.1
| | | | Intensive | | | 35%
| | | | Mean: 7.2
| | | | SD: 0.6

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 22. Retinopathy: Randomized Controlled Trials: Blindness / Visual Acuity, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Gaede et al., 1999 [416] | 2 | 4 | 160 | ALL | HPLC | No
| | | | | HbA1c
| | | | Standard: | | | 9%
| | | | Mean: 8.8
| | | | SD: 1.7
| | | | Intensive: | | | 1.3%
| | | | Mean: 8.4
| | | | SD: 1.6
United Kingdom Prospective Diabetes Study (UKPDS) Group, 1998 [2113] | 2 | 10 | 4209 | ALL | HPLC | No
| | | | | HbA1c
| | | | Conventional | | | | RR: 1.0 Crude
| | | | Over f/u:
| | | | Median: 7.9
| | | | IQR: (6.9, 8.8)
| | | | During f/u
| | | | Intensive: | | | | 0.84 (0.51, 1.40)
| | | | Over f/u:
| | | | Median: 7
| | | | IQR (6.9, 8.2)
| | | | During f/u

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 23. Retinopathy: Randomized Controlled Trials: Cataract Extraction, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
United Kingdom Prospective Diabetes Study (UKPDS) Group, 1998 [2113] | 2 | 10 | 4209 | ALL | HPLC HbA1c | No
| | | | Conventional | | | | RR: 1.0 Crude
| | | | Median: 7.9
| | | | IQR: (6.9, 8.8)
| | | | During f/u
| | | | Intensive: | | | | 0.76 (0.53, 1.08)
| | | | Median: 7
| | | | IQR (6.9, 8.2)
| | | | During f/u

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 24. Nephropathy: Cohort Studies: Incidence/Progression of Microalbuminuria, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Linear Regression | Outcome definition | Comments
Chaturvedi et al., 2001a [84] | 1 | 7 | 1134 | ALL | Immunoassay | Yes | | RR: 1.57 (1.26, 1.97) Adj. | | AER: 24 hrs | Adj: Adiposity, lipids, AER
| | | | *Mean: 6.32 | HbA1c | | | | | 20–200 μg/min
| | | | Progressors:
| | | | Mean: 7.1
| | | | SD: 1.8
| | | | Non-Progressors
| | | | Mean: 6.2
| | | | SD: 1.7
DCCT, 2000 [292] | 1 | 4 | 1208 | ALL | HPLC | Yes | | | | AER: Timed 4 hrs
| | | | | HbA1c | | | | | 29–208 μg/min
| | | | Conventional: | | | 11% | RRR: 0 Adj. | | | Adj: Microalbuminuria status at baseline
| | | | Mean: 9.0
| | | | SD: 1.2
| | | | Intensive: | | | 5% | 53 (26, 70)
| | | | Mean: 7.3
| | | | SD: 0.9
Villar et al., 1999 [325] | 1 | 2 | 340 | Mean: 7.6 | HPLC | NOS | 4.7% | | | AER: 24 hrs
| | | | SD: 1.3 | HbA1c | | | | | 30–299 mg/24 hrs
Jones et al., 1998 [482] | 1 | 8 | 233 | ALL | HPLC | NOS | 14.6% | | | ACR: Random/Spot
| | | | | HbA1c | | | | | >2.5 mg/mmol creatinine
| | | 34 | Raised ACR
| | | | Median: 9.2
| | | | IQR: 8–10.2
| | | 27 | Intermediate ACR
| | | | Median: 9.7
| | | | IQR: 8.2–10.3
| | | 172 | Normal ACR
| | | | Median: 8.6
| | | | IQR: 7.5–9.6
Reichard et al., 1996 [699] | 1 | 10 | 91 | ALL | HPLC | No | | OR: 3.55 (1.66, 7.56) Adj. | | AER: Timing unclear | Adj: Unclear, age, DM duration, weight, BP, insulin use, smoking, age at diagnosis
| | | | *Mean: 9.45 | HbA1c | | | | | >200 μg/min
| | | | Conventional:
| | | | Mean: 9.4
| | | | SD: 1.2
| | | | Intensive:
| | | | Mean: 9.5
| | | | SD: 1.4
Reichard et al., 1992 [1188] | 1 | 5 | 96 | ALL | HPLC | NOS | | | | AER: Timing unclear | Adj: Unclear
| | | | | HbA1c | | | | | >200 μg/min
| | | | ≤8.9 | | | | 0.09 (0.02, 0.52) Adj.
| | | | ≥9.0 | | | | OR: 1.0
Bojestig et al., 1998 [460] | 1 | 20 | 180 | ALL | HPLC | No | | | | Albustix
| | | | | HbA1c | | | | | Positive at >300 mg/L
| | | | ≤8.1 | | | 0%
| | | | 8.2–9.4 | | | 4.3%
| | | | ≥9.5 | | | 36.3%
Lloyd et al., 1996 [777] | 1 | 4 | 658 | ALL | NOS | No | | | | AER: Timing unclear
| | | | | HbA1c | | | | | 20–200 μg/min
| | | | ≤10.9 | | | | RR: 1.0 Adj. | | | Adj: DM duration
| | | | ≥11 | | | | 3.5 (p<0.001)
Rudberg et al., 1993 [1023] | 1 | 15 | 156 | ALL | HPLC | No | | | | AER: Timed overnight
| | | | | HbA1c | | | | | 20–200 μg/min
| | | | ≤7.5 | | | | RR: 1.0 (Crude/Adj) | | | Adj: Age
| | | | ≥7.6 | | | | 4.49 (1.13, 17.84) Crude
| | | | | | | | 3.51 (0.9, 14.42) Adj
Rudberg et al., 1992 [1204] | 1 | 8 | 75 | Mean: 11.8 | HPLC | No | | | -0.18 (p=0.26) Adj. | AER: 24 hrs | Adj: DM duration, GFR, log AER, blood glucose
| | | | SD: 0.3 | HbA1c | | | | | 20–200 μg/min
Chase et al., 1989 [1444] | 1 | 7 | 230 | ALL | HPLC | NO | | | | AER: Timing unclear
| | | | | HbA1c | | | | | >30μg/min
| | | | ≤10.8 | | | 9%
| | | | 10.9–12.3 | | | 10%
| | | | ≥12.4 | | | 29%
Yokoyama et al., 1995 [2386] | 1 | 7 | 234 | ALL | HPLC | No | | | | Albustix
| | | | | HbA1c | | | | | Positive at ≥300 mg/L
| | | | ≤8.1 | | | | RR: 1.0 Adj. | | | Adj: Gender, DM duration, age at diagnosis, year of onset, retinopathy status
| | | | 8.2–10.2
| | | | ≥10.3 | | | | 2.8 (1.2, 6.5)
DCCT, 1996 [718] | 1 | 6.5 | 1273 | ALL | HPLC | Yes | | RRR: 25% (19%, 32%) Adj | | AER: Timed 4 hrs | Adj: Baseline urinary albumin; for 10% change in HbA1c
| | | | *Mean: 7.99 | HbA1c | | | | | ≥40 mg/24 hrs
| | | | <8.0 | | | | 25% (8%, 39%)
| | | | >8.0 | | | | 26% (16%, 34%)
| | | | Conventional | | | | 24% (15%, 32%)
| | | | <8.0 | | | | 21% (-31%, 52%)
| | | | >8.0 | | | | 24% (13%, 34%)
| | | | Intensive | | | | 28% (17%, 37%)
| | | | <8 | | | | 23% (2%, 40%)
| | | | >8.0 | | | | 33% (11%, 50%)
Scott et al., 2001 [25] | 1 | 4 | 943 | ALL | Electro-phoresis | No | | | | ACR:
| | | | | HbA1 | | | | | Timing unclear
| | | | | | | | | | 18–249 mg/g
| | | | 4.3–7.2 | | | 1.4% /100 person years | OR: 1.0 Crude | | | Adj: DM duration, smoking, glycemic control, period of analysis
| | | | | | | | OR: 1.0 Adj
| | | | 7.3–8.1 | | | 1.7%/100 person years | 0.98 (0.4, 2.4) Crude
| | | | | | | | 0.85 (0.3, 2.1) Adj
| | | | 8.2–9.0 | | | 3.0%/100 person years | 3.0 (1.1, 5.0) Crude
| | | | | | | | 1.9 (0.9, 4.2) Adj
| | | | 9.1–16.5 | | | 6.5%/100 person years | 6.3 (3.1, 12.7) Crude
| | | | | | | | 4.7 (2.3, 9.7) Adj
Izumi et al., 1995 [871] | 1 | 3.2 | 107 | ALL | NOS | No | | | | Paper-strip method
| | | | | HbA1 | | | | | 1+
| | | | ≤9.9 | | | 13.6%
| | | | 10.0–12.4 | | | 10.3%
| | | | ≥12.5 | | | 5.9%
Klein et al, 1991 [2691] | 1 | 4 | 661 | ALL | Resin microcolumn technique | No | 14% | RR: 1.24 (1.13, 1.36) Adj. | | AER: Random / Spot | Adj: Age, gender, BMI, BP, smoking, age at diagnosis, units of insulin, retinopathy status
| | | | | HbA1 | | | | | ≥0.3 g/L
| | | | ≤10.8 | | | 8.4% | RR: 1.0 (Crude)
| | | | 10.9–12.2 | | | 10.1% | 1.20 (0.6,2.42)
| | | | 12.3–14.1 | | | 14.4% | 1.71 (0.91, 3.24)
| | | | ≥14.2 | | | 24.8% | 2.95 (1.64, 5.33)
Powrie et al., 1994 [929] | 1 | 9.6 | 97 | ALL | Electro-phoresis | No | 8.2% | | 1.187 (p=0.006) | ACR: Random/Spot | Adj: Gender, DM duration, BP, smoking, log_10_UACR
| | | | Mean: 10.2 | GHB | | | | For log_10_ | >3mg/mmol creatinine
| | | | Range: 6.7–16.8 | | | | | GHB Adj.
| | | | ≤12.0 | | | | OR: 1.0 (Crude)
| | | | ≥12.0 | | | | 9.7 (2.1, 45.8)
Klein et al., 1995a [853] | 1 | 10 | 666 | ALL | Microcolumn technique | No | | | | Labstix
| | | | 5.6–9.4 | GHB | | 14% | RR: 1.0 Crude | | Positive at ≥0.3g/L
| | | | 9.5–10.5 | | | 17.5% | 1.22 (0.71, 2.10)
| | | | 10.6–12.0 | | | 35.9% | 2.42 (1.56, 3.75)
| | | | 12.1–19.5 | | | 46.2% | 3.45 (2.30, 5.17)

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 25. Nephropathy: Cohort Studies: Incidence/Progression of Microalbuminuria, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Outcome definition | Comments
Villar et al., 1999 [325] | 2 | 2 | 258 | Mean: 7.5 | HPLC | NOS | 7% | | AER: 24 hrs
| | | | SD: 1.5 | HbA1c | | | | 30–299 mg/24 hrs
Molyneaux et al., 1989 [424] | 2 | 2.3 | 963 | Mean change in group: 9.5 (6.7, 7.8) | HPLC | Yes | 8.3% (5.7, 10) | RRR=9.9 % for 10% change (1.1 unit) reduction in HbA1c Adj | AER: Timing unclear | Adj: Unclear
| | | | | HbA1c | | | | >30 mg/L
Yokoyama et al., 1998 [503] | 2 | 6.8 | 426 | Mean: 8.4 (2.2) | HPLC | Yes | 14.1/1000 person years | RH: 1.56 (1.34, 1.81) Crude | Albustix | Adj: DM duration, BP
| | | | | HbA1c | | | RH: 1.63 (1.39, 1.92) Adj | Positive at 300 mg/L
| | | | ≤6.4 | | | 0%
| | | | 6.5–7.4 | | | 3.4%
| | | | 7.5–8.4 | | | 10%
| | | | 8.5–9.4 | | | 22%
| | | | 9.5–10.4 | | | 27%
| | | | ≥10.5 | | | 27%
Ravid et al., 1998 [531] | 2 | 7.8 | 574 | ALL | HPLC | NOS | | | AER: 24 hrs
| | | | | HbA1c | | | | 30–300 mg/24 hrs
| | | | ≤0.089 | | | 15% | OR: 1.0 Adj | | Adj: Unclear
| | | | ≥0.09 | | | 54.9% | OR: 8.46 (5.61, 12.77) Adj
Niskanen et al., 1996 [749] | 2 | 10 | 133 | Mean: 9.2 | Liquid cation exchange chromatography | No | | | AER: Timed overnight
| | | | SD: 0.2 | HbA1c | | | | ≥30 mg/24 hrs
Haneda et al., 1992 [1172] | 2 | 5 | 52 | ALL | HPLC | No | | | AER: 24 hrs
| | | | | HbA1 | | | | ≥15 μg/min
| | | | ≤9.5 | | | 18.2%
| | | | >9.5 | | | 58.3%
Klein et al., 1995a [853] | 2 | 10 | 794 | ALL | Microcolumn technique | NOS | | | Labstix
| | | | Older onset taking insulin | GHB | | | | Positive at ≥ 0.3 g/L
| | | | 5.9–8.8 | | | 31.1% | RR: 1.0 (Crude)
| | | | 8.9–10.2 | | | 30.9% | RR: 0.99 (0.56, 1.76)
| | | | 10.3–11.5 | | | 41.9% | RR: 1.25 (0.74, 2.11)
| | | | 11.6–17 | | | 41.8% | RR: 1.43 (0.85, 2.42)
| | | | Older onset not taking insulin
| | | | 5.4–7.6 | | | 25.7% | RR: 1.0 (Crude)
| | | | 7.7–8.6 | | | 24.2% | RR: 0.91 (0.50, 1.65)
| | | | 8.7–10.0 | | | 44.2% | RR: 1.63 (1.0, 2.68)
| | | | 10.1–20.8 | | | 43.5% | RR: 1.87 (1.12, 3.13)
Klein et al., 1993 [1103] | 2 | 4.1 | 728 | ALL | Microcolumn technique | NOS | | | Labstix
| | | | Older onset taking insulin | GHB | | | | Positive at ≥ 0.3 g/L
| | | | <10.1 | | | 15.7% | RR: 1.0 (Crude)
| | | | 10.2–11.8 | | | 14.0% | 0.89 (0.43, 1.84)
| | | | 11.9–13.4 | | | 15.9% | 1.01 (0.5, 2.05)
| | | | >13.5 | | | 20.9% | 1.33 (0.7, 2.52)
| | | | Older onset not taking insulin
| | | | <8.5 | | | 9.8% | RR: 1.0 (Crude)
| | | | 8.6–9.8 | | | 6.2% | 0.63 (0.24, 1.67)
| | | | 9.9–11.6 | | | 10.7% | 1.09 (0.48, 2.46)
| | | | >11.7 | | | 17.9% | 1.83 (0.87, 3.85)

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 26. Nephropathy: Cohort Studies: Incidence/Progression of Macroalbuminuria, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Outcome definition | Comments
DCCT, 2000 [292] | 1 | 4 | 1208 | ALL | HPLC | Yes | | | AER: Timed 4 hrs
| | | | | HbA1c | | | | >208 μg/min
| | | | Conventional: | | | 5% | RRR: 0% Adj. | | Adj: Microalbuminuria status at baseline
| | | | Mean: 9.8
| | | | SD: 1.2
| | | | Intensive: | | | 1% | 86% (60%, 95%)
| | | | Mean: 7.3
| | | | SD: 0.9
DCCT, 1996 [718] | 1 | 6.5 | 1273 | ALL | HPLC | Yes | | RRR: 36% (26%, 45%) Adj | AER: Timed 4 hrs | Adj: Baseline urinary albumin; for 10% change in HbA1c
| | | | Mean: 7.99 | HbA1c | | | | ≥100 mg/24 hrs
| | | | Conventional | | | | 36% (32%, 59%)
| | | | Mean over f/u ~9
| | | | Intensive | | | | 36% (19%, 49%)
| | | | Mean over f/u ~7
Warram et al, 2000 [304] | 1 | 4 | 279 | ALL | HPLC/Electro-phoresis | Yes | | | ACR: Random/ Spot
| | | | | HbA1 | | | | >28 mg/mmol creatinine
| | | | 5.1–7.9 | | | 4/317 person years | OR: 1.0 Adj. | | Adj: Age, gender, DM duration, BP, HTN rx, baseline ACR
| | | | 8–8.9 | | | 10/196 personyears | 4.2 (1.2, 14.4)
| | | | 9.0–9.9 | | | 9/212 personyears | 3.2 (0.9, 11.2)
| | | | 10–13.1 | | | 15/224 personyears | 5.5 (1.6, 18.8)
The Microalbuminuria Collaborative Study Group, 1999 [310] | 1 | 7 | 148 | ALL | Corning electro-endosmosis | No | | RR: 1.32 (1.01, 1.72) Adj. | AER: Timed overnight | Adj: Age, gender, weight, BP, smoking, height, retinopathy grade, AER
| | | | *Mean: 9.20 | HbA1 | | | | ≥10 ug/min
| | | | Normoalbuminuria
| | | | Mean: 9.0
| | | | Range: 8.7, 9.4
| | | | Microalbuminuria
| | | | Mean: 9.5
| | | | Range: 8.6, 10.5
| | | | Macroalbuminuria
| | | | Mean: 10.2
| | | | Range: 9.1, 11.4
Villar et al., 1999 [325] | 1 | 2 | 340 | Mean: 7.6 | HPLC | NOS | 0% | | AER: 24 hrs
| | | | SD: 1.3 | HbA1 | | | | ≥300 mg/24 hrs
Jones et al., 1998 [482] | 1 | 8 | 233 | ALL | HPLC | NOS | 11.6% | | ACR: Random/ Spot
| | | | | HbA1 | | | | ≥2.5 mg/mmol creatinine
| | | 34 | Raised ACR
| | | | Median: 9.2
| | | | IQR: 8–10.2
| | | 27 | Intermediate ACR
| | | | Median: 9.7
| | | | IQR: 8.2–10.3
| | | 172 | Normal ACR
| | | | Median: 8.6
| | | | IQR: 7.5–9.6
Lloyd et al., 1996 [777] | 1 | 4 | 658 | ALL | Saline incubated | No | | | AER: Timing unclear
| | | | | GHB | | | | >200 μg/min
| | | | ≤10.9 | | | | RR: 1.0 Adj. | | Adj: DM duration
| | | | ≥11.0 | | | | 3.5 (p<0.001)

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary preventaion; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 27. Nephropathy: Cohort Studies Incidence/Progression of Macroalbuminuria (combined endpoint), type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Outcome definition | Comments
Villar et al., 1999 [325] | 2 | 2 | 258 | Mean: 7.5 | HPLC | NOS | 0.8% | | AER: 24 hrs
| | | | SD: 1.5 | HbA1c | | | | Microalbuminuria: 30–299 mg/24 hrs
| | | | | | | | | Macroalbuminuria: ≥300 mg/24 hrs
Gall et al., 1997 [654] | 2 | 6 | 176 | ALL | Thin Isoelectric focusing | NOS | 23% | RR: 1.2 (1.0, 1.4) | AER: 24 hrs | Age, gender, lipids, retinopathy, log_10_UAER
| | | | *Mean: 7.79 | HbA1c | | | Adj | Microalbuminuria: 30–299 mg/24 hrs
| | | | | | | | | Macroalbuminuria: ≥300 mg/24 hrs
| | | | Normoalbuminuria
| | | | Mean: 7.6 SD: 1.7
| | | | Nephropathy
| | | | Mean: 8.4 SD: 2
Park et al., 1998 [534] | 2 | 5.5 | 146 | ALL | HPLC | NOS | 51.6/1000 person years | RH: 1.13 (1.05, 1.21) Adj | AER: Timed overnight | Age, DM duration, nephropathy at baseline, BP, retinopathy
| | | | *Mean: 11.25 | HbA1 | | | | Microalbuminuria: <20 μg/min
| | | | | | | | | Macroalbuminuria: 20–200 μg/min
| | | | Progressors
| | | | Mean: 11.4
| | | | SD: 1.8
| | | | Non-Progressors
| | | | Mean: 11.2
| | | | SD: 2.4
Klein et al., 1996 [809] | 2 | 10 | 533 | ALL | Microcolumn technique | No | | | Urine protein concentration: ≥0.3 g/L
| | | | | HbA1
| | | | Insulin use: | | | 40.0% | OR: 0.81 (1.09, 1.61) | | Gender, BP, smoking, retinopathy level, BP rx
| | | | Mean: 10.2 | | | | Adj
| | | | No insulin use: | | | 33.4% | OR: 1.00 (0.77, 1.29)
| | | | Mean: 8.9

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 28. Nephropathy: Cohort Studies: Progression of Nephropathy, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Outcome Definition | Comments
Villar et al., 1999 [325] | 1 | 2 | 340 | Mean: 7.6 | HPLC | NOS | 4.7% | OR: 2.08 (1.34, 3.21) | AER: 24 hrs 30–299mg/24 hrs to ≥300 mg/24 hrs | Adj: Age, gender, DM duration, nephropathy status at baseline, BP, retinopathy, CVD
| | | | SD: 1.3 | HbA1c
Sawicki et al., 2000 [289] | 1 | 6 | 601 | Mean: 7.8 | HPLC | No | | 1.65 (1.4, 1.9) Crude | Progression to any higher level of nephropathy according to Mogensen stages of nephropathy | Adj Model 1: SBP
| | | | SD: 1.3 | HbA1 | No | | 1.68 (1.4, 2.0) Adj Model 1
| | | | | | | | 1.65 (1.4, 1.9) Adj Model 2 | | Adj Model 2: DBP

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 29. Nephropathy: Cohort Studies: Progression of Nephropathy, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Outcome Definition | Comments
Nosadine et al., 2000 [245] | 2 | 4 | 108 | ALL | HPLC | No | | | Progression by change in % GFR above or below the median
| | | | | HbA1c
| | | | 4.87–6.69 | | | | OR: 1.0: Adj | | Adj: Age, gender, DM duration
| | | | 6.71–8.00 | | | | OR: -2.11 (1.21–6.64)
| | | | 8.02–9.01 | | | | OR: 0.79 (0.11, 1.22)
| | | | 9.02–11.01 | | | | OR: 3.33 (1.52, 11.2)
Oue et al., 1999 [315] | 2 | 10 | 67 | ALL | HPLC | No | | OR: 7.30 (1.29, 41.4) | Progression: >2x baseline urinary albumin index value | Adj: Age, DM duration, BMI, BP, smoking, lipids, alcohol
| | | | *Mean: 8.16 | HbA1c | | | Crude OR: 1.65 (1.09, 2.50) Adj
| | | | Progressors
| | | | Mean: 8.7
| | | | SD: 1.6
| | | | Non-Progressors
| | | | Mean: 7.8
| | | | SD: 1.2
Villar et al., 1999 [325] | 2 | 2 | 258 | Mean: 7.5 | HPLC | NOS | 7.8% | OR: 1.77 (1.27, 2.45) Adj | AER: 24 hrs 30–299mg/24 hrs to ≥300 mg/24 hrs | Adj : Age, gender, DM duration, endpoint at baseline, BP, retinopathy, CVD
| | | | SD: 1.5 | HbA1c

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated

Table 30. Nephropathy: Cohort Studies: Change in GFR / Creatinine Clearance, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Linear regression | Outcome | Comments
Hovind et al., 2001 [154] | 1 | 3 | 301 | Mean: 9.3 | HPLC | No | | | .73 (0.36, 1.10) Adj. | Rate of decline of GFR | Adj: BP, lipids, log_10_albuminuria
| | | | SD: 1.4 | HbA1c | | | | | 6 ml/min/year
Klein et al., 1999 [387] | 1 | 3 | 301 | Mean: 10.0 | Micro-column technique | No | 52.5% | OR: 1.22 (1.12, 1.34) Adj. | | Decline in Cr clearance^2^ | Adj: Age, DM duration, weight, BP, smoking HTN, alcohol, proteinuria, physical activity
| | | | | HbA1 | | | | | ≥3 ml/min/1.73m
| | | | 5.4–8.7 | | | 37.9% | RR: 1.0 Crude
| | | | 8.8–9.8 | | | 49.5% | 1.28 (0.94, 1.75)
| | | | 9.9–11.1 | | | 58.3% | 1.63 (1.22, 2.17)
| | | | 11.2–17.7 | | | 71.6% | 2.04 (1.55, 2.68)
Mulec et al., 1998 [540] | 1 | 8 | 158 | Mean: 8.7 | HPLC | No | | RR: 2.8 (1.5, 4.9) Adj. | | Decline in GFR of 40% | Adj: Unclear
| | | | SD: 1.6 | HbA1
Earle et al., 1997 [566] | 1 | 8.4 | 54 | ALL | Electrophoresis | No | | | 0.093 | Rate of decline in GFR NOS | Adj: Smoking, lipids, HTN, baseline GFR, Na-Li countertransport
| | | | *Mean: 10.79 | HbA1 | | | | SEM: 0.047 (p=0.06) Adj.1
| | | | With hypertension
| | | | Mean: 10.7
| | | | SD: 0.3
| | | | Without hypertension
| | | | Mean: 11.2
| | | | SD: 0.4
Alaveras et al., 1997 [681] | 1 | 8 | 58 | Mean: 10.88 | Electro-endosmosis | No | | | -0.15 | Rate of decline in GFR NOS | Adj: Gender, baseline GFR, BP, AER
| | | | SD: 2.1 | HbA1 | | | | SEM: 0.03 (p<0.001)

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 31. Nephropathy: Cohort Studies: End-stage renal disease: Renal replacement therapy or transplant, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Comments
Muhlhauser et al., 2000b [185] | 1 | 10 | 3453 | ALL | HPLC | No
| | | | | HbA1c
| | | | Normal protein: | | | 0.5%
| | | | Mean: 8.1 (1.9)
| | | | Microalbuminuria: | | | 1.5%
| | | | Mean: 8.3 (1.9)
| | | | Macroalbuminuria: | | | 37.2%
| | | | Mean: 8.4 (1.7)
Muhlhauser et al., 2000a [178] | 1 | 10 | 3674 | ALL | HPLC | No
| | | | | HbA1
| | | | ≤7.0 | | | 2.4%
| | | | 7–9 | | | 4.9%
| | | | ≥9.0 | | | 5.9%
Alaveras et al., 1997 [681] | 1 | 8 | 58 | Mean: 10.8 | HPLC | No | 1.7%
| | | | SD: 2.1 | HbA1

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 32. Nephropathy: Cohort Studies: End-stage renal disease: Renal replacement therapy or transplant, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Yokoyama et al., 1997 [653] | 2 | 8 | 182 | Mean: 8.3 | HPLC | No | | 1.0 (0.91, 1.13) Crude
| | | SD: 1.6 | HbA1c

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 33. Nephropathy: Randomized Controlled Trials: Incidence/Progression of Microalbuminuria, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Outcome Definition | Comments
Reichard et al., 1993 [1069] | 1 | 7.5 | 89 | ALL | HPLC | No | | OR: 5.9 (1.9, 16.8) Adj | AER: 24 hrs | Adj: DM duration, baseline urinary albumin, BP, insulin use, smoking, age at diagnosis, baseline retinopathy, treatment type
| | | | *Mean: 7.91 | HbA1c | | | | ≥200 μg/min
| | | | Conventional | | | 24%
| | | | Mean: 8.7
| | | | SD: 1.1
| | | | Intensive | | | 6.8%
| | | | Mean: 7.2
| | | | SD: 0.6
DCCT, 1993 [4638] | 1 | 6.5 | 1441 | ALL | HPLC | Yes | | | AER: Timed 4 hrs | DCCT, 1993 [4638]
| | | | | HbA1c | | | | ≥40 mg/24 hrs
| | | | 1° Conventional | | | 3.4/100 person years | RRR: 0% Crude
| | | | Mean: 8.8
| | | | SD: 1.7
| | | | 1° Intensive | | | 2.2/100 person years | 34% (2%, 56%)
| | | | Mean: 8.8
| | | | SD: 1.6
| | | | 2° Conventional | | | 5.7/100 person years | RRR: 0%
| | | | Mean: 8.9
| | | | SD: 1.5
| | | | 2° Intensive | | | 3.6/100 person years | 43% (21%, 58%)
| | | | Mean: 9
| | | | SD: 1.5

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 34. Nephropathy: Randomized Controlled Trials: Incidence/Progression of Microalbuminuria, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Outcome Definition | Comments
Shichiri et al., 2000 [247] | 2 | 8 | 110 | ALL | HPLC | No | | | AER: Timing unclear
| | | | | HbA1c | | | | 30–300 mg/24 hrs
| | | | 1° Conventional | | | 4.3% 5.4 events per 100 person years | RRR: 0%
| | | | Mean: 8.8
| | | | SD: 1.4
| | | | 1° Intensive | | | 11.5% 1.4 events per 100 person years | 74%
| | | | Mean: 9.5
| | | | SD: 1.7
| | | | 2° Conventional | | | 40% 5 events per 100 person years | RRR: 0%
| | | | Mean: 9.0
| | | | SD: 1.5
| | | | 2° Intensive | | | 16% 2 events per 100 person years | 60%
| | | | Mean: 9.3
| | | | SD: 1.5
Ohkubo et al., 1995 [888] | 2 | 6 | 102 | ALL | HPLC | No | | | AER: Timing unclear
| | | | | HbA1c | | | | 30–300 mg/24 hrs
| | | | 1° Conventional | | | 28% over 100 person years
| | | | Mean: 8.9
| | | | SD: 1.8
| | | | 1° Intensive | | | 7.7% over 100 person years
| | | | Mean: 8.2
| | | | SD: 1.8
United Kingdom Prospective Diabetes Study (UKPDS) Group., 1998 [2113] | 2 | 10 | 4209 | ALL | HPLC | Yes | | | AER: Timing unclear
| | | | | HbA1c | | | | >50 mg/L
| | | | Conventional | | | | RR: 1.0
| | | | Mean: 7.05
| | | | SD: 1.42
| | | | Intensive | | | | 0.70 (0.46, 1.77)
| | | | Mean: 7.09
| | | | SD: 1.54

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 35. Nephropathy: Randomized Controlled Trials: Incidence/Progression of Macroalbuminuria, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Outcome Definition | Comments
DCCT, 1993 [4638] | 1 | 6.5 | 1441 | ALL | HPLC | Yes | | | AER: Timed 4 hrs
| | | | | HbA1c | | | | ≥300 mg/24 hrs
| | | | 1° Conventional | | | 0.3/100 person years | RRR: 0%
| | | | Mean: 8.8
| | | | SD: 1.7
| | | | 1° Intensive | | | 0.2/100 person years | 44% (-124%, 86%)
| | | | Mean: 8.8
| | | | SD: 1.6
| | | | 2° Conventional | | | 1.4/100 person years | RRR: 0%
| | | | Mean: 8.9
| | | | SD: 1.5
| | | | 2° Intensive | | | 0.6/10 person years | 56% (18%, 76%)
| | | | Mean: 9
| | | | SD: 1.5

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 36. Nephropathy: Randomized Controlled Trials: Incidence/Progression of Macroalbuminuria, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Outcome Definition
Shichiri et al., 2000 [247] | 2 | 8 | 110 | ALL | HPLC | No | | | AER: Timing unclear
| | | | | HbA1c | | | | >300 mg/24 hrs
| | | | 1° Conventional | | | 1.1 events per 100 person years | RRR: 0%
| | | | Mean: 8.8
| | | | SD: 1.4
| | | | 1° Intensive | | | 0 events per 100 person years | 100%
| | | | Mean: 9.5
| | | | SD: 1.7
| | | | 2° Conventional | | | 2 events per 100 person years | RRR: 0%
| | | | Mean: 9.0
| | | | SD: 1.5
| | | | 2° Intensive | | | 0 events per 100 person years | 100%
| | | | Mean: 9.3
| | | | SD: 1.5
Ohkubo et al., 1995 [888] | 2 | 6 | 102 | ALL | HPLC | No | | | AER: Timing unclear
| | | | | HbA1c | | | | >300 mg/24 hrs
| | | | 1° Conventional | | | 32% over 100 person years
| | | | Mean: 9
| | | | SD: 1.9
| | | | 1° Intensive | | | 11.5% over 100 person years
| | | | Mean: 9.4
| | | | SD: 1.8
United Kingdom Prospective Diabetes Study (UKPDS) Group., 1998 [2113] | 2 | 10 | 4209 | ALL | HPLC | Yes | | | AER: Timing unclear
| | | | | HbA1c | | | | >300 mg/L
| | | | Conventional | | | | RR: 1.0
| | | | Mean: 7.05
| | | | SD: 1.42
| | | | Intensive | | | | 0.56 (0.23, 1.43)
| | | | Mean: 7.09
| | | | SD: 1.54

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 37. Nephropathy: Randomized Controlled Trials: Progression of Nephropathy, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Outcome Definition | Comments
Reichard et al., 1991 [1266] | 1 | 5 | 96 | ALL | HPLC | No | | OR: 2.3 (1.3, 3.4) Adj | Progression: Microalbuminuria: AER: 24 hrs 20–200 μg/min to Macroalbuminuria: AER: 24 hrs ≥200 μg/min | Adj: Unclear
| | | | *Mean:8.01 | HbA1c
| | | | Conventional Mean: 8.7
| | | | SD: 0.1
| | | | Intensive Mean: 7.2
| | | | SD: 0.1

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 38. Nephropathy: Randomized Controlled Trials: Progression of Nephropathy, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Outcome Definition
Ohkubo et al., 1995 [888] | 2 | 6 | 102 | ALL | HPLC | No | | Worsening of nephropathy:
| | | | HbA1c | | | | AER: Timing unclear
| | | | | | | | Microalbuminuria: 30–300 mg/24 hrs to Macroalbuminuria: >300 mg/24 hrs
| | | | 1° Conventional | | | 30% over 100 person years
| | | | Mean: 9.4
| | | | SD: 1.5
| | | | At end of f/u
| | | | 1° Intensive | | | 9.6% over 100 person years
| | | | Mean: 7.1
| | | | SD: 1.1
| | | | At end of f/u

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 39. Neuropathy: Cohort Study: Peripheral Neuropathy, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
DCCT, 1996 [718] | 1 | 6.5 | 1273 | ALL | HPLC | Yes | | RRR: 30% (18%, 40) | Confirmed clinical neuropathy
| | | | *Mean: 7.99 | HbA1c | | | | For 10% change in HbA1c
| | | | | | | | | Adj: type of treatment
| | | | <8 | | | | 32% (-5%, 56%)
| | | | >8 | | | | 29% (13%, 42%)
| | | | Conventional | | | | 29% (15%, 41%)
| | | | <8 | | | | 32% (-70%, 73%)
| | | | >8 | | | | 28% (11%, 43%)
| | | | Intensive | | | | 32% (9%, 50%)
| | | | <8 | | | | 30% (-19%, 58%)
| | | | >8 | | | | 35% (-17%, 64%)
Lloyd et al., 1996 [777] | 1 | 4 | 658 | ALL | NOS | No | | | Distal symmetric polyneuropathy
| | | | | HbA1c
| | | | <10.9 | | | | RR: 1.0 Adj | Adj: DM duration
| | | | >11.0 | | | | 3.2
Reichard et al., 1992 [1188] | 1 | 5 | 96 | ALL | HPLC | No | | | Neuropathy
| | | | | HbA1c
| | | | <8.9 | | | | OR: 0.15 (0.02, 0.90)
| | | | >9.0 | | | | OR: 1.0 Adj. | Adj: Unclear
Klein et al., 1996 [809] | 1 | 10 | 765 | Mean: 10.8 | Microcolumn technique | No | Sensory loss: 18.6% (14.8%, 22.3%)
| | | | SD not reported | HbA1 | | Diminished temperature sensation: 10.6% (7.6%, 13.5%)
Christen et al., 1999 [1999] | 1 | 3 | 407 | Mean: 11.8 | NOS | No | | Progression to definite distally symmetric polyneuropathy (PDSP): RR: 1.25 | PDSP: Adj: Age, gender, smoking, sorbinil, height
| | | | SD: 2 | GHB | | | (1.12, 1.39) Adj. | PN: Adj: Age, BP, sorbinil
| | | | | | | | Progression of neuropathy (PN): 1.17
| | | | | | | | (1.08, 1.26) Adj.
| | | | <10.1 | | | | PDSP: 1.0 Adj.
| | | | | | | | PN: 1.0 Adj.
| | | | 10.2–11.1 | | | | PDSP: 2.6 (0.9, 7.4)
| | | | | | | | PN: 1.8 (1.1, 3.2)
| | | | 11.2–12.1 | | | | PDSP: 2.8 (1.0, 7.6)
| | | | | | | | PN: 1.4 (0.8, 2.6)
| | | | 12.2–13.5 | | | | PDSP: 2.7 (1.0, 7.7)
| | | | | | | | PN: 2.0 (1.1, 3.5)
| | | | >13.6 | | | | PDSP: 6.4 (2.4, 16.8)
| | | | | | | | PN: 2.8 (1.6, 4.8)

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 40. Neuropathy: Cohort Study: Peripheral Neuropathy, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Linear regression | Comments
Sands et al., 1997 [2275] | 2 | 5 | 231 | ALL | Mini-column | No
| | | | | HbA1
| | | | <8.9 | | | Definite distal symmetric neuropathy: 0.65% over 100 person years
| | | | | | | Abnormal neurological exam 4.71% over 100 person years
| | | | >9.1 | | | Definite distal symmetric neuropathy: 0.48% over 100 person years
| | | | | | | Abnormal neurological exam 5.60% over 100 person years
Klein et al., 1996 [809] | 2 | 10 | 765 | ALL | Microcolumn technique | No
| | | | | HbA1
| | | | Insulin use: | | | Sensory loss: 25.3% (16.7%, 33.9%)
| | | | Mean: 10.2
| | | | SD not reported | | | Diminished temperature sensation: 18.8% (10.7, 26.8%)
| | | | No Insulin use: | | | Sensory loss: 23.3% (17.0%, 29.6%)
| | | | Mean: 8.9
| | | | SD not reported | | | Diminished temperature sensation: 15.4% (10.0%, 20.9%)
Dyck et al., 1999 [2022] | 2 | 6 | 149 | Mean: 101 | NOS | No | | 0.9583 | Polyneuropathy impairment score and 7 test composite neuropathy score.
| | | | SD: 2 | GHB | | | SEM: 0.1326 | Adj model 1: Age, DM duration, smoking, FG, 240hour protein, retinopathy, pulse, calcified foot vessels
| | | | | | | | (p<0.001) Adj. Model 1 | Adj model 2: model 1 minus calcified foot vessels.
| | | | | | | | 0.9583
| | | | | | | | SEM: 0.1326 Adj. Model 2

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 41. Neuropathy: Cohort Study: Autonomic Neuropathy, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Linear regression | Comments
Makimattila et al., 2000 [184] | 1 | 10 | 83 | Mean: 9.3 | HPLC | No | | | -0.39 (0.001) HRV: Total power (ms^2^)
| | | | SD: 0.2 | HbA1c
Stella et al., 2000 [224] | 1 | 5 | 373 | ALL | HPLC | No | 27% | RR: 1.50 (1.21, 1.86) Adj. | | Cardiac autonomic neuropathy Adj: Age, gender, DM duration, BP, smoking, age at diagnosis, lipids, nephropathy, fibrinogen, macrovascular disease
| | | | | HbA1c
| | | | Incident cases:
| | | | Mean: 10.8
| | | | SD: 1.9
| | | | Non cases:
| | | | Mean: 10.4
| | | | SD: 1.7
| | | | <10 | | | | RR: 1.0 Crude
| | | | ≥10 | | | | 1.67 (1.16, 2.41)

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 42. Neuropathy: Randomized Controlled Trials: Peripheral Neuropathy, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Gaede et al., 1999 [416] | 1 | 4 | 149 | ALL | HPLC | NOS | | | Peripheral neuropathy progression
| | | | | HbA1c
| | | | Conventional | | | 33% | OR: 1.0 Adj | Age, gender, DM duration, endpoint at baseline
| | | | Mean: 8.8
| | | | SD: 1.7
| | | | Intensive | | | 27% | 0.89 (0.43, 1.85)
| | | | Mean: 8.4
| | | | SD: 1.6
Reichard et al., [921] | 1 | 8 | 89 | ALL | HPLC | No | | | Subjective symptoms and abnormal nerve conduction study
| | | | | HbA1c
| | | | <7.0 | | | 10%
| | | | 7–7.99 | | | 33%
| | | | 8–8.99 | | | 39%
| | | | >9 | | | 43%
Reichard et al., 1991 [1266] | I | 5 | 96 | ALL *Mean: 8.01 | HPLC | No | | OR: 3.5 (1.7, 7.0) Adj. | At least 2 abnormal measurements Adj: Unclear
| | | | | HbA1c
| | | | Conventional:
| | | | Mean: 9.4
| | | | SD: 0.2
| | | | Intensive:
| | | | Mean: 9.5
| | | | SD: 0.2
DCCT, 1993 [4638] | I | 6.5 | 1441 | ALL | HPLC | Yes
| | | | | HbA1c
| | | | 1° Conventional | | | 9.8% | Clinical neuropathy:
| | | | Mean: 8.8 | | | | RRR: 0%
| | | | SD: 1.7
| | | | 1° Intensive | | | 3.1% | 69% (24%, 87%)
| | | | Mean: 8.8
| | | | SD: 1.6
| | | | 2° Conventional | | | 16.1% | RRR: 0%
| | | | Mean: 8.9
| | | | SD: 1.5
| | | | 2° Intensive | | | 7.0% | 57% (29%, 73%)
| | | | Mean: 9.0
| | | | SD: 1.5

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 43. Neuropathy: Randomized Controlled Trials: Peripheral Neuropathy, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Gaede et al., 1999 [416] | 2 | 4 | 160 | ALL | HPLC HbA1c | No
| | | | Conventional: Mean: 8.8 | | | 33% | Progression of neuropathy: | Adj: Gender, DM duration, endpoint at baseline
| | | | SD: 1.7 | | | | OR: 1.0 Adj.
| | | | Intensive: Mean: 8.4 | | | 27% | 0.89 (0.43, 1.85)
| | | | SD: 1.6
United Kingdom Prospective Diabetes Study (UKPDS) Group, 1998 [2113] | 2 | 10 | 4209 | ALL | HPLC HbA1c | Yes | | | Abnormal biothesiometry
| | | | Conventional: Mean: 7.05 | | | | RR: 1.0 (Crude)
| | | | SD: 1.42
| | | | Intensive: Mean: 7.09 | | | | 0.60 (0.39, 0.94)
| | | | SD: 1.54

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 44. Neuropathy: Randomized Controlled Trials: Autonomic Neuropathy, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Gaede et al., 1999 [416] | 2 | 4 | 160 | ALL | HPLC | No
| | | | | HbA1c
| | | | Conventional: | | | 28% | Progression of autonomic neuropathy: | Adj: Gender, DM duration, endpoint at baseline
| | | | Mean: 8.8 | | | | OR: 1.0 Adj.
| | | | SD: 1.7
| | | | Intensive: | | | 10% | 0.31 (0.12, 0.78)
| | | | Mean: 8.4
| | | | SD: 1.6

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 45. Macrovascular: Cause Specific Cardiovascular Morbidity—Coronary Artery Disease: Cohort Studies: Angina, Non-fatal Myocardial Infarction, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Risk Estimate | Comments
Adler et al., 1999 [4124] | 2 | 10 | 5063 | ALL | HPLC | No | | Angina
| | | | | HbA1c
| | | | <8.0 | | | RH: 1.0 Adj. | Adj: Age, gender, race, age at diagnosis
| | | | 8.1–10.2 | | | 1.4 (1.1, 1.9)
| | | | >10.3 | | | 1.2 (0.8, 1.6)
| | | | After dietary run in
| | | | <6.3 | | | RH: 1.0 Adj. model 1 | Adj model 1: Gender, race, age at diagnosis
| | | | | | | RH: 1.0 Adj. model 2 | Adj model 2: Gender, race, baseline angina, weight, BP, smoking, age at diagnosis, lipids, fitness, social class
| | | | 6.4–7.6 | | | 1.5 (1.1, 2.0)
| | | | | | | 1.5 (1.1, 2.0)
| | | | >7.7 | | | 1.7 (1.3, 2.3)
| | | | | | | 1.6 (1.1, 2.1)
Lehto et al., 1997 [4240] | 2 | 7 | 1059 | ALL | Affinity chromatography HbA1c | No | | Non-fatal MI
| | | | ≤10.7 | | | RH: 1.0 Crude | Adj: Age, gender, DM duration, baseline MI, lipids, AUC, glucose
| | | | | | | RH: 1.0 Adj.
| | | | ≥10.7 | | | 1.3 (1.0, 1.7) Crude
| | | | | | | 1.1 (0.9, 1.5)

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 46. Macrovascular: Cause Specific Cardiovascular Morbidity—Cerebrovascular Disease: Cohort Studies: Non-fatal Stroke, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Comments
Fu et al., 1993 [4403] | 2 | 4 | 479 | ALL | NOS | No
| | | | | HbA1c
| | | | ≤6.2 | | | 2.8%
| | | | 6.3–7.2 | | | 4.7%
| | | | 7.3–8.4 | | | 2.6%
| | | | ≥8.5 | | | 6.2%

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 47. Macrovascular: Cause Specific Cardiovascular Morbidity— Peripheral Arterial Disease: Cohort Studies: Non-fatal Peripheral Arterial Disease, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Muhlhauser et al., 2000b [185] | 1 | 10 | 3453 | ALL | HPLC | No | | | Limb amputation
| | | | | HbA1c
| | | | Normal protein | | | 0.5/10 events
| | | | Mean: 8.1
| | | | SD: 1.9
| | | | Microalbuminuria: | | | 1.5/21 events
| | | | Mean 8.2
| | | | SD: 1.9
| | | | Macroalbuminuria: | | | 10.5/38 events
| | | | Mean: 8.4
| | | | SD: 1.7
Olson et al., 2002 [7] | 1 | 10 | 586 | ALL | Microcolumn cation exchange | No | | RH: 1.53 (1.22, 1.92) Adj. | For 1.84 units change in HbA1.
| | | | *Mean: 10.37 | HbA1 | | | | Adj: DM duration, HTN, log AER, heart rate
| | | | No Lower
| | | | Extremity Artery
| | | | Disease
| | | | Mean: 10.3
| | | | SD: 1.8
| | | | Lower Extremity
| | | | Artery Disease
| | | | Mean: 10.9
| | | | SD: 1.9
Muhlhauser et al., 2000a [178] | 1 | 10 | 3674 | ALL | HPLC | NOS | | | Limb amputation
| | | | | HbA1
| | | | <7 | | | 1.1%
| | | | 7–9 | | | 2.3%
| | | | >9 | | | 2.7%
Lloyd et al., 1996 [777] | 1 | 4 | 658 | ALL | NOS | No | 6.0%
| | | | | GHB
| | | | ≤10.9 | | | | RR: 1.0 Adj. | Adj: DM duration
| | | | ≥11.0 | | | | RR: Not significant
Moss et al., 1999 [2047] | 1 | 14 | 906 | ALL | Microcolumn technique | NOS | | OR: 1.39 (1.22, 1.59) Adj. | Adj: Age, gender, BP, retinopathy, hx of ulcers
| | | | Mean: 10.8 | GHB
| | | | SD: 2.1
| | | | 5.6–9.4 | | | | RR: 1.0 Crude
| | | | 9.5–10.5 | | | | 2.93 (1.10, 7.83)
| | | | 10.6–12 | | | | 3.21 (1.24, 8.33)
| | | | 12.1–19.5 | | | | 5.64 (2.43, 13.10)
Moss et al., 1996 [2326] | 1 | 10 | 879 | Mean: 10.8 | Microcolumn technique | NOS | | OR: 1.39 (1.19, 1.62) Adj. | Adj: Gender, DM duration, BP, hx of ulcers, proteinuria
| | | | SD: 2.1 | GHB
| | | | 5.6–9.4 | | | 1.5% | RH: 1.0 Crude
| | | | 9.5–10.5 | | | 5.8% | 4.12 (1.28, 13.29)
| | | | 10.6–12.0 | | | 6.1% | 4.17 (1.32, 13.24)
| | | | 12.1–19.5 | | | 9.0% | 6.15 (2.13, 17.74)
Moss et al, 1992 [2636] | 1 | 4 | 996 | ALL | Microcolumn technique | NOS | Limb amputation: 2.2% | Limb amputation: | OR: for 2 units change in GHB
| | | | | GHB | | Patient self report of sores or foot ulcers: 9.5% | OR: 1.4 (1.0, 2.1) Adj. | Adj: Age, retinopathy, hx of sores/ulcers
| | | | | | | | Patient self report of sores or foot ulcers: OR: 1.6 (1.3, 2.0) Adj.
| | | | 6.0–10.8 | | | Limb amputation: 0.9%
| | | | | | | Patient self report of sores or foot ulcers: 5.2%
| | | | 10.9–12.2 | | | Limb amputation: 2.4%
| | | | | | | Patient self report of sores or foot ulcers: 5.9%
| | | | 12.3–14.1 | | | Limb amputation: 2.8%
| | | | | | | Patient self report of sores or foot ulcers: 9.4%
| | | | 14.2–23.3 | | | Limb amputation: 3.0%
| | | | | | | Patient self report of sores or foot ulcers: 17.2%

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 48. Macrovascular: Cause Specific Cardiovascular Morbidity—Peripheral Arterial Disease: Cohort Studies: Non-fatal Peripheral Arterial Disease, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Lehto et al., 1996a [2330] | 2 | 7 | 1044 | ALL | HPLC | No | | | Limb amputation
| | | | | HbA1
| | | | ≤10.7 | | | | RR: 1.0 Adj. | Adj: Age, gender
| | | | >10.8 | | | | 2.4 (1.4, 4.0)
Moss et al., 1999 [2047] | 2 | 14 | 984 | Mean: 9.6 | Microcolumn technique | NOS | | OR: 1.25 (1.09, 1.43) Adj. | Lower extremity amputation
| | | | SD: 2.0 | GHB | | | | Adj: Gender, BP, retinopathy, hx of ulcers
| | | | 5.4–8.1 | | | | RR: 1.0 Crude
| | | | 8.2–9.4 | | | | 1.98 (0.78, 4.99)
| | | | 9.5–10.8 | | | | 2.68 (1.15, 6.24)
| | | | 10.9–20.8 | | | | 3.79 (1.72, 8.35)
Moss et al., 1996 [2326] | 2 | 10 | 956 | Mean: 9.6 | Microcolumn technique | NOS | | OR: 1.28 (1.11, 1.48) Adj. | Lower extremity amputation
| | | | SD: 2 | GHB | | | | Adj: Gender, BP, retinopathy, hx of ulcers
| | | | 5.4–8.1 | | | 3.5% | RH: 1.0 Crude
| | | | 8.2–9.4 | | | 6.0% | 1.88 (0.68, 5.21)
| | | | 9.5–10.8 | | | 7.3% | 2.20 (0.84, 5.76)
| | | | 10.9–20.8 | | | 13% | 3.90 (1.68, 9.07)
Moss et al, 1992 [2636] | 2 | 4 | 996 | ALL | Microcolumn technique | NOS | | Limb amputation: OR: 1.5 (1.0, 2.2) Adj. | For 2 units change in GHB
| | | | | GHB | | | Patient self report of sores or foot ulcers: OR: 1.6 (1.3, 2.0) | Adj for age, retinopathy and hx sores/ulcers
| | | | 6.2–9.2 | | | Limb amputation: 0.9%
| | | | | | | Patient self report of sores or foot ulcers: 4.2%
| | | | 9.3–10.8 | | | Limb amputation: 2.3%
| | | | | | | Patient self report of sores or foot ulcers: 8.1%
| | | | 10.9–12.6 | | | Limb amputation: 2.3%
| | | | | | | Patient self report of sores or foot ulcers: 10.4%
| | | | 12.7–23.6 | | | Limb amputation: 3.7%
| | | | | | | Patient self report of sores or foot ulcers: 18.7%

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 49. Macrovascular: Cause Specific Cardiovascular Morbidity—Congestive Heart Failure: Cohort Studies: Congestive Heart Failure, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Stratton et al., 2000 [4087] | 2 | 10 | 3642 | Mean: 7.1 | HPLC | No | | RRR: 16% (3%, 26%) | Adj: Gender, race, BP, smoking, age at diagnosis, lipids, albuminuria
| | | | SD: 1.8 | HbA1c
| | | | <6 | | | (1.2, 4.5)
| | | | 6–6.9 | | | (1.9, 5.8)
| | | | 7–7.9 | | | (2.9, 8.6)
| | | | 8–8.9 | | | (2.4, 8.2)
| | | | 9–9.9 | | | (2.3, 10.6)
| | | | ≥10 | | | (5.5, 25.8)
Nichols et al., 2001 [4025] | 2 | 2.5 | 8640 | Mean: 7.7 | NOS | No | | OR: 0.91 (0.83, 1.00) Adj. | Adj: Age, DM duration, weight, BP, insulin use
| | | | SD not reported | HbA1c

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 50. Macrovascular: Cause Specific Cardiovascular Morbidity— Carotid IMT: Cohort Studies: Carotid IMT, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Linear regression | Comments
Epidemiology of Diabetes Intervention and Complications (EDIC) Research Group, 1999 [4147] | 1 | 15 | 1325 | ALL | HPLC | Yes
| | | | | HbA1c
| | | | All women | | | ICIMT | Adj for age, DM duration, weight, BP, smoking, height, GFR, therapy
| | | | *Mean: 8.14 | | | -0.00310 (p=0.274)
| | | | | | | CCIMT
| | | | | | | 0.01192 (p=0.247)
| | | | Conventional:
| | | | Mean: 9.0
| | | | SD: 1.4
| | | | Intensive:
| | | | Mean: 7.3
| | | | SD: 0.9
| | | | All men | | | ICIMT | Adj for age, DM duration, weight, BP, smoking, height, GFR, therapy
| | | | *Mean: 8.11 | | | 0.00226 (p=0.481)
| | | | | | | CCIMT
| | | | | | | 0.00894 (p=0.35)
| | | | Conventional:
| | | | Mean: 9.0
| | | | SD: 1.1
| | | | Intensive:
| | | | Mean: 7.2
| | | | SD: 0.9

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 51. Macrovascular: Cause Specific Cardiovascular Morbidity—Carotid IMT: Cohort Studies: Carotid IMT, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Linear regression | Comments
Yamasaki et al., 2000 [4081] | 2 | 3.1 | 287 | Mean: 8.66 | NOS | No | 0.0093 | CCIMT
| | | | SE: 0.1 | HbA1c | | (p=0.001) | Adj: Age, gender, DM duration, CCIMT at baseline, weight, BP, smoking, lipids, creatinine, BUN, uric acid

GHB exposure is expressed as a %; *indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 52. Macrovascular: Cause Specific Cardiovascular Mortality—Coronary Artery Disease: Cohort Studies: Fatal Myocardial Infarction, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Risk Estimate | Comments
Lehto et al., 1999 [397] | 1 | 7 | 177 | ALL | HPLC | NOS
| | | | | HbA1
| | | | ≤10.4 | | | RH: 1.0 Crude | Adj: Age, gender, DM duration, endpoint at baseline, weight, BP, smoking, area, alcohol, log triglycerides, HDL
| | | | | | | RH: 1.0 Adj.
| | | | ≥10.4 | | | 6.8 (2.5, 19.0) Crude
| | | | | | | 5.4 (1.4, 20.4) Adj.

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 53. Macrovascular: Cause Specific Cardiovascular Mortality—Coronary Artery Disease: Cohort Studies: Fatal Myocardial Infarction, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Toyry et al., 1996 [3527] | 2 | 10 | 121 | Mean: 9.0 | HPLC | No | | OR: 1.5 (1.1, 2.1) | Mortality confirmed by chart review/death certificate.
| | | | SD: 2.2 | HbA1c | | | Adj. | Adj: Age, gender, weight, BP, smoking, autonomic dysfunction, ischemic ECG, diuretics
| | | | End of f/u
Turner et al, 1998 [4217] | 2 | 10 | 2693 | ALL | HPLC | No
| | | | | HbA1c
| | | | <6.1 | | | | Fatal MI | Adj model 1: Age, gender
| | | | | | | | RH: 1.0 Adj. model 1 | Adj model 2: Age, gender, BP, smoking, lipids
| | | | | | | | RH: 1.0 Adj. model 2
| | | | 6.2–7.4 | | | | Fatal MI
| | | | | | | | RH: 1.09
| | | | | | | | RH: 0.98 (0.58, 1.65)
| | | | >7.5 | | | | Fatal MI
| | | | | | | | RH: 2.11
| | | | | | | | RH: 1.72 (1.06, 2.77)
Lehto et al., 1997 [4240] | 2 | 7 | 1059 | ALL | Affinity chromatography | No | | | Fatal MI
| | | | | HbA1
| | | | ≤10.7 | | | | RH: 1.0 Crude | Adj: Age, gender, DM duration, baseline MI, lipids, AUC, glucose
| | | | | | | | RH: 1.0 Adj.
| | | | >10.7 | | | | 1.5 (1.1, 2.1) Crude
| | | | | | | | 1.4 (1.0, 1.9) Adj.
Florkowski et al., 1998b [519] | 2 | 6 | 447 | ALL | Automated furfural method | No | | Fatal CAD: | Adj model 1: For individuals free of CAD: Adj: Age, gender, DM duration, weight, insulin use, smoking, lipids, hypertension, coronary artery disease, peripheral neuropathy, albuminuria, metformin, sulfonlylurea, combined oral agents
| | | | *Mean: 6.3 | GHB | | | RH: 1.90
| | | | | | | | (1.04, 3.47) Adj model 1
| | | | | | | | RH: 0.81
| | | | | | | | (0.42, 1.58) Adj model 2
| | | | | | | | | Adj model 1: For individuals free of CAD: Adj: Age, gender, DM duration, weight, insulin use, smoking, lipids, hypertension, coronary artery disease, peripheral neuropathy, albuminuria, metformin, sulfonlylurea, combined oral agents
| | | | Dead:
| | | | Mean: 6.3
| | | | SD: 1.8
| | | | Alive
| | | | Mean: 6.3
| | | | SD: 1.8

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 54. Macrovascular: Cause Specific Cardiovascular Mortality— Cerebrovascular Disease: Cohort Studies: Fatal Stroke, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Risk Estimate | Comments
Moss et al, 1994b [4338] | 2 | 10 | 1265 | Mean: 11.1 | Microcolumn technique | No | RH: 1.17 (1.05, 1.3) Adj. | Adj: Age, gender, BP, Hx CVD
| | | | SD: 2.4 | GHB

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 55. Macrovascular: Composite Cardiovascular Mortality— Fatal Myocardial Infarction or Stroke: Cohort Studies: Fatal Myocardial Infarction or Stroke, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Linear regression | Comments
Niskanen et al., 1998 [457] | 2 | 15 | 133 | Mean: 9 | HPLC | No | | OR: 1.52 (1.25, 2.0) Adj. | | Adj: Age, gender, weight
| | | | SD: 0.2 | HbA1c
| | | | End of f/u
Gall et al., 1995 [827] | 2 | 5.3 | 328 | ALL | Thin isoelectric focusing | NOS | 8.8% | RR: 1.3 (1.1, 1.6) Adj. | | Adj: Age, BP, CHD, AER
| | | | *Mean: 8.12 | HbA1c
| | | | Normoalbuminuria:
| | | | Mean: 7.8
| | | | SD: 1.8
| | | | Microalbuminuria:
| | | | Mean: 8.6
| | | | SD: 2
| | | | Macroalbuminuria:
| | | | Mean: 8.5
| | | | SD: 2.2
Standl et al., 1996 [4276] | 2 | 10 | 268 | ALL | NOS | NOS | | | 0.18 | Adj model 1: Age, gender, endpoint at baseline, smoking, VWF protein
| | | | | HbA1c | | | | SEM=0.09
| | | | | | | | | Adj model 1
| | | | | | | | | 0.16
| | | | | | | | | SEM=0.07 | Adj model 2: Age, weight, BP, lipids
| | | | | | | | | Adj model 2
| | | | | | | | | -0.19 | Adj model 3: Age, endpoint at baseline, VWF protein
| | | | | | | | | SEM=0.09
| | | | | | | | | Adj model 3
| | | 165 | Survivors:
| | | | Median: 7.7
| | | | IQR: (6.3, 9.6)
| | | 103 | All deceased:
| | | | Median: 8.1
| | | | IQR: (6.9, 9.6)
| | | 58 | Macrovascular deaths:
| | | | Median: 8.2
| | | | IQR: (7.1, 10)

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 56. Macrovascular: Composite CVD Morbidity and Mortality—Cardiovascular Disease: Cohort Studies: Fatal and Non-fatal Myocardial Infarction, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Lehto et al., 1999 [397] | 1 | 7 | 177 | ALL | HPLC | NOS
| | | | | HbA1
| | | | ≤10.4 | | | | RH: 1.0 Crude | Adj: Age, gender, DM duration, endpoint at baseline, weight, BP, smoking, area, alcohol, log triglycerides, HDL
| | | | | | | | RH: 1.0 Adj.
| | | | ≥10.4 | | | | 3.4 (1.6, 7.4) Crude
| | | | | | | | 2.8 (1.2, 6.9) Adj.
Lloyd et al., 1996 [777] | 1 | 4 | 658 | ALL | NOS | No
| | | | | GHB
| | | | <10.9 | | | | RR: 1.0
| | | | ≥11 | | | | Not significant

GHB exposure is expressed as a %; *indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 57. Macrovascular: Composite CVD Mortality—Cardiovascular Disease: Cohort Studies: Fatal and Non-fatal Myocardial Infarction, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Stratton et al., 2000 [4087] | 2 | 10 | 3642 | Mean: 7.1 | HPLC | No | | RRR: 14% (8%, 21%) Adj. | For 1% reduction in HbA1c
| | | | SD: 1.8 | HbA1c | | | | Adj: Gender, race, BP, smoking, age at diagnosis, lipids, albuminuria
| | | | <6 | | | (12.1, 21.2)
| | | | 6–6.9 | | | (16.2, 26.7)
| | | | 7–7.9 | | | (22.8, 37.4)
| | | | 8–8.9 | | | (22.9, 39.4)
| | | | 9–9.9 | | | (28.8, 54.5)
| | | | ≥10 | | | (24.4, 61.0)
Adler et al., 1999 [4124] | 2 | 10 | 5063 | ALL | HPLC | No | | | Adj: Age, gender, race, age at diagnosis
| | | | | HbA1c
| | | | <8.0 | | | | RH: 1.0 Adj.
| | | | 8.1–10.2 | | | | 1.2 (1.0. 1.5)
| | | | >10.3 | | | | 1.4 (1.1, 1.7)
| | | | After dietary run in
| | | | <6.3 | | | | RH: 1.0 Adj. model 1 | Adj model 1: Gender, race, age at diagnosis
| | | | | | | | RH: 1.0 Adj. model 2 | Adj model 2: Gender, race, baseline MI, weight, BP, smoking, age at diagnosis, lipids, fitness, social class
| | | | 6.4–7.6 | | | | 1.2 (1.0, 1.5)
| | | | | | | | 1.2 (0.9, 1.5)
| | | | >7.7 | | | | 1.5 (1.2, 1.9)
| | | | | | | | 1.5 (1.2, 1.8)
Turner et al, 1998 [4217] | 2 | 10 | 2693 | ALL | HPLC | No | | RH: 1.11 | Adj: Change in HbA1c, unclear
| | | | *Mean: 7.11 | HbA1c | | | (1.02, 1.20) Adj.
| | | | <6.1 | | | | RH: 1.0 Adj. model 1 | Adj model 1: Age, gender
| | | | | | | | RH: 1.0 Adj. model 2 | Adj model 2: Age, gender, BP, smoking, lipids
| | | | 6.2–7.4 | | | | 1.64
| | | | | | | | 1.47 (1.12, 1.95)
| | | | >7.5 | | | | 1.52
| | | | | | | | 1.52 (1.15, 2.01)

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 58. Macrovascular: Composite CVD Morbidity and Mortality—Cerebrovascular Disease: Cohort Studies: Fatal and Non-fatal Stroke, type 1 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Risk Estimate | Comments
Moss et al, 1994b [4338] | 1 | 10 | 943 | Mean: 12.6 | Microcolumn technique | No | RH: 1.18 (1.0, 1.4) Adj. | Adj: Age, gender, BP, urine protein, Hx CVD, insulin dose
| | | | SD: 2.6 | GHB

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 59. Macrovascular: Composite CVD Morbidity and Mortality—Cerebrovascular Disease: Cohort Studies: Fatal and Non-fatal Stroke, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Incidence Rate | Risk Estimate | Comments
Stratton et al., 2000 [4087] | 2 | 10 | 3642 | Mean: 7.1 | HPLC | No | | RRR: 12% (1%, 21%) Adj. | For 1% reduction in HbA1c Adj: Gender, race, BP, smoking, age at diagnosis, lipids, albuminuria
| | | | SD: 1.8 | HbA1c
| | | | <6 | | | (2.6, 7.0)
| | | | 6–6.9 | | | (4.4, 10.1)
| | | | 7–7.9 | | | (5.4, 12.7)
| | | | 8–8.9 | | | (4.5, 11.9)
| | | | 9–9.9 | | | (3.5, 12.7)
| | | | ≥10 | | | (5.7, 25.3)
Adler et al., 1999 [4124] | II | 10 | 5063 | ALL | HPLC | No | | | Adj: Age, gender, race, age at diagnosis
| | | | | HbA1c
| | | | <8.0 | | | | RH: 1.0 Adj.
| | | | 8.1–10.2 | | | | 1.1 (0.8, 1.6)
| | | | >10.3 | | | | 1.0 (0.7, 1.4)
| | | | After dietary run in
| | | | <6.3 | | | | RH: 1.0 Adj. model 1 | Adj model 1: Gender, race, age at diagnosis
| | | | | | | | RH: 1.0 Adj. model 2 | Adj model 2: Gender, race, baseline MI, weight, BP, smoking, age at diagnosis, lipids, fitness, social class
| | | | 6.4–7.6 | | | | 1.1 (0.8, 1.5)
| | | | | | | | 1.2 (0.8, 1.7)
| | | | >7.7 | | | | 1.1 (0.8, 1.6)
| | | | | | | | 1.1 (0.7, 1.6)
Lehto et al., 1996b [4313] | II | 7 | 1059 | ALL | Affinity | No
| | | | | Chromatography
| | | | | HbA1
| | | | 8.9–10.7 | | | | OR: 1.0 Adj. | Adj: Age, sex
| | | | >10.8 | | | | 1.6 (1.1, 2.4)

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 60. Macrovascular: Composite CVD Morbidity and Mortality—Cardiovascular Disease: Randomized Controlled Trial: Fatal and Non-fatal Myocardial Infarction, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Risk Estimate | Comments
United Kingdom Prospective Diabetes Study (UKPDS) Group, 1998 [2113] | 2 | 10 | 4209 | ALL | HPLC | Yes
| | | | | HbA1c
| | | | Conventional: | | | MI: RR: 1.0 Crude
| | | | Median: 7.9 | | | Angina: RR: 1.0 Crude
| | | | Range: (6.2–8.2) | | | Fatal MI: RR: 1.0 Crude
| | | | Over f/u | | | Sudden cardiac death: 1.0 Crude
| | | | Intensive: | | | MI: 0.79 (0.58, 1.09)
| | | | Median: 7.0 | | | Angina: 1.02 (0.71, 1.46)
| | | | Range: (6.9, 8.8) | | | Fatal MI: 0.94 (0.68, 1.30)
| | | | Over f/u | | | Sudden cardiac death: 0.54 (0.24, 1.21)

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 61. Macrovascular: Composite CVD Morbidity and Mortality— Cerebrovascular Disease: Randomized Controlled Trial: Fatal and Non-Fatal Stroke, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Risk Estimate | Comments
United Kingdom Prospective Diabetes Study (UKPDS) Group, 1998 [2113] | 2 | 10 | 4209 | ALL | HPLC | Yes
| | | | | HbA1c
| | | | Conventional: | | | Fatal stroke: RR: 1.0 (Crude)
| | | | Median: 7.9 | | | Non fatal stroke: RR: 1.0 (Crude)
| | | | Range: (6.2–8.2)
| | | | Over f/u
| | | | Intensive: | | | 1.07 (0.68, 1.69)
| | | | Median: 7.0 | | | 1.17 (0.54, 2.54)
| | | | Range: (6.9, 8.8)
| | | | Over f/u

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 62. Macrovascular: Composite CVD Morbidity and Mortality— Peripheral Arterial Disease: Randomized Controlled Trial: Fatal and Non-fatal peripheral vascular disease, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Risk Estimate | Comments
United Kingdom Prospective Diabetes Study (UKPDS) Group, 1998 [2113] | 2 | 10 | 4209 | ALL | HPLC | Yes | | Limb amputation
| | | | | HbA1c
| | | | Conventional: | | | RR: 1.0
| | | | Median: 7.9
| | | | Range: (6.2–8.2)
| | | | Over f/u
| | | | Intensive: | | | 0.61 (0.28, 1.33)
| | | | Median: 7.0
| | | | Range: (6.9, 8.8)
| | | | Over f/u

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 63. Macrovascular Cause Specific Cardiovascular Morbidity—Congestive Heart Failure: Randomized Controlled Trial: Congestive Heart Failure, type 2 diabetes

Reference | DM type | F/U (Y) | n | GHB exposure | GHB Method | DCCT traceable | Risk Estimate | Comments
United Kingdom Prospective Diabetes Study (UKPDS) Group, 1998 [2113] | 2 | 10 | 4209 | ALL | HPLC | Yes
| | | | | HbA1c
| | | | Conventional: | | | RR: 1.0
| | | | Median: 7.9
| | | | Range: (6.2–8.2)
| | | | Over f/u
| | | | Intensive: | | | 0.91 (0.54, 1.52)
| | | | Median: 7.0
| | | | Range: (6.9, 8.8)
| | | | Over f/u

GHB exposure is expressed as a %; * indicates that a weighted mean was calculated based on the subgroup data given; n=Number of participants enrolled; RH = Relative Hazard, RR=Relative Risk, OR= Odds Ratio; RRR= Relative Risk Reduction; ROR=Relative Odds Reduction; 1°=primary prevention; 2°=secondary prevention; Risk Estimate for studies with continuous analyses for whole groups is for 1% change in GHB exposure unless otherwise indicated; Risk Estimates (95% Confidence Interval) unless otherwise indicated.

Table 64. Studies Examining Threshold Effect Between Glycosylated Hemoglobin and Retinopathy

Study Design | Study | Outcome | Methodology | Reported Threshold
Cohort | Molyneaux et al., 1998 [424] | Incident retinopathy | Data was analyzed comparing HbAlc less than or equal to 8.0% and greater than 8.0% as the cut off to enable comparison with DCCT. The Poisson model was fitted with a threshold variable [<ln 8.0%=0 and if >ln 8.0%=(ln mean HbA_1c_ - 1og 8.0%)]. The threshold (≤8.0% and >8.0%) was tested using a Wald test. | None
Cohort | Danne et al., 1994 [934] | Incident retinopathy | The actual prevalence of retinopathy and its rates per 100 patient-years in the different subgroups were compared with trend analysis. To analyze whether this influence of glycemic control follows a continuous relationship, we subdivided the total cohort into quartiles of long-term HbA_1c_ levels of <8, 8–9, 9–10, and >10%, resulting in four groups of approximately equal sizes. | 9.0%
Cohort | Klein et al., 1994 [2458] | Incident/Progression retinopathy | The baseline glycosylated hemoglobin level was divided into quartiles for each group. Tests for trends in rates were performed by the Mantel-Haenszel procedure stratified on time period. | None
| | Progression to proliferate retinopathy | The baseline glycosylated hemoglobin level was divided into quartiles for each group. Tests for trends in rates were performed by the Mantel-Haenszel procedure stratified on time period.
Cohort | Porta et al., 2001 [1769] | Progression to PDR | A breakpoint or threshold effect for the relation between HbA_1c_ and progression to PDR was tested by a two-phase segmented weighted regression analysis which fits two straight lines through a series of defined points. These points were calculated by logistic regression adjusted for diabetes duration. This segmented regression was compared to the line of best fit, using weighted linear regression. Logistic regression was also used to test for a threshold effect. | None
Cohort | Chaturvedi et al., 2001b [140] | Retinopathy | A breakpoint or threshold effect for the relationship between HbA_1c_, and retinopathy was tested for using a two-phase segmented-weighted regression analysis, which fits two straight lines through a series of defined points. These points were calculated by logistic regression adjusted for diabetes duration. This segmented regression was compared with the line of best fit, using weighted linear regression. Logistic regression was used to test for the threshold effect. | None
Trial | DCCT, 1996 [718] | Retinopathy | A change point was defined as a value of HbA_1c_ below and above which there is a statistically significant difference in the slope or risk gradient for the association with the risk of complications. The presence and significance of a change point was assessed through segmented log (risk) versus log (HbA_1c_) regression models. A test for an optimal change point selected by a search among a range of values from 6 to 9.9% in increments of 0.1% was performed using a 2 df likelihood ratio test of the segmented model at the optimal value compared to the simple exponential model. A threshold was defined as a change point below which the risk, if any was constant, or the risk gradient was zero. A test of a threshold at a specified change point (c) was assessed by a Wald test that β_1_ =0. | None
Trial | Ohkubo et al., 1995 [888] | Incidence/ Progression Retinopathy | The relative risks were also calculated using proportional-hazards analysis only in the combined cohort. Event rates of complications were presented as the number of events per 100 patient-years, based on the ratio of observed number of events to the total number of patient-years of exposure. | 6.5%
Cohort from Trial | Stratton et al., 2000 [4087] | Cataract extraction | The presence of thresholds was evaluated by visual inspection. | None

Table 65. Studies Examining Threshold Effect Between Glycosylated Hemoglobin and Nephropathy

Study Design | Study | Outcome | Methodology | Reported Threshold
Cohort | Molyneaux et al., 1998 [424] | Incident micro-albuminuria | Data was analyzed comparing HbAlc less than or equal to 8.0% and greater than 8.0% as the cut off to enable comparison with DCCT. The Poisson model was fitted with a threshold variable [<ln 8.0%=0 and if >ln 8.0%=(1n mean HbA_1c_ - 1og 8.0%)]. The threshold (≤8.0% and >8.0%) was tested using a Wald test. | None
Cohort | Scott et al., 2001 [25] | Micro-albuminuria | GAMs, (Generalized Additive Models) were used within the discrete failure time approach, to assess the linearity (in the logarithm of odds scale) of the relationship between HbA1c and onset of microalbuminuria. A GAM allows for relaxation of the assumption of linearity by using a flexible smoothing term- in this case the loess option- to fit a smooth curve to the ungrouped data. | 8% (among smokers)
Cohort | Chaturvedi et al., 2001a [84] | Micro-albuminuria | A breakpoint or threshold effect for the relationship between HbA_1c_, and microalbuminuria was tested for using a two-phase segmented-weighted regression analysis, which fits two straight lines through a series of defined points. These points were calculated by logistic regression adjusted for diabetes duration. This segmented regression was compared with the line of best fit, using weighted linear regression. Logistic regression was used to test for the threshold effect. | None
Cohort | Sawicki et al., 2000 [289] | Nephropathy progression | To investigate possible threshold effects of HbA_1c_ and blood pressure on progression of nephropathy. Ulm's threshold model and a novel approach by Bender to assessing threshold effects in epidemiological studies were used. | None
Cohort | Hovind et al., 2001 [154] | Decline in GFR | To evaluate whether there were nonlinear effects of the variables on the decline in GFR, the linear regression model was extended to a model with one change point for each variable at a time. By varying the change point, the position of the change point could be estimated (threshold) and tested to determine whether inclusion of a change point improved the model. | None
Cohort | Alaveras et al., 1997 [681] | Decline in GFR | To assess whether there was a threshold effect in the relationship between HbA_1_, and rate of decline of GFR the distribution of mean HbA_1_ was divided into thirds. | None
Cohort | Warram et al, 2000 [304] | Progression to proteinuria | A generalized additive model (GAM) was constructed to examine further the relationship between baseline HbA1c and progression to proteinuria. A GAM replaces the usual assumption of linearity with a flexible smooth term, in this cases the loess option, to fit a smooth curve to the ungrouped data. | 7.5–8.5%
Trial | Ohkubo et al., 1995 [888] | Incidence/Progression nephropathy | The relative risks were calculated using proportional-hazards analysis only in the combined cohort. Event rates of complications were presented as the number of events per 100 patient-years, based on the ratio of observed number of events to the total number of patient-years of exposure. | 6.5%

Table 66. Studies Examining Threshold Effect Between Glycosylated Hemoglobin and Neuropathy

Study Design | Study | Outcome | Methodology | Reported Threshold
Trial | DCCT, 1996 [718] | Peripheral Neuropathy | A change point was defined as a value of HbA_1c_ below and above which there is a statistically significant difference in the slope or risk gradient for the association with the risk of complications. The presence and significance of a change point was assessed through segmented log (risk) versus log (HbA_1c_) regression models. A test for an optimal change point selected by a search among a range of values from 6 to 9.9% in increments of 0.1% was performed using a 2 df likelihood ratio test of the segmented model at the optimal value compared to the simple exponential model. A threshold was defined as a change point below which the risk, if any is constant, or the risk gradient is zero. A test of a threshold at a specified change point (c) was assessed by a Wald test that β_1_ =0. | None

Table 67. Studies Examining Threshold Effect Between Glycosylated Hemoglobin and Macrovascular Complications

Study Design | Study | Outcome | Methodology | Reported Threshold
Cohort from Trial | Stratton et al., 2000 [4087] | Fatal and non-fatal CHD | The presence of thresholds was evaluated by visual inspection. | None
| | Fatal and non-fatal stroke CHF
| | PAD

Table 68. Study Population, Design, Location, Recruitment, Outcomes, Quality

Reference | Type of DM | Design | Location | Number of Sites | Recruitment | Outcomes | | | | | | Quality Score
| | | | | | Renal | All Cause Death | CVD Composite Death | Cause Specific CVD Death | CVD Morbidity | CVD Morbidity and Mortality
Gerstein et al., 2001 [136] | 1 and 2 | CC | NA, SA, Europe | Multi-country | NOS | | X | | | X | X | 50.7
Hoy et al., 2001 [160] | NOS | Cohort | New Zealand | One Country | Aboriginal community | | X | | | | | 38.3
deGrauw et al., 2001 [216] | 2 | Cohort | Europe | One Country | Outpatient general clinic | | X | X | | | | 61.5
Muhlhauser et al., 2000a[283] | 1 | Cohort | Europe | One Country | Hospital specialty clinic | X | X | | | X | | 73.0
Muhlhauser et al., 2000b [293] | 1 | Cohort | Europe | One Country | Hospital specialty clinic | X | X | X | X | | | 39.5
Rachmani et al., 2000 [336] | 2 | Cohort | Europe | Unclear | NOS | X | | | | X | X | 48.6
Nosadini et al., 2000a [376] | 2 | Cohort | Europe | Single city | NOS | X | | | | | | 54.9
Biderman et al., 2000 [392] | 2 | Cohort | Israel | Single city | Primary care centers | | X | | | | | 48.6
Valmadrid et al., 2000 [411] | 2 | Cohort | NA | One Country | Primary care physicians | | | X | | | | 76.7
Mlacak et al., 1999 [465] | 1 and 2 | Cohort | Europe | One Country | Local health center | | X | | | | | 31.1
Hanninen et al., 1999 [580] | 2 | Cohort | Europe | Single city | Outpatient general clinic | | X | | | | | 55.2
Gaede et al., 1999 [613] | 2 | RCT | Europe | Single city | Hospital specialty clinic | X | X | X | | X | | 76.9
Mattock et al.,1998 [659] | 2 | Cohort | Europe | Single city | Hospital specialty clinic | | X | X | | | | 59.0
Araki et al., 1997 [930] | 2 | Cohort | Asia (Japan) | Single city | Outpatient specialty clinic | | X | X | | | | 36.1
Nelson et al.,1996 [967] | 2 | Cohort | NA | Single city | NOS | X | | | | | | 49.8
Miettinen et al., 1996 [977] | 2 | Cohort | Europe | One country | Hospital | | | | | X | X | 50.2
Rossing et al.,1996 [991] | 1 | Cohort | Europe | Single city | Hospital clinic Outpatient DM clinic | | X | | X | | | 66.8
Beilin et al.,1996 [1009] | 2 | Cohort | New Zealand | Single city | Hospital specialty clinic | | X | X | | | | 41.8
The Microalbumin uria Captopril Study Group, 1996[1061] | 1 | RCT | NA, Europe, Asia | Multi-country | Hospital specialty clinic | X | | | | | | 54.1
Niskanen et al.,1996 [1067] | 2 | Cohort | Europe | Single city | General population | | | X | | | | 44.8
Deckert et al.,1996 [1074] | 1 | Cohort | Europe | Single city | Specialty clinic | | | | | X | | 41.5
Agardh et al.,1996 [1075] | 2 | Cohort | Europe | Single city | Outpatient clinic | | | | | | X | 34.6
Gall et al., 1995 [1146] | 2 | Cohort | Europe | Unclear | Hospital specialty clinic | | X | X | X | | | 59.0
Crepaldi et al., 1995 [1158] | 2 | RCT | Europe | One country | Specialty centers | X | | | | | | 47.7
Chan et al., 1995 [1195] | 2 | Cohort | Asia | Single city | Hospital Gen clinic | X | X | | | | | 36.5
MacLeod et al.,1995 [1218] | 2 | Cohort | Europe | Single city | Hospital specialty clinic | | X | X | | | | 49.8
Lebovitz et al., 1994 [1366] | 2 | RCT | NA | NOS | NOS | X | | | | | | 34.5
Damsgaard et al., 1993 [1429] | 1 and 2 | Cohort | Europe | Single city | General population | | X | | | | | 32.0
Niskanen et al., 1993 [1452] | 1 and 2 | Cohort | Europe | Unclear | Outpatient general clinic | | X | | | | | 64.4
Neil et al., 1993 [1454] | 2 | Cohort | Europe | Single city | General population | | X | X | | | | 56.8
Torffvit et al.,1993 [1508] | 1 | Cohort | Europe | NOS | Outpatient clinic, Hospital clinic | | X | | | | | 47.3
Mattock et al.,1992 [1603] | 2 | Cohort | Europe | Single city | Hospital specialty clinic | | X | X | | | | 66.0
Damsgaard et al., 1992 [1622] | 2 | Cohort | Europe | Single city | General population | | X | | | | | 42.0
Schmitz et al., 1988 [1986] | 2 | Cohort | Europe | Single city | Outpatient clinic NOS | | X | | | | | 45.8
Klein et al., 1999 [3379] | 1 | Cohort | NA | One country | Outpatient general clinic | X | | | | | | 64.6
Stehouwer et al., 2002 [6834] | 2 | Cohort | Europe | Single city | Hospital specialty clinic | | X | | | | | 64.2

CC= Cohort study from a previous clinical trial; RCT = Randomized Controlled Trial; NA = North America, SA = South America

Table 69. Baseline Data for All Participants; Cohort Studies

Reference | Total N | Age, Y | Gender | | Race/Ethnicity n (%) | Diabetes Duration (Y) | Smoking n (%) | HbA1C* (%) | FG* | Prior CVD* n (%)
| | | M n (%) | F n (%)
Gerstein et al., 2001 [136]** | 3498 | Mean: 65.4 | 15 | 1324 (37.1) | ~ | Mean: 11.4 | Past: 2315(64.8) | ~ | ~ | CHD: 2143(60)
| | SD: 6.5 | | | | SD: 10.4 | | | | CBVD: 269(7.5)
| | | | | | | | | | PVD: 659(18.4)
Hoy et al., 2001 [160] | 86 | Mean: 66 | (47) | ~ | ~ | Mean: 9.6 | Current: 122 | ~ | ~ | ~
| | SD: 11 | | | | SD: 7.4
deGrauw et al., 2001 [216] | 262 | Mean: 66 | (39) | ~ | ~ | Mean: 5 | ~ | Mean: 6.3 | ~ | CVD: 28
| | SD: 11 | | | | SD: 3.4 | | SD: 1.9
Muhlhauser et al., 2000a [283] | 3674 | Mean: 27.5 | ~ | 1844 (50.2) | ~ | Mean: 10.5 | Current: (43) | ~ | ~ | CVD: 123 (3.4)
| | SD: 9.5 | | | | SD: 9.5
Muhlhauser et al., 2000b [293] | 3674 | Mean: 27.5 | ~ | 1844 (50.2) | ~ | Mean: 10.5 | Current: (43) | ~ | ~ | CVD: 123 (3.4)
| | SD: 9.5 | | | | SD: 9.5
Rachmani et al., 2000 [336] | 599 | Mean: 47.9^a^ | ~ | ~ | ~ | Mean: 1.98^a^ | ~ | Mean: 9.6^a^ | ~ | ~
| | | | | | SD: 0.8^a^ | | SD: 1.1^a^
Nosadini et al., 2000a [376] | 125 | Mean: 56.0^a^ | 60 | ~ | ~ | Mean: 12.7^a^ | ~ | ~ | ~ | ~
| | SD: 7.2^a^ | | | | SD: 6.1^a^
Biderman et al., 2000 [392] | 498 | Mean: 62.3^a^ | ~ | ~ | ~ | Mean: 9.2^a^ | Current: (20.1)^a^ | ~ | ~ | CHD: (30.9) ^a^
| | SD: 10.2^a^ | | | | SD: 7.8^a^
Valmadrid et al., 2000 [411] | 840 | Mean: 67.9 | (45) | ~ | ~ | Mean: 15.1 | Current: (47.2) | Mean: 9.3 | ~ | ~
| | SD: 11 | | | | SD: 7.9 | | SD: 1.9
Mlacak et al., 1999 [465] | 138 | Mean: 62 | 60 | 78 | ~ | ~ | Current: 20 (14.5) | Mean: 8.2 | ~ | CVD: 32 (23.2)
| | Range: 22–88 | | | | | | | | PVD: 38 (27.5)
Hanninen et al., 1999 [580] | 237 | Median: 58 | 134 | 118 | ~ | Median: 6 | ~ | Mean: 8.7 | ~ | ~
| | Range: 36–64 | | | | Range: 0–33 | | SD: 2
Mattock et al., 1998 [659] | 146 | Median: 59 | 82 | 64 | ~ | Median: 5 | Current: 50(34) | Median: 8.9 | Median: 9.1 | CHD: 50 (34)
| | IQR*: 53–63 | | | | IQR: 2–9 | | IQR: 7.5–10.3 | IQR: 7.6–11.8 mmol/L
Araki et al., 1997 [930] | 297 | Mean: 57.5^a^ | 164 | 133 | ~ | Mean: 9.3^a^ | Current: 122 (41.1) | Mean: 7.4^a^ | ~ | ~
| | SD: 11.3^a^ | | | | SD: 8.1^a^ | | SD: 1.8^a^
Nelson et al., 1996 [967] | 134 | Mean: 44.5^a^ | 45 | 59 | NA*: (100) | Mean: 13.7^a^ | | Mean: 11.9^a^ | ~ | ~
| | SD: 1.2^a^ | | | | | | SD: 0.4^a^
Miettinen et al., 1996 [977] | 1056 | Mean: 58.1^a^ | 580 | 476 | ~ | Mean: 8.1^a^ | ~ | Mean: 9.9^a^ | Mean: 11.8^a^ | CHD: (16.3)^a^
| | SD: 0.2^a^ | | | | SD: 0.2^a^ | | SD: 0.11^a^ | SE: 0.2^a^ mmol/L | CBVD: (6.3)^a^
| | | | | | | | | | PVD: (1.3)^a^
| | | | | | | | | | CVD: (21.7)^a^
Rossing et al., 1996 [991] | 939 | Mean: 39.6^a^ | 493 | 446 | ~ | Median: 18.6^a^ | Current: 557 (59) | Mean: 9.0^a^ | ~ | ~
| | SD: 12.6^a^ | | | | Range: 5–60 | | SD: 1.8^a^
Beilin et al., 1996 [1009] | 666 | Mean: 67 | 314 | 352 | ~ | Mean: 13 | Current: (15) | Mean: 10 | Mean: 10.8 | CHD: (25)
| | SD: 12 | | | | SD: 13 | | SD: 1.7 | SD: 3.8 mmol/L | CBVD: (7)
| | | | | | | | | | PVD: (18)
Niskanen et al., 1996 [1067] | 133 | Mean: 55.7 | 70 (53) | ~ | ~ | ~ | Current: 62 (47) | ~ | ~ | CBVD: 24 (18)
| | SD: 0.8
Deckert et al., 1996 [1074] | 259 | Mean: 34.7 | (54) | ~ | ~ | Mean 17.7 | Past: 64 | Mean: 8.4 | ~ | ~
| | 95%CI: 33.7–35.7 | | | | 95% CI: 17.1–18.7 | | 95%CI: 8.2–8.6
Agardh et al., 1996 [1075] | 451 | Mean: 53.5^a^ | 293 | 159 | ~ | Mean: 8.9^a^ | ~ | Mean: 8.2^a^ | ~ | ~
| | SD: 10.2^a^ | | | | SD: 7.6^a^ | | SD: 1.6^a^
Gall et al., 1995 [1146] | 328 | Mean: 54 | 202 | 126 | W: 328 | Median: 6.25^a^ | Past: 83 | Mean: 8.1^a^ | ~ | CHD:71
| | SD: 9 | | | | Range: 1–39 | Current: 140 | SD: 1.9^a^ | | CBVD:20
Chan et al.,1995 [1195] | 374 | Mean: 54.2 | 146 | 257 | ~ | Mean: 5.5 | ~ | Mean:10.8 | ~ | ~
| | SD:12.5 | | | | SD: 4.8 | | SD: 2.6
MacLeod et al.,1995 [1218] | 306 | Mean: 67.2^a^ | ~ | ~ | ~ | Mean: 8.7 | ~ | ~ | ~ | CHD: (30.1)^a^
| | SD: 1.3^a^ | | | | SD: 1.0 | | | | PVD: (26.1)^a^
Damsgaard et al., 1993 [1429] | 228 | ~ | 91 | 137 | ~ | ~ | ~ | ~ | ~ | ~
Niskanen et al., 1993 [1452] | 132 | Mean: 56.2^a^ | 57 | 51 | ~ | ~ | ~ | ~ | Mean: 12.0^a^ | ~
| | SD: 5.9^a^ | | | | | | | SD: 4.2^a^ mmol/L
Neil et al., 1993 [1454] | 249 | Mean: 66.1^a^ | 121 | 125 | ~ | Mean: 7.4^a^ | Current: 55 | Mean: 9.9^a^ | ~ | CHD: 35
| | SD: 11.1^a^ | | | | SD: 6.9^a^ | | SD: 2.4^a^ | | CBVD: 0
| | | | | | | | | | PVD: 24
Torffvit et al.,1993 [1508] | 476 | Mean: 35 | 254 | 222 | ~ | Mean 20 | ~ | ~ | ~ | ~
| | SD: 11 | | | | SD: 12
Mattock et al.,1992 [1603] | 252 | Mean: 56.2^a^ | 82 | 59 | W (100) | Mean: 5.5^a^ | Current: (36)^a^ | Mean: 9.0^a^ | ~ | ~
| | SE: 1.2^a^ | | | | SE: 0.7^a^ | | SE: 1.9^a^
Damsgaard et al., 1992 [1622] | 228 | Median: 68.2 | 91 (40) | 137 (60) | ~ | Median: 5.4 | Current: 82 (36) | | Median: 7.55 | CHD: 133(58.3)
| | IQR: 64.1–71.6 | | | | IQR: 2.7–10.4 | | | IQR: 5.53–10.3 mmol/L
Schmitz et al., 1988 [1986] | 503 | Mean: 65.9^a^ | 222 | 281 | ~ | Mean: 7.0^a^ | ~ | ~ | Mean: 9.2 | ~
| | SD: 6.3^a^ | | | | SD: 5.3^a^ | | | SD: 2.4 mmol/L
Klein et al., 1999 [3379] | 7654 | 31.3 | (49) | ~ | ~ | Mean: 15.3 | Past: (18) | Mean: 10 | ~ | ~
| | | | | | Range: 1–37 | Current: (22)
Stehouwer et al., 2002 [6834] | 328 | Mean: 53.8^a^ | (61.6)^a^ | ~ | W: (100) | Median: 6.4^a^ | Past: (25)^a^ | Median: 7.9^a^ | ~ | CHD: (9.8)^a^
| | SD: 8.1^a^ | | | | | Current: (47)^a^
| | | | | | | Never: (28)^a^

* Abbreviations: HbA1C= Hemoglobin A1C, FG=Fasting Glucose, CVD=Cardiovascular Disease, CHD=Coronary Heart Disease, PVD=Peripheral Vascular Disease, CBVD=Cerebrovascular Disease, W=Caucasian, AA=African American, NA=Native American, Oth=Other, IQR=Interquartile Range, SE=Standard Error, SD=Standard deviation

a Value is a weighted mean of values presented for subgroups in paper

** Gerstein et al., 2001 is a cohort analysis of a clinical trial

Table 70. Baseline Data for All Study Participants; Randomized Controlled Trials

Reference and Study Group | Total N | Age, Y | Gender | | Race/Ethnicity n (%) | Diabetes Duration (Y) | Smoking n (%) | HbA1C* (%) | FG | Prior CVD* n (%)
| | | M n (%) | F n (%)
Gaede et al., 1999 [613] | 160
“Standard” | 80 | Mean: 55.2 | 56 | 24 | ~ | Median: 6 | Past: 33 | Mean: 8.8 | Mean: 10.5 | CHD: 21
| | SD:7.2 | | | | IQR: 4–10 | Current: 27 | SD: 1.7 | SD: 3 | CBVD: 3
| | | | | | | | | | PVD: 2
“Intensive” | 80 | Mean: 54.9 | 63 | 17 | ~ | Median 5.5 | Past: 27 | Mean: 8.4 | Mean: 10.1 | CHD: 18
| | SD:7.2 | | | | IQR: 2–8.8 | Current: 32 | SD: 1.6 | SD: 3.1 | CBVD: 2
| | | | | | | | | | PVD: 1
The Microalbuminuria Captopril Study Group, 1996 [1061] | 235
“Captopril” | 116 | Mean: 31.8 | 63 | 53 | W: 108 | Mean: 17.5 | Current: 46 | Mean: 8.1 | ~ | ~
| | Range:17–54 | | | AA: 3 | Range:4–33 | | 95% CI:
| | | | | Oth: 5 | | | 7.9–8.4
“Placebo” | 119 | Mean: 32.5 | 60 | 59 | W: 110 | Mean: 18.1 | Current: 43 | Mean: 8.2 | ~ | ~
| | Range:15–57 | | | AA: 2 | Range:4–29 | | 95% CI:
| | | | | Oth: 7 | | | 7.9–8.5
Crepaldi et al., 1995 [1158] | 162
“Lisinopril” | 83 | ~ | 40 | 43 | ~ | ~ | ~ | Mean: 7.3 | Mean: 8.3 | ~
| | | | | | | | SD: 1.9 | SD: 2.8
| | | | | | | | | mmol/L
“Nifedipine” | 79 | ~ | 38 | 41 | ~ | ~ | ~ | Mean: 7.1 | Mean: 8.6 | ~
| | | | | | | | SD: 1.8 | SD: 3
| | | | | | | | | mmol/L
Lebovitz et al.,1994 [1366] | 121 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
“Enalapril” | 63 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~
“Control” | 58 | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~ | ~

* Abbreviations: HbA1C= Hemoglobin A1C, FG=Fasting Glucose, CVD=Cardiovascular Disease, CHD=Coronary Heart Disease, PVD=Peripheral Vascular Disease, CBVD=Cerebrovascular Disease, W=Caucasian, AA=African American, NA=Native American, Oth=Other, IQR=Interquartile Range, SE=Standard Error, SD=Standard deviation

a Value is a weighted mean of values presented for subgroups in paper

Table 71. Diagnosis of Diabetes; Cohort Studies (** Indicates Cohort study from previous clinical trial)

Reference | DM type | Not mentioned | Insulin rx | Chart review | Self report of previous physician diagnosis | Previous physician diagnosis | Fasting Glucose | Non Fasting Glucose | Age at diagnosis | C-peptide Concentration | Additional Comments
Gerstein et al., 2001 [136]** | 1 and 2 | X
Hoy et al., 2001 [160] | NOS | X
deGrauw et al., 2001[216] | 2 | X
Muhlhauser et al., 2000a [283] | 1 | | | | | | | | | | • Insulin treatment before the age of 31.
Muhlhauser et al., 2000b [293] | 1 | | | | | | | | | | • Insulin treatment before the age of 31.
Rachmani et al., 2000 [336] | 2 | | | | | | | | >40 yrs | | • Diet and/or oral agents only within 1–6 months of diagnosis.
Nosadini et al., 2000a [376] | 2 | | | | | | | | >39 yrs | | • No insulin therapy within first 2 yrs of diagnosis.
Nosadini et al., 2000b [392]** | 2
Valmadrid et al., 2000 [411] | 2 | | | X | | | | | ≥30 yrs
Mlacak et al., 1999 [465] | 1 and 2 | X
Hanninen et al., 1999 [580] | 2 | | | | | | <6.7mmol/L
Mattock et al., 1998 [659] | 2 | | | | | | | | >30 yrs | | • No history of ketosis and no insulin in 1st year after diagnosis.
Araki et al., 1997 [930] | 2 | X
Nelson et al.,1996 [967] | 2
Miettinen et al., 1996 [977] | 2 | | | | | | | | | | • WHO criteria
| | | | | | | | | | | • No history of ketoacidosis.
Rossing et al.,1996 [991] | 1 | | | | | | | | <40 yrs
Beilin et al.,1996 [1009] | 2 | X
Niskanen et al., 1996 [1067] | 2 | | | | | X | | | | | • WHO criteria 1980
Deckert et al.,1996 [1074] | 1 | X
Agardh et al., 1996 [1075] | 2 | | | | | | | | ≥30 yrs
Gall et al., 1995 [1146] | 2 | | | | | | | | | | • Treatment by diet alone or diet combined with oral hypoglycemic agents
| | | | | | | | | | | • Insulin treatment and onset diabetes > age 40 and BMI >25 kglm2 for women, BMI> 27 kglm2 in men
| | | | | | | | | | | • Insulin treatment, normal weight, and glucagon stimulated C-peptide value >0
Chan et al.,1995 [1195] | 2 | | | | | | | | | | • Insulin treatment within first month of diagnosis of diabetes
MacLeod et al.,1995 [1218] | 2 | | | | | | | | >35 yrs | | • No insulin in first 2 years
Damsgaard et al., 1993 [1429] | 1 and 2 | | | | | | >7mmol/L | >=11 mmol/L | | | • 1980 WHO criteria
Niskanen et al., 1993 [1452] | 1 and 2 | | | | | | >7mmol
Neil et al., 1993 [1454] | 2 | | | | | | | | >30 yrs | | • Diagnosed as treated without insulin, or if treated with insulin, age of diagnosis >30 with no evidence of ketosis and at least 1 month elapsed before start of treatment.
Torffvit et al.,1993 [1508] | 1 | | X | | | | | | <30 yrs
Mattock et al.,1992 [1603] | 2 | | | | | | >=7.8 mM | >=11 mM | >30 yrs | | • No insulin use in 1st yr of diagnosis
Damsgaard et al., 1992 [1622] | 2 | | | | X | | >7mmol/L | | | | • If fasting blood glucose was <7.0 mmoL/liter, physician medical records were checked to confirm the diagnosis
Schmitz et al., 1988 [1986] | 2 | | | | | | | | | | • Subgroup (n=416) used a “strickter” definition of NIDDM= no insulin therapy for at least 2yrs and those with urinary albumin concentration <200 mg/mL (clinical data and medical records)
Klein et al., 1999 [3379] | 1 | | X | | | | | | < 30 yrs
Stehouwer et al., 2002 [6834] | 2 | | | | | | | | >40 yrs | >=0.6 | • Treated by diet alone or by diet combined with oral hypoglycemic agents
| | | | | | | | | | | • Treatment with insulin plus diabetes onset >40 yrs and a BMI above normal (>=25kg/m^2 in women, >=27kg/m^2 in men) at the time of diagnosis

Table 72. Diagnosis of Diabetes; Randomized Controlled Trials

Reference | DM type | Diagnosis Criteria Not mentioned | WHO Criteria Year | Additional Comments
Gaede et al., 1999 [613] | 2 | | 1985
The Microalbuminuria Captopril Study Group, 1996 [1061] | 1 | X
Crepaldi et al., 1995 [1158] | 2 | X
Lebovitz et al., 1994 [1366] | 2 | | | Diabetes diagnosed by “age at diagnosis of diabetes, clinical course, and response to treatment.”

Table 73. Renal Outcomes; Cohort Studies: Change in GFR at Study Follow Up

Reference | DM Type | F/U, (Y) | UAE Ascertainment | Timing | n | Level of UAE* | Baseline UAE for group | Mean % Change GFR from Baseline
Nelson et al., 1996 [967] | 2 | 4 | ACR | Random | 143 | ALL | ~ | ~
| | | | | 20 | <30 mg/g | Mean: 10.9 mg/g , 95% | +2
| | | | | | | CI: 8.8–13.5
| | | | | 50 | 30 to 299 mg/g* | Mean: 87.7 mg/g, 95% | -3
| | | | | | | CI: 72.8–106.0
| | | | | 34 | ≥300 mg/g | Mean: 1180 mg/g, 95% | -35
| | | | | | | CI: 844–1650

n=Number of participants enrolled in for a given level of urinary albumin excretion, DM= Diabetes mellitus, F/U=Follow up, UAE= Urinary albumin excretion, GFR=Glomerular filtration rate ~=Data not provided

* Level representing microalbuminuria

Table 74. Renal Outcomes; Cohort Studies: Rate of Change in GFR

Reference | DM Type | F/U, (Y) | UAE Ascertainment | Timing | n | Level of UAE* | Baseline UAE for group | Rate of Change in GFR
Rachmani et al., 2000 [336] | 2 | 8 | AER | 24 hour | 599 | ALL | ~ | ~
| | | | | 359 | <=10 mg/24hrs | Mean: 7.2, SD: 1.3 | Mean: -1.19,
| | | | | | | | SD: 0.36
| | | | | | | | ml/min/yr
| | | | | 131 | 10.1–20 mg/24hrs* | Mean: 16.5, SD: 1.6 | Mean: -1.64,
| | | | | | | | SD: 0.58
| | | | | | | | ml/min/yr
| | | | | 109 | 20.1–30 mg/24hrs | Mean: 25.7. SD: 2.1 | Mean: -2.52,
| | | | | | | | SD: 0.96
| | | | | | | | ml/min/yr
Nosadini, et al., 2000a [376] | 2 | 4 | AER | 24 hour | 125 | ALL | ~ | ~
| | | | | 17 | 20–199 μg/min | Median: 41, | Mean: -5.54,
| | | | | | (“Progressors”)* | Range: 232–3126 | SD: 6.74
| | | | | | | | ml/min/1.73m^2^
| | | | | 17 | 20–199 μg/min | Median: 33, | Mean: +3.96,
| | | | | | (“Non-Progressors”)* | Range: 200–2200 | SD: 5.84
| | | | | | | | ml/min/1.73m^2^
| | | | | 37 | >199 μg/min | Median 420, | Mean: -10.92,
| | | | | | (“Progressors”) | Range: 21–199 | SD: 9.99
| | | | | | | | ml/min/1.73m^2^
| | | | | 37 | >199 μg/min (“Non-Progressors”) | Median: 371, | Mean: +4.08,
| | | | | | | Range: 23–199 | SD: 11.0
| | | | | | | | ml/min/1.73m^2^

n=Number of participants enrolled in for a given level of urinary albumin excretion, DM= Diabetes mellitus, F/U=Follow up, UAE= Urinary albumin excretion, GFR=Glomerular filtration rate ~=Data not provided

* Level representing microalbuminuria

Table 75. Renal Outcomes; Cohort Studies: Rate of change of 1/serum creatinine

Reference | DM Type | F/U, (Y) | UAE Ascertainment | Timing | n | Level of UAE* | Baseline UAE for group | Rate of Change in 1/serum creatinine
Chan et al., 1995 [1195] | 2 | 2 | ACR | Random | 374 | ALL | ~ | ~
| | | | | 208 | <5.6 mg/mmol | ~ | Mean: -27.3, SD: 62.5
| | | | | | | | l/μmol/month
| | | | | 94 | 5.6–38 mg/mmol* | ~ | Mean: -43.4, SD: 68.6
| | | | | | | | l/μmol/month
| | | | | 72 | >38 mg/mmol | ~ | Mean: -108.8, SD: 98.8
| | | | | | | | l/μmol/month

n=Number of participants enrolled in for a given level of urinary albumin excretion, DM= Diabetes mellitus, F/U=Follow up, UAE= Urinary albumin excretion, GFR=Glomerular filtration rate ~=Data not provided

* Level representing microalbuminuria

Table 76. Renal Outcomes; Cohort Studies: Rate of change in creatinine clearance

Reference | DM Type | F/U, (Y) | UAE Ascertainment | Timing | n | Level of UAE* | Baseline UAE for group | Risk of decline in creatinine clearance >3ml/min/1.73m^2^/year Relative risk (95%CI)
Klein et al., 1999 [3379] | 1 | 10 | Reagent strip and agglutination assay | Random | 765 | ALL | ~ | ~
| | | | | 283 | 0–30 mg/L | ~ | 1.0 (Reference)
| | | | | 109 | 30–299 mg/L* | ~ | 1.45 (1.09–1.92)
| | | | | 110 | ≥300 mg/L | ~ | 2.03 (1.61–2.56)

n=Number of participants enrolled in for a given level of urinary albumin excretion, DM= Diabetes mellitus, F/U=Follow up, UAE= Urinary albumin excretion, GFR=Glomerular filtration rate ~=Data not provided

* Level representing microalbuminuria

Table 77. Renal Outcomes; Cohort Studies: Incidence of ESRD, need for renal replacement therapy, or kidney transplantation

Reference | DM Type | F/U, (Y) | UAE Ascertainment | Timing | n | Level of UAE* | Baseline UAE for group | Cumulative Incidence
Mulhauser et al., 2000a, b [283,293] | 1 | 10 | AER | 24 hour | 3674 | ALL | ~ | 0.05%
| | | | | 1883 | <50 mg/L | ~ | 1.5%
| | | | | 1296 | 51–499 mg/L* | ~ | 34.8%
| | | | | 224 | ≥500 mg/L | ~
| | | | | | | | Relative Risk (95%CI) of Creatinine>2.0 or Need for Renal Replacement Therapy
Klein et al., 1999 [3379] | 1 | 10 | Reagent strip and agglutination assay | Random | 765 | ALL | ~
| | | | | 283 | 0–30mg/L | ~ | 1.0 (Reference)
| | | | | 109 | 30–299 mg/L* | ~ | 8.79 (4.19–18.45)
| | | | | 110 | ≥300 mg/L | ~ | 12.54 (13.3–41.65)

n=Number of participants enrolled in for a given level of urinary albumin excretion, DM= Diabetes mellitus, F/U=Follow up, UAE= Urinary albumin excretion, GFR=Glomerular filtration rate ~=Data not provided

* Level representing microalbuminuria

Table 78. Renal Outcomes; Randomized Controlled Trials: Change in GFR at Study Follow Up

Reference | DM Type | F/U, (Y) | UAE Ascertainment | Timing | n | Intervention Type | Level of UAE* | Baseline UAE for group | Absolute Change GFR from Baseline
Gaede et al., 1999 [613] | 2 | 4 | AER | 24 hour | 160 | ALL | ~ | ~ | ~
| | | | | 80 | Intensive | 30–300 mg/24hrs* | | Mean: -11,
| | | | | | Diabetes | | Median: 78, | SD: 20
| | | | | | Intervention | | Range: 61–231 | ml/min/1.73m^2^
| | | | | 80 | Conventional | 30–300 mg/24hrs* | | Mean: -13,
| | | | | | Diabetes | | Median: 69, | SD: 15
| | | | | | Intervention | | Range: 47–113 | ml/min/1.73m^2^

n=Number of participants enrolled in for a given level of urinary albumin excretion, DM= Diabetes mellitus, F/U=Follow up, UAE= Urinary albumin excretion, GFR=Glomerular filtration rate ~=Data not provided

* Level representing microalbuminuria

Table 79. Renal Outcomes; Randomized Controlled Trials: Rate of Change in GFR

Reference | DM Type | F/U, (Y) | UAE Ascertainment | Timing | n | Intervention Type | Level of UAE* | Baseline UAE for group | Rate of Change in GFR
Lebovitz et al., 1994 [1366] | 2 | 3 | AER | 24 hour | 121 | ALL | ~ | ~ | ~
| | | | | 28 | Enalapril | <30 mg/24hrs | ~ | Mean: +0.386,
| | | | | | | | | SE: 0.178
| | | | | | | | | ml/min/1.73m^2^/month
| | | | | 18 | | 30–300 mg/24hrs * | ~ | Mean: -0.003,
| | | | | | | | | SE: 0.179
| | | | | | | | | ml/min/1.73m^2^/month
| | | | | 17 | | >300 mg/24hrs | ~ | Mean: -0.533,
| | | | | | | | | SE: 0.158
| | | | | | | | | ml/min/1.73m^2^/month
| | | | | 18 | Control | <30 mg/24hrs | ~ | Mean: -0.235,
| | | | | | | | | SE: 0.15
| | | | | | | | | ml/min/1.73m^2^/month
| | | | | 19 | | 30–300 mg/24hrs * | ~ | Mean: -0.416,
| | | | | | | | | SE: 0.192
| | | | | | | | | ml/min/1.73m^2^/month
| | | | | 21 | | >300 mg/24hrs | ~ | Mean: -0.785,
| | | | | | | | | SE: 0.253
| | | | | | | | | ml/min/1.73m^2^/month

n=Number of participants enrolled in for a given level of urinary albumin excretion, DM= Diabetes mellitus, F/U=Follow up, UAE= Urinary albumin excretion, GFR=Glomerular filtration rate ~=Data not provided

* Level representing microalbuminuria

Table 80. Renal Outcomes; Randomized Controlled Trials: Change in Creatinine Clearance at Study Follow up

Reference | DM Type | F/U, (Y) | UAE Ascertainment | Timing of Urine Collection | n | Intervention Type | Level of UAE* | Baseline UAE for group | Absolute Change Creatinine Clearance from Baseline
Crepaldi et al., 1995 [1158] | 2 | 0.5 | AER | Timed | 162 | ALL | ~ | ~ | ~
| | | | | 83 | Lisinopril | 20–200 μg/min* | Geo. Mean: 36, | Mean: -1, SD: 2
| | | | | | | | Tol. Factor: 1.3 | ml/min/1.73m^2^
| | | | | 79 | Nifedipine | 20–200 μg/min* | Geo. Mean: 38, | Mean: -2, SD: 2
| | | | | | | | Tol. Factor: 1.3 | ml/min/1.73m^2^

n=Number of participants enrolled in for a given level of urinary albumin excretion, DM= Diabetes mellitus, F/U=Follow up, UAE= Urinary albumin excretion, GFR=Glomerular filtration rate ~=Data not provided

* Level representing microalbuminuria

Table 81. Renal Outcomes; Randomized Controlled Trials: Rate of Change in Creatinine Clearance

Reference | DM Type | F/U, (Y) | UAE Ascertainment | Timing of Urine Collection | n | Intervention Type | Level of UAE* | Baseline UAE for group | Rate if Change in Creatinine Clearance
The Microalbuminuria Captopril Study Group, 1996 [1061] | 1 | 2 | AER | Timed | 235 | ALL | | ~ | ~
| | | | | 116 | Captopril | 20–200 μg/min* | Mean: 57, 95% | Mean: -1.4,
| | | | | | | | CI: 51–64 | Range: 2.6–5.3 ml/min/1.73m^2^/year
| | | | | 119 | Conventional | 20–200 μg/min* | Mean: 61, 95% | Mean: -6.4,
| | | | | | | | CI: 53–69 | Range: 2.5–10.5 ml/min/1.73m^2^/year

n=Number of participants enrolled in for a given level of urinary albumin excretion, DM= Diabetes mellitus, F/U=Follow up, UAE= Urinary albumin excretion, GFR=Glomerular filtration rate ~=Data not provided

* Level representing microalbuminuria

Table 82. All Cause Mortality; Cohort Studies: type 1 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Cumulative Incidence | Crude Risk | Adj. Risk
Muhlhauser et al., 2000 a,b [283],[293] | 1 | 10 | AER | 24 hour | 3674 | ALL | ~
| | | | | 1883 | <50 mg/L | ~ | 3.2% | ~ | RH: 1.0
| | | | | | | | | | 95% CI:(Ref)
| | | | | 1296 | 51–499 mg/L* | ~ | 5.3% | ~ | ~
| | | | | 224 | ≥500 mg/L | ~ | 31.1% | ~ | ~
| | | | | | >50 mg/L* | ~ | ~ | ~ | RH: 3.84
| | | | | | | | | | 95%CI: (2.64–5.6)
Rossing et al., 1996 [991] | 1 | 10 | AER | 24 hour | 939 | ALL | | | ~ | ~
| | | | | 593 | <31 mg/24 hrs | Median:10 | 15% | ~ | ~
| | | | | | | Range:1–196
| | | | | 181 | 31–299 mg/24 hrs* | Median: 83 | 25% | ~ | ~
| | | | | | | Range:31–398
| | | | | 165 | ≥300 mg/24 hrs | Median: 920 | 44% | ~ | ~
| | | | | | | Range:43–8213
Torffvit et al., 1993 [1508] | 1 | 5 | AER | Random | | ALL | | | ~ | ~
| | | | | 186 | <12.5 mg/L | ~ | 1.6% | ~ | ~
| | | | | 103 | 12.5–30 mg/L | ~ | 2.9% | ~ | ~
| | | | | 118 | 31–299 mg/L* | ~ | 4.2% | ~ | ~
| | | | | 69 | ≥300 mg/L | ~ | 12%

Adjustments:

1.Muhlhauser et al., 2000 a, b [283],[293]-age, gender, duration of diabetes, smoking, total cholesterol, social stauts

Table 83. All Cause Mortality; Cohort Studies: type 2 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Cumulative Incidence | Crude Risk | Adj. Risk
deGrauw et al., 2001 [216] | 2 | 6 | AER | Random | 262 | ALL | ~ | ~ | ~ | ~
| | | | | 138 | <20 mg/L | Mean: 9.6, | 21.7% | ~ | Model 1: RR: 1.0 (Ref)
| | | | | | | SD: 4.7 | | | Model 2: RR: 1.0 (Ref)
| | | | | 25 | 20–200 mg/L* | Mean: 55.5, | 26% | ~ | Model 1: RR:1.4
| | | | | | | SD: 51.1 | | | 95% CI: (0.8–2.7)
| | | | | | | | | | Model 2: RR:1.2
| | | | | | | | | | 95% CI: (0.8–2.2)
Biderman et al., 2000 [392] | 2 | 8 | AER | Random | 498 | ALL | ~ | ~ | ~ | ~
| | | | | 176 | <30 mg/L men | ~ | 21% | ~ | RR: 1.0 (Ref)
| | | | | 57 | ≥30 mg/L men* | ~ | 54% | ~ | 3.57 (p<0.002)
| | | | | 204 | <30 mg/L women | ~ | 24% | ~ | ~
| | | | | 61 | ≥30 mg/L women* | ~ | 51% | ~ | ~
Hanninen et al., 1999 [580] | 2 | 5 | AER | Timed | 237 | ALL | Median:10 | 8.3 % | ~ | ~
| | | | | | | Range 1–700
| | | | | 159 | <20 μg/min | ~ | 3.8 % | ~ | ~
| | | | | 68 | 20–200 μg/min* | ~ | 13.2 % | ~ | ~
| | | | | 10 | >200 μg/min | ~ | 40 % | ~ | ~
Mattock et al., 1998 [659] | 2 | 7 | AER | Timed | 146 | ALL | Median: 7.3 | Cumulative: 25% | ~
| | | | | | | Range: 4.4–20.8
| | | | | | <20 μg/min | Median: 5.8 | ~ | ~ | Model 1, RH: 1.0 (Ref)
| | | | | | | Range: 3.8–9.9 | | | Model 2, RH: 1.0 (Ref)
| | | | | | 20–199 μg/min* | Median: 67.8 | ~ | ~ | Model 1, RR: 3.94
| | | | | | | Range: 29.9–98.5 | | | 95% CI: (2.04–7.62)
| | | | | | | | | | Model 2, RR: 1.15
| | | | | | | | | | 95% CI: (0.47–2.84)
| | | | | | ≥200 μg/min | ~
Araki et al., 1997 [930] | 2 | 6 | AER | 24 hour | 297 | ALL | ~ | ~ | ~ | ~
| | | | | 201 | <15 μg/min | Mean: 6.7 | Rate: 0.82/100 person-y | ~ | ~
| | | | | | | SD: 3.5
| | | | | 96 | 15–199 μg/min* | Mean: 49 | Rate: 1.35 100 person-y | ~ | ~
| | | | | | | SD: 39.1
Beilin et al., 1996 [1009]; | 2 | 7 | AER | Random | 666 | ALL | Mean: 149
| | | | | | | SD:530
| | | | | 390 | <30 mg/L | ~ | 17.2 % | ~ | Model 1, RH: 1.0 (Ref)
| | | | | | | | | | Model 2, RH: 1.0 (Ref)
| | | | | 211 | 30–300 mg/L* | ~ | 32 % | ~ | Model 1, RH: 1.83(1.31–2.57)
| | | | | | | | | | Model 2, RH: 1.77(1.22–2.57)
| | | | | 65 | >300 mg/L | ~ | 49.2% | ~ | Model 1, RH: 3.67(2.39– 5.61)
| | | | | | | | | | Model 2, RH: 3.58(2.19– 5.88)
Gall et al., 1995 [1146] | 2 | 5 | AER | 24 hour | 328 | ALL | | 16% | ~ | RR: 1.9 (1.4–2.6) per log_10_AERmg/24hrs
| | | | | 191 | <30 mg/24hrs | Median:8 | 8.4% | ~
| | | | | | | Range:1–29
| | | | | 86 | 30–299 mg/24hrs* | Median:68 | 19.7% | ~
| | | | | | | Range:30–244
| | | | | 51 | ≥300 mg/24hrs | Median:908 | 35.3% | ~
| | | | | | | Range:52–8019
| | | | | 277 | <300 mg/24hrs | ~ | ~ | ~ | RR: 2.0 (1.1–3.7) per log_10_AERmg/24hrs
Chan et al., 1995 [1195] | 2 | 2 | ACR | Random | 374 | ALL | Median:3.6 | ~ | ~ | ~
| | | | | | | Range:35.7–89.3
| | | | | 208 | <5.6 mg/mmol | ~ | ~ | RR: 1.0 (Ref) | ~
| | | | | 94 | 5.6–38 mg/mmol* | ~ | ~ | RR: 3.7 (1.1–12.4) | ~
| | | | | 72 | >38 mg/mmol | ~ | ~ | RR: 11 (3.8– 31.6) | ~
| | | | | 166 | ≥5.6 mg/mmol* | ~ | ~ | RR: 7.1 (2.5– 19.9) | ~
MacLeod et al.,1995 [1218] | 2 | 8 | AER | Timed | 306 | ALL | ~ | ~ | ~ | ~
| | | | | 153 | <10.6 μg/min | ~ | 41.2% | ~ | ~
| | | | | 74 | 10.6–29.9 μg/min | ~ | 58.8% | ~ | ~
| | | | | 48 | 30–149.9 μg/min* | ~ | 50.0% | ~ | ~
| | | | | 31 | ≥150 μg/min | ~ | 74.2% | ~ | ~
Neil et al., 1993 [1454] | 2 | 6 | AER | Random | 249 | ALL | ~ | | ~
| | | | | 145 | <15 mg/L | ~ | 30.3% | ~ | RH: 1.0(Ref)
| | | | | 45 | 15–39mg/L | ~ | 37.8% | ~ | RH: 1.0 (0.57–1.76)
| | | | | 36 | 40–200mg/L* | ~ | 58.3% | ~ | RH: 2.15 (1.37–3.65)
| | | | | 10 | >200mg/L | ~ | 36.9% | ~ | RH:1.19 (0.41–3.45)
Mattock et al., 1992 [1603] | 2 | 3 | AER | Timed | 252 | ALL | ~ | 9.9% | ~ | ~
| | | | | 105 | <20 μg/min | ~ | 3.8% | ~
| | | | | 36 | 20–200 μg/min* | ~ | 28% | ~
Damsgaard et al., 1992 [1622] | 2 | 9 | AER | Timed | 228 | ALL | Median:17.4 | 48.7% | ~ | ~
| | | | | | | IQR: 7.89–77.9 | | ~ | ~
| | | | | 104 | <17.4 μg/min | ~ | 37.5% | ~ | ~
| | | | | 107 | ≥17.4 μg/min* | ~ | 58.9% | ~ | ~
Schmitz et al., 1988 [1986] | 2 | 10 | AER | Random | 503 | ALL | ~ | ~ | ~ | ~
| | | | | 328 | ≤15 mg/mL | ~ | ~ | ~ | RR:1.0(Ref)
| | | | | 88 | 16–40 mg/mL | ~ | ~ | ~ | RR:1.53 (p=0.007)
| | | | | 62 | 41–200 mg/mL* | ~ | ~ | ~ | RR:2.28 (p=0.000002)
| | | | | 25 | >200 mg/mL | ~ | ~ | ~ | RR:1.82 (p=0.02)
Stehouwer et al., 2002 [6834] | 2 | 9 | AER | 24 hour | 328 | ALL | ~ | 34% | ~ | ~
| | | | | 198 | <30mg/24hrs | ~ | ~ | ~ | RR:1.0 (Ref)
| | | | | 91 | 30–299 mg/24hrs* | ~ | ~ | ~ | RR:1.86 (1.17–2.96)
| | | | | 46 | ≥300 mg/24hrs | ~ | ~ | ~ | RR:2.76 (1.52–4.85)

Adjustments:

1. deGrauw et al., 2001-Model 1: age; Model 2: age, gender, duration of diabetes

2. Nosadini el al., 2000b-Adjustment unclear

1. Mattock et al., 1998- Model 1: age; Model 2: age, gender, diabetes duration, glycemic control, total cholesterol, HDL/LOL cholesterol, history of CVD

2. Araki et al., 1997-Incidence rates adjusted for age, gender

3. Beilin et at., 1996-Model 1: age, gender; Model 2: age, gender, diabetes duration, weight, blood pressure, smoking, age at diagnosis, total cholesterol, HDL/LDL cholesterol, history of CVD neuropathy, PVD, or cerebrovascular disease

1. Gall et al., 1995-age, glycemic control, CVD history

1. Neil et at., 1993-age, diabetes duration, retinopathy, lens opacity, claudication

2. Schmitz et al., 1988-age, gender, diabetes duration, weight, blood pressure, age at diagnosis, glycemic control, retinopathy treatment, serum creatinine

1. Stehouwer et al., 2002-age, gender, duration of diabetes, weight, blood pressure, glycemic control, total cholesterol, CVD history, C-reactive protein

Table 84. All Cause Mortality; Cohort Studies: type 1 and 2 diabetes or Diabetes Type Not Specified (NOS)

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Incidence | Crude Risk | Adj. Risk
Hoy et al., 2001 [160] | NOS | 6 | ACR | Random | 86 | ALL | Mean: 4.2 95%CI: 3.6–4.8 | ~ | ~ | ~
| | | | | ~ | <3.4 g/mol | | Rate : 3.2/100 | ~ | ~
| | | | | | | | person-y 95%CI: 0.8–12.8
| | | | | ~ | 3.4–33 g/mol* | ~ | Rate: 1.7/100 | ~ | ~
| | | | | | | | person-y 95%CI: 0.42–6.66
| | | | | ~ | 34–99 g/mol | ~ | Rate: 3.48/100 | ~ | ~
| | | | | | | | person-y 95%CI: 1.12–10.8
| | | | | ~ | ≥100 g/mol | ~ | Rate: 3.6/100 | ~ | ~
| | | | | | | | person-y 95%CI: 1.16–11.13
Mlacak et al., 1999 [465] | 1, 2 | 5 | ACR | Random | 138 | ALL | ~ | Cumulative: 13% | ~ | ~
| | | | | 82 | <2.5 mg/mmol | ~ | Cumulative: 3.7% | ~ | ~
| | | | | 40 | 2.5–25 mg/mmol* | ~ | Cumulative: 10% | ~ | ~
| | | | | 16 | >25 mg/mmol | ~ | Cumulative: 69% | ~ | ~
Damsgaard et al., 1993 [1429] | 1, 2 | 11 | AER | Timed | 228 | ALL | ~ | Cumulative: 59.7% | ~ | ~
| | | | | 89 | <15 μg/min | ~ | Cumulative: 49.9% | ~ | ~
| | | | | 122 | ≥15 μg/min* | ~ | Cumulative: 63.9% | ~ | ~
Niskanen et al., 1993 [1452] | 1 , 2 | 11 | AER | 24 hour | 132 | ALL | ~ | | ~ | ~
| | | | | 82 | ≤35 mg/24hrs | ~ | Cumulative:3.8% | ~ | ~
| | | | | 26 | >35 mg/24hrs* | ~ | Cumulative:15.4% | ~ | ~

Table 85. All Cause Mortality; Clinical Trials Analyzed as Cohort Studies: type 1 and 2 diabetes or Diabetes Type Not Specified (NOS)

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Cumulative Incidence | Crude Risk | Adj. Risk
Gerstein et al., 2001 [136] | 1, 2 | 4.5 | ACR | Random | 3498 | ALL | ~ | ~ | ~ | ~
| | | | | ~ | <0.22 mg/mmol | ~ | ~ | RR: 1.0 (Ref) | ~
| | | | | ~ | 0.22–0.57 mg/mmol | ~ | ~ | RR: 0.86 | ~
| | | | | | | | | 95% CI:(0.58–1.28)
| | | | | ~ | 0.58–1.62 mg/mmol | ~ | ~ | RR: 1.41 | ~
| | | | | | | | | 95% CI:(1.01–1.95)
| | | | | ~ | >1.62 mg/mmol | ~ | ~ | RR: 2.38 | ~
| | | | | | | | | 95% CI:(1.8–3.2)
| | | | | 2358 | <2 mg/mmol | ~ | 9.3% | RR: 1.0 (Ref) | RR: 1.0 (Ref)
| | | | | 1140 | ≥2 mg/mmol* | ~ | 18.6% | RR: 2.01 | RR: 2.15
| | | | | | | | | 95% CI:(1.69–2.39) | 95% CI:(1.78–2.6)^a^
| | | | | ~ | <2 mg/mmol Placebo | ~ | 10.6% | RR: 1.0 (Ref) | RR: 1.0 (Ref)
| | | | | ~ | ≥2 mg/mmol* Placebo | ~ | 20.8% | RR: 1.96 | RR: 1.85
| | | | | | | | | 95% CI:(1.56–2.46) | 95% CI:(1.41–2.43)^b^
| | | | | ~ | <2 mg/mmol Ramipril | ~ | 7.9% | RR: 1.0 (Ref) | RR: 1.0 (Ref)
| | | | | ~ | ≥2 mg/mmol* Ramipril | ~ | 16.3% | RR: 2.05 | RR: 1.64
| | | | | | | | | 95% CI:(1.57–2.68) | 95% CI:(1.21–2.22)^b^

Adjustments:

1. Gerstein et al., 2001-(a) adjusted for randomization to Ramipril; (b) adjusted for age, gender, duration of diabetes, weight, blood pressure, insulin therapy, smoking, glycemic control, cholesterol, serum creatinine, use of oral agents

Table 86. All Cause Mortality; Randomized Controlled Trials: type 2 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Cumulative Incidence | Crude Risk | Adj. Risk
Gaede et al., 1999 [613] | 2 | 4 | AER | 24 Hour | 160 | ALL | ~ | ~ | ~ | ~
| | | | | 80 | 30–300 mg/24hrs (Conventional therapy)* | Median: 69 | 3% | ~ | ~
| | | | | | | Range: 47–113
| | | | | 80 | 30–300 mg/24hrs (Intensive therapy)* | Median: 78 | 5.19% | ~ | ~
| | | | | | | Range: 61–231

Table 87. Composite CVD Mortality; Cohort Studies: type 1 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Cumulative Incidence | Crude Risk | Adj. Risk
Muhlhauser et al., 2000 [293] | 1 | 10 | AER | 24 hour | 3674 | ALL | ~ | | ~ | ~
| | | | | 1829 | ≤50 mg/24hrs | ~ | 1.03% | ~ | ~
| | | | | 1257 | 51–499 mg/24hrs* | ~ | 1.91% | ~ | ~
| | | | | 367 | ≥500 mg/24hrs | ~ | 13.9% | ~ | ~

Table 88. Composite CVD Mortality; Cohort Studies: type 2 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Cumulative Incidence | Crude Risk | Adj. Risk
deGrauw et al., 2001 [216] | 2 | 6 | AER | Random | 262 | ALL
| | | | | 138 | <20 mg/L | Mean: 9.6 | Cumulative: 14% | ~ | RR:1.0(Ref)
| | | | | | | SD: 4.7
| | | | | 25 | 20–200mg/L* | Mean: 55.5 | Cumulative: 14% | ~ | RR:1.2
| | | | | | | SD: 51.1 | | | 95% CI: (0.5–2.8)
Valmadrid et al., 2000 [411] | 2 | 12 | AER | Random | 840 | ALL | ~
| | | | | 460 | <0.03 g/L | ~ | Rate: 3.69/100 | | Model 1: 1.0 (Ref)
| | | | | | | | person-y | | Model 2: 1.0 (Ref)
| | | | | | | | | | Model 3: 1.0 (Ref)
| | | | | 208 | 0.03–0.29 g/L* | ~ | Rate: 8.55/100 | | Model 1: RR: 2.23
| | | | | | | | person-y | | 95%CI: (1.74–2.86)
| | | | | | | | | | Model 2: RR: 2.02
| | | | | | | | | | 95% CI: (1.57–2.6)
| | | | | | | | | | Model 3: RR: 1.84
| | | | | | | | | | 95% CI: (1.42–2.4)
| | | | | 172 | ≥0.3 g/L | ~ | Rate: 12.3/100 | | Model 1: RR: 3.66
| | | | | | | | person-y | | 95% CI: (2.82–4.75)
| | | | | | | | | | Model 2: RR: 3.16
| | | | | | | | | | 95% CI: (2.42–4.12)
| | | | | | | | | | Model 3: RR: 2.61
| | | | | | | | | | 95% CI: (1.99–3.43)
Mattock et al.,1998 [659] | 2 | 7 | AER | Timed | 146 | ALL | Median: 7.3
| | | | | | | IQR: 4.4–20.8
| | | | | 109 | <20 μg/min | Median: 5.8 | Cumulative: 39% | | Model 1: RR:1.0 (Ref)
| | | | | | | IQR: 3.8–9.9 | | | Model 2: RR:1.0 (Ref)
| | | | | 37 | 20–199 μg/min* | Median: 67.8 | Cumulative: 72% | | Model 1: RR:7.4 95% CI: (2.94–18.7)
| | | | | | | IQR: 29.9–98.5 | | | Model 2: RR: 1.83 95% CI: (0.56–6.04)
Araki et al., 1997 [930] | 2 | 6 | AER | 24 hour | 297 | ~ | ~ | ~ | ~ | ~
| | | | | 201 | <15 μg/min | Mean: 6.7 | Rate: 0.33/100 | ~ | ~
| | | | | | | SD: 3.5 | person-y
| | | | | 96 | 15–199 μg/min* | Mean: 49 | Rate: 0.34/100 | ~ | ~
| | | | | | | SD: 39.1 | person-y
Beilin et al.,1996 [1009] | 2 | 7 | AER | Random | 666 | Mean: 149 | ~ | ~ | ~ | ~
| | | | | | SD: 530
| | | | | 390 | <30 mg/L | ~ | Cumulative: 7.7% | ~ | Model 1: RH 1.0 (Ref)
| | | | | | | | | | Model 2: RH 1.0 (Ref)
| | | | | 211 | 30–300 mg/L* | ~ | Cumulative: 17.1% | ~ | Model 1: RH: 2.17
| | | | | | | | | | 95%CI: (1.33–3.53)
| | | | | | | | | | Model 2: RH: 2.34
| | | | | | | | | | 95%CI: (1.38–3.99)
| | | | | 65 | >300 mg/L | ~ | Cumulative: 21.5% | ~ | Model 1: RH: 3.54
| | | | | | | | | | 95%CI: (1.86–6.72)
| | | | | | | | | | Model 2: RH: 3.17
| | | | | | | | | | 95%CI: (1.54–6.53)
Niskanen et al., 1996 [1067] | 2 | 2 | AER | Timed | 133 | ALL | Mean: 35 | ~ | ~ | ~
| | | | | | | SE: 7
| | | | | 105 | ≤30 mg/24hrs | ~ | ~ | ~ | OR: 1.0 (Ref)
| | | | | 28 | >30 mg/24hrs* | ~ | ~ | ~ | OR: 3.98
| | | | | | | | | | 95% CI: (1.04–15.2)
Gall et al., 1995 [1146] | 2 | 5 | AER | 24 hour | 328 | ALL | ~ | ~ | ~ | ~
| | | | | 191 | <30 mg/24hrs | Median: 8 | 5.96% | ~ | ~
| | | | | | | Range: 1–29
| | | | | 86 | 30–299 mg/24hrs* | Median: 68 | 11.62% | ~
| | | | | | | Range: 30–244
| | | | | 51 | ≥300 mg/24hrs | Median: 908 | 19.6% | ~ | RR: 2.5
| | | | | | | Range: 82–8019 | | | 95% CI: (1.1–5.8)
| | | | | 277 | <300 mg/24hrs | ~ | ~ | ~ | RR:1.0 (Ref)
MacLeod et al.,1995 [1218] | 2 | 8 | AER | Timed | 306 | ALL | ~ | ~ | ~ | ~
| | | | | | <10.6 μg/min | ~ | 18.5% | ~ | ~
| | | | | | 10.6–29.9 μg/min | ~ | 36.5% | ~ | ~
| | | | | | 30–149.9 μg/min* | ~ | 25% | ~ | ~
| | | | | | ≥150 μg/min | ~ | 32.2% | ~ | ~
Neil et al., 1993 [1454] | 2 | 6 | AER | Random | 249 | ALL | ~ | ~ | ~ | ~
| | | | | 145 | ≤15 mg/L | ~ | 8.28% | ~ | ~
| | | | | 45 | 15–39 mg/L | ~ | 4.4% | ~ | ~
| | | | | 36 | 40–200 mg/L* | ~ | 27.7% | ~ | ~
| | | | | 10 | >200 mg/L | ~ | 20% | ~ | ~
Mattock et al.,1992 [1603] | 2 | 3 | AER | Timed | 252 | ALL | ~ | | ~ | ~
| | | | | 105 | <20 μg/min | ~ | 0% | ~ | ~
| | | | | 36 | 20–200 μg/min* | ~ | 19% | ~ | ~

Ajustments:

1. deGrauw et al., 2001-age

2. Valmadrid et al., 2000-Model 1: age, gender; Model 2: age, gender, insulin dose, glycemic control, alcohol intake, physical activity; Model 3: age, gender, insulin dose, glycemic control, alcohol intake, physical activity, CVD history, use of antihypertensive agents, presence and severity of retinopathy

1. Mattock et al., 1998-Model 1: age., Model 2: age, gender, diabetes duration, glycemic control, total cholesterol, HDL/LDL cholesterol, CVD history

2. Araki et al., 1997-Incidence rates adjusted for age, gender

3. Beilin et al., 1996-Model 1:age, gender; Model 2: age. gender, diabetes duration, weight, blood pressure, smoking, age at diagnosis,, total cholesterol, HDL/LDL cholesterol, CVD history, neuropathy, PVD, cerebrovascular disease

1. Niskanen et al., 1996-age, gender, weight, blood pressure, smoking, glycemic control, HDL/LDL cholesterol, ischemic ECG, Triglycerides, fasting insulin

2. Gall et al., 1995-age, blood pressure, glycemic control, CVD history

Table 89. Composite CVD Mortality; Randomized Controlled Trials: type 2 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Cumulative Incidence | Crude Risk | Adj. Risk
Gaede et al., 1999 [613] | 2 | 4 | AER | 24 Hour | 160 | ALL | ~ | ~ | ~ | ~
| | | | | 80 | 30–300 mg/24hrs (Conventional therapy)* | Median: 69 | 2.56% | ~ | ~
| | | | | | | Range: 47–113
| | | | | 80 | 30–300 mg/24hrs (Intensive therapy)* | Median: 78 | 3.9% | ~ | ~
| | | | | | | Range: 61–231

Table 90. Cause Specific CVD Mortality; Cohort Studies: Myocardial Infarction type 1 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Cumulative Incidence | Crude Risk | Adj. Risk
Rossing et al.,1996 [991] | 1 | 10 | AER | 24 hour | 939 | ALL | ~ | ~ | ~ | ~
| | | | | 593 | <31 mg/24hrs | Median: 10 | 2.87% | ~ | ~
| | | | | | | Range: 1–196
| | | | | 181 | 31–299 mg/24hrs* | Median: 83 | 7.18% | ~ | ~
| | | | | | | Range: 31–398
| | | | | 165 | ≤300 mg/24hrs | Median: 920 | 5.45% | ~ | ~
| | | | | | | Range: 43–8213

Table 91. Cause Specific CVD Mortality; Cohort Studies: Myocardial Infarction type 2 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Cumulative Incidence | Crude Risk | Adj. Risk
Gall et al., 1995 [1146] | 2 | 5 | AER | 24 hour | 328 | ALL | ~ | ~ | ~ | ~
| | | | | 191 | <30 mg/24hrs | Median: 8 | 1.57% | ~ | ~
| | | | | | | Range: 1–29
| | | | | 86 | 30–299 mg/24hrs* | Median: 68 | 8.14% | ~ | ~
| | | | | | | Range: 30–244
| | | | | 51 | ≥300 mg/24hrs | Median: 908 | 11.8% | ~ | ~
| | | | | | | Range: 52–8019

Table 92. Cause Specific CVD Mortality; Cohort Studies: Cerebrovascular Accident, type 1 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Cumulative Incidence | Crude Risk | Adj. Risk
Muhlhauser et al., 2000b [293] | 1 | 10 | AER | 24 hour | 3674 | ALL | ~ | ~ | ~ | ~
| | | | | 1829 | ≤50 mg/24hrs | ~ | 0.11% | ~ | ~
| | | | | 1257 | 51–499 mg/24hrs* | ~ | 0.08% | ~ | ~
| | | | | 367 | ≥500 mg/24hrs | ~ | 4.63% | ~ | ~
Rossing et al.,1996 [991] | 1 | 10 | AER | 24 hour | 991 | ALL | ~ | ~ | ~ | ~
| | | | | | <31 mg/24hrs | Median: 10 | 0.67% | ~ | ~
| | | | | | | Range: 1–196
| | | | | | 31–299 mg/24hrs* | Median: 83 | 0.55% | ~ | ~
| | | | | | | Range: 30–244
| | | | | | ≥300 mg/24hrs | Median: 920 | 3.03% | ~ | ~
| | | | | | | Range: 52–8019

Table 93. Cause Specific CVD Mortality; Cohort Studies: Cerebrovascular Accident, type 2 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Cumulative Incidence | Crude Risk | Adj. Risk
Gall et al., 1995 [1146] | 2 | 5 | AER | 24 hour | 328 | ALL | ~ | ~ | ~ | ~
| | | | | | | Median: 8
| | | | | 191 | <30 mg/24hrs | Range: 1–29 | 0.52% | ~ | ~
| | | | | | | Median: 68
| | | | | 86 | 30–299 mg/24hrs* | Range: 30–244 | 2.32% | ~ | ~
| | | | | | | Median: 908
| | | | | 51 | ≥300 mg/24hrs | Range: 52–8019 | 3.92% | ~ | ~

Table 94. CVD Morbidity; Cohort Studies, type 1 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Morbidity | Incidence | Crude Risk | Adj. Risk
Muhlhauser et al., 2000a [283] | 1 | 10 | AER | 24 hour | 3674 | ALL | ~ | ~ | ~ | ~ | ~
| | | | | 1883 | ≤50 mg/24 hrs | ~ | | Cumulative: | ~ | ~
| | | | | | | | 1:amputation | 1: 0.5%
| | | | | | | | 2:blindness | 2: 0.4%
| | | | | 1296 | 51–499 mg/24 hrs* | ~ | | Cumulative: | ~ | ~
| | | | | | | | 1:amputation | 1: 1.7%
| | | | | | | | 2:blindness | 2: 1.2%
| | | | | 224 | ≥500 mg/24 hrs | ~ | | Cumulative: | ~ | ~
| | | | | | | | 1:amputation | 1: 10.5%
| | | | | | | | 2:blindness | 2: 5.8%
Deckert et al.,1996 [1074] | 1 | 7 | AER | 24 hour | 259 | ALL | Mean:16 | | Rate: | 4*: RH: 1.06 | 4*: RH: 1.04
| | | | | | | 95%CI: 15–18 | 1* | 1*: 0.28/100 person-y | 95%CI: 1.02–1.18 per 5mg/24hr increase UAE | 95%CI: 1.01–1.08 per 5mg/24hr increase UAE
| | | | | | | | 2* | 2*: 0.28/100 person-y
| | | | | | | | 3* | 3*: 0.65/100 person-y
| | | | | | | | 4* | 4*: 1.22/100 person-y
| | | | | 212 | <30 mg/24 hrs | ~ | ~ | ~ | 4*: RH: 1.0 (Ref) | ~
| | | | | 47 | 30–300 mg/24 hrs* | ~ | ~ | ~ | 4*: RH: 2.46 | ~
| | | | | | | | | | 95%CI: 1.02–5.92

* Types of morbidity

1. peripheral arterial insufficiency
2. stroke
3. ischemic heart disease (angina, acute myocardial infarction, coronary artery bypass surgery)
4. atherosclerotic vascular disease (ischemic heart disease, CVA, peripheral arterial insufficiency)

Adjustments

Age, gender, diabetes duration, blood pressure, insulin therapy, smoking, glycemic control, total cholesterol, sialic acid, Von Willebrand Factor

Table 95. CVD Morbidity; Cohort Studies, type 2 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Morbidity | Cumulative Incidence | Crude Risk | Adjusted Risk Estimates
Rachmani et al., 2000 [336] | 2 | 8 | AER | 24 hour | 599 | ALL | | | Cumulative: | ~ | ~
| | | | | | | | 1* | 1:1.67%
| | | | | | | | 2* | 2: 0.83%
| | | | | | | | 3* | 3: 3.84%
| | | | | | | | 4* | 4: 6.54%
| | | | | 359 | <=10 mg/24hrs | ~ | ~ | ~ | ~ | ~
| | | | | 131 | 10.1–20 mg/24hrs* | ~ | ~ | ~ | ~ | ~
| | | | | 109 | 20.1–30 mg/24hrs | ~ | ~ | ~ | ~ | ~
Miettinen et al., 1996 [977] | 2 | 7 | AER | Random | 1056 | ALL | ~ | 1* | 1: 11.8% | | ~
| | | | | | | | 2* | 2: 5.49%
| | | | | | <150 mg/L | ~ | 1* | 1: 7.2% | | 1*:Model A-D:1.0 (Ref)
| | | | | | | | 2* | 2: 3.9% | | 2*:Model A-D:1.0 (Ref)
| | | | | | 150–299 mg/L* | ~ | 1* | 1: 11.1% | | 1*:
| | | | | | | | | | | Model A:1.28 (0.68–1.43)
| | | | | | | | | | | Model B:1.23 (0.61–2.50)
| | | | | | | | | | | Model C:1.19 (0.61–2.43)
| | | | | | | | | | | Model D:1.13 (0.54–2.35)
| | | | | | | | 2* | 2: 5.7% | | 2*:
| | | | | | | | | | | Model A: 1.57 (0.96–2.56)
| | | | | | | | | | | Model B: 1.54 (0.93–2.51)
| | | | | | | | | | | Model C: 1.41 (0.85–2.32)
| | | | | | | | | | | Model D: 1.36 (0.82–2.25)
| | | | | | ≥300 mg/L | ~ | | Cumulative:
| | | | | | | | 1* | 1: 23% | | 1*:
| | | | | | | | | | | Model A: 3.14 (1.75–5.62)
| | | | | | | | | | | Model B: 3.07 (1.61–5.84)
| | | | | | | | | | | Model C: 2.84 (1.46–5.51)
| | | | | | | | | | | Model D: 2.60 (1.32–5.11)
| | | | | | | | 2* | 2: 12.2% | | 2*:
| | | | | | | | | | | Model A: 3.64 (2.28–5.81)
| | | | | | | | | | | Model B: 3.6 (2.25–5.77)
| | | | | | | | | | | Model C: 3.0 (1.84–4.86)
| | | | | | | | | | | Model D: 2.81 (1.73–4.58)

* Types of morbidity

1:peripheral vascular disease; 2: congestive heart failure; 3: angina; 4: non-fatal myocardial infarction

1: all atheroscierotic vacular disease (chd death or non-fatal mi, stroke, or amputation); 2: amputation

Adjustment: Model A age, gender, study area; Model B age, gender, study area, previous disease (amputation); Model C: Model B plus smoking, total cholesterol, HDL/LDL cholesterol; Model D: Model C plus glycemic control, duration of diabetes

Table 96. CVD Morbidity; Clinical Trials Analyzed as Cohort Studies, type 1 and 2 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Morbidity | Cumulative Incidence | Crude Risk | Adj. Risk
Gerstein et al., 2001 [136] | 1, 2 | 4.5 | ACR | Random | 3498 | ALL | ~ | | ~ | ~ | ~
| | | | | ~ | <0.22 mg/mmol | ~ | CHF* | ~ | RR: 1.0 (Ref) | ~
| | | | | ~ | 0.22–0.57 mg/mmol | ~ | CHF* | ~ | RR: 0.72 | ~
| | | | | | | | | | 95%CI: (0.32–1.63)
| | | | | ~ | 0.58–1.62 mg/mmol | ~ | CHF* | ~ | RR: 1.83 | ~
| | | | | | | | | | 95% CI: (0.98–3.43)
| | | | | ~ | >1.62 mg/mmol | ~ | CHF* | ~ | RR: 3.65 | ~
| | | | | | | | | | 95%CI: (2.06–6.46)
| | | | | 2358 | <2 mg/mmol | ~ | CHF* | 9.3% | RR: 1.0 (Ref) | RR: 1.0 (Ref)
| | | | | 1140 | ≥2 mg/mmol* | ~ | CHF* | 18.6% | RR: 3.34 | RR: 3.7
| | | | | | | | | | 95% CI: (2.49–4.50) | 95% CI: (2.64–5.17)^a^
| | | | | ~ | <2 mg/mmol Placebo | ~ | CHF* | 10.6% | RR: 1.0 (Ref) | RR: 1.0 (Ref)
| | | | | ~ | ≥2 mg/mmol* Placebo | ~ | CHF* | 20.8% | RR: 3.24 | RR: 4.51
| | | | | | | | | | 95% CI: (2.11–4.96) | 95% CI: (2.55–7.96)^b^
| | | | | ~ | <2 mg/mmol Ramipril | ~ | CHF* | 7.9 % | RR: 1.0 (Ref) | RR: 1.0 (Ref)
| | | | | ~ | ≥2 mg/mmol* Ramipril | ~ | CHF* | 16.3% | RR: 3.46 | RR: 2.91
| | | | | | | | | | 95% CI: (2.29–5.23) | 95% CI: (1.79–4.73)^b^

* Hospitalization for CHF

Adjustments: a) adjusted for randomization to Ramipril; (b) adjusted for age, gender, duration of diabetes, weight, blood pressure, insulin therapy, smoking, glycemic control, cholesterol, serum creatinine, use of oral agents

Table 97. CVD Morbidity; Randomized Controlled Trials, type 2 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Morb-idity | Cumulative Incidence | Crude Risk | Adj. Risk
Gaede et al., 1999 [613] | 2 | 4 | AER | 24 Hour | 160 | ALL | ~ | | ~ | ~ | ~
| | | | | 80 | 30–300 mg/24hrs (Conventional therapy)* | Median: 69 | 1* | 1*: 5.13% | ~ | ~
| | | | | | | Range: 47–113 | 2* | 2*: 5.13%
| | | | | | | | 3* | 3*: 10.3%
| | | | | | | | 4* | 4*: 5.13%
| | | | | 80 | 30–300 mg/24hrs (Intensive therapy)* | Median: 78 | 1* | 1*: 5.19% | ~ | ~
| | | | | | | Range: 61–231 | 2* | 2*: 2.6%
| | | | | | | | 3* | 3*: 1.3%
| | | | | | | | 4* | 4*: 5.19%

* Types of morbidity

1: non-fatal myocardial infarction; 2: coronary artery bypass graft; 3: cerebrovascular accident; 4: amputation

Table 98. CVD Morbidity and Mortality; Cohort Studies, type 2 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Outcome | Incidence | Crude Risk | Adj. Risk
Rachmani et al., 2000 [336] | 2 | 8 | AER | 24 hour | 599 | ALL
| | | | | 359 | ≤10 mg/24hrs | Mean: 7.2 | 1*
| | | | | | | SD:1.3
| | | | | 131 | 10.1–20 mg/24hrs* | Mean: 16.5 | 1* | | | OR: 1.9
| | | | | | | SD:1.6 | | | | 95%CI:(0.8–2.5)
| | | | | 109 | 20.1–30 mg/24hrs | Mean:25.7 | 1* | | | OR: 9.8
| | | | | | | SD:2.1 | | | | 95%CI:(6.7–12.3)

* Outcome

1: non-fatal myocardial infarction, angina, congestive heart failure, peripheral vascular disease, or all-cause death

Adjustments:

age

Table 98. CVD Morbidity and Mortality; Cohort Studies, type 2 diabetes (Continued)

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Morbidity | Cumulative Incidence | Adjusted Odds Ratio
Miettinen et al., 1996 [977] | 2 | 7 | AER | Random | 1056 | ALL | ~ | 1* | 1: 35.6% | ~
| | | | | | | | 2* | 2: 24.14%
| | | | | | <150 mg/L | ~ | 1* | 1: 26.0% | 1*:Model A-D:1.0 (Ref)
| | | | | | | | 2* | 2: 18.4% | 2*:Model A-D:1.0 (Ref)
| | | | | | 150–299 mg/L* | ~ | 1* | 1: 35.7% | 1*:
| | | | | | | | | | Model A:1.52 (1.02–2.07)
| | | | | | | | | | Model B:1.49(1.08–2.04)
| | | | | | | | | | Model C:1.43 (1.08–2.04)
| | | | | | | | | | Model D:1.3(1.0–2.07)
| | | | | | | | 2* | 2: 25.7% | 2*:
| | | | | | | | | | Model A: 1.44 (1.02–2.03)
| | | | | | | | | | Model B: 1.42 (1.0–2.16)
| | | | | | | | | | Model C: 1.4 (0.98–2.0)
| | | | | | | | | | Model D: 1.38(0.82–2.25)
| | | | | | ≥300 mg/L | ~ | | Cumulative:
| | | | | | | | 1* | 1: 52.9% | 1*:
| | | | | | | | | | Model A: 2.78 (2.05–4.04)
| | | | | | | | | | Model B: 2.66(1.88–3.76)
| | | | | | | | | | Model C: 2.29(1.88–3.28)
| | | | | | | | | | Model D: 2.16(1.51–3.09)
| | | | | | | | 2* | 2: 34.8% | 2*:
| | | | | | | | | | Model A: 2.04 (1.41–2.94)
| | | | | | | | | | Model B: 1.91 (1.32–2.76)
| | | | | | | | | | Model C: 1.69(1.15–2.48)
| | | | | | | | | | Model D: 1.6 (1.09–2.35)

* Outcome

1: all atherosclerotic vacular disease (chd death or non-fatal mi, stroke, or amputation); 2: CHD death or non-fatal MI

Adjustments: Model A: age, gender, study area; Model B: age, gender, study area, previous disease (amputation); Model C: Model B plus smoking, total cholesterol, HDL/LDL cholesterol; Model D: Model C plus glycemic control, duration of diabetes

Table 98. CVD Morbidity and Mortality; Cohort Studies, type 2 diabetes (Continued)

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Outcome | Incidence | Crude Risk | Adj. Risk
Agardh et al.,1996 [1075] | 2 | 5 | AER | Random | 369 | ALL
| | | | | | <12.5 mg/L | | 1* | | | RR: 1.0 (Ref)
| | | | | | 12.5–30 mg/L | | 1* | | | RR: 1.37
| | | | | | | | | | | 95% CI: (0.73–2.58)
| | | | | | 31–299 mg/L* | | 1* | | | RR: 1.59
| | | | | | | | | | | 95% CI: (0.85–2.97)
| | | | | | >=300 mg/L | | 1* | | | RR: 3.48
| | | | | | | | | | | 95% CI: (1.56–7.76)

* Outcome

1: vascular morbidity (myocardial infarction, cerebrovascular disease, amputation) or death

Adjustments: age, diabetes duration, blood pressure, age at diagnosis, glycemic control, serum creatinine

Table 99. CVD Morbidity and Mortality; RCT Analyzed as Cohort Study, type 1 and 2 diabetes

Reference | DM Type | F/U, (Y) | UAE Asc. | Timing | n | Level of UAE* | Baseline UAE | Outcome | Cumulative Incidence | Crude Risk | Adj. Risk
Gerstein et al., 2001 [136] | 1, 2 | 4.5 | ACR | Random | 3498 | ALL | ~ | | ~ | ~ | ~
| | | | | ~ | <0.22 mg/mmol | ~ | 1* | ~ | RR: 1.0 (Ref) | ~
| | | | | ~ | 0.22–0.57 mg/mmol | ~ | 1* | ~ | RR: 0.85 | ~
| | | | | | | | | | 95%CI: (0.63–1.14)
| | | | | ~ | 0.58–1.62 mg/mmol | ~ | 1* | ~ | RR: 1.11 | ~
| | | | | | | | | | 95% CI: (0.86–1.43)
| | | | | ~ | >1.62 mg/mmol | ~ | 1* | ~ | RR: 1.89 | ~
| | | | | | | | | | 95%CI: (1.52–2.36)
| | | | | 2358 | <2 mg/mmol | ~ | 1* | 13.9% | RR: 1.0 (Ref) | RR: 1.0 (Ref)
| | | | | 1140 | ≤2 mg/mmol* | ~ | 1* | 25.0% | RR: 1.8 | RR: 1.97
| | | | | | | | | | 95% CI: (1.56–2.07) | 95% CI: (1.68–2.31) ^a^
| | | | | ~ | <2 mg/mmol Placebo | ~ | 1* | 15.3% | RR: 1.0 (Ref) | RR: 1.0 (Ref)
| | | | | ~ | ≤2 mg/mmol* Placebo | ~ | 1* | 28.6% | RR: 1.87 | RR: 1.84
| | | | | | | | | | 95% CI: (1.55–2.25) | 95% CI: (1.46–2.31) ^b^
| | | | | ~ | <2 mg/mmol Ramipril | ~ | 1* | 12.6 % | RR: 1.0 (Ref) | RR: 1.0 (Ref)
| | | | | ~ | ≤2 mg/mmol* Ramipril | ~ | 1* | 21.1% | RR: 1.68 | RR: 1.44
| | | | | | | | | | 95% CI: (1.35–2.1) | 95% CI: (1.11–1.86) ^b^

* Outcomes

1: myocardial infarction, stroke, or cardiovascular death

Adjustments: a) adjusted for randomization to Ramipril; (b) adjusted for age, gender, duration of diabetes, weight, blood pressure, insulin therapy, smoking, glycemic control, cholesterol, serum creatinine, use of oral agents