# Urine Albumin Bibliography (N=150)

NOTE: Numbers in brackets correspond to study numbers in the Evidence Tables.

Abderrahim E, Zouaghi K, Hedri H, Ben Abdallah T, Ben Hamida F, Kaaroud H, Goucha R, Ben Abdallah N, Khiari K, El Younsi F, Ben Moussa F, Kheder A, Ben Maiz H. Renal replacement therapy for diabetic end-stage renal disease. Experience of a Tunisian hospital centre. Diabetes Metab. 2001;27(5 Pt 1):584-90. [58]. [pmid: 11694858].
Agardh C D, Agardh E, Torffvit O. The association between retinopathy, nephropathy, cardiovascular disease and long-term metabolic control in type 1 diabetes mellitus: a 5 year follow-up study of 442 adult patients in routine care. Diabetes Res Clin Pract. 1997;35(23):113-21. [915]. [pmid: 9179466].
Agardh C D, Agardh E, Torffvit O. The prognostic value of albuminuria for the development of cardiovascular disease and retinopathy: a 5-year follow-up of 451 patients with type 2 diabetes mellitus. Diabetes Res Clin Pract. 1996;32(12):35-44. [1075]. [pmid: 8803480].
Ahmad J, Siddiqui M A, Ahmad H. Effective postponement of diabetic nephropathy with enalapril in normotensive type 2 diabetic patients with microalbuminuria. Diabetes Care. 1997;20(10):1576-81. [844]. [pmid: 9314638].
…and people with diabetes. Health News . 1999; 5 (15): 5. [3199].
Andersen A R, Christiansen J S, Andersen J K, Kreiner S, Deckert T. Diabetic nephropathy in Type 1 (insulin-dependent) diabetes: an epidemiological study. Diabetologia. 1983;25(6):496-501. [2197]. [pmid: 6363177].
Araki S, Haneda M, Togawa M, Sugimoto T, Shikano T, Nakagawa T, Isono M, Hidaka H, Kikkawa R. Microalbuminuria is not associated with cardiovascular death in Japanese NIDDM. Diabetes Res Clin Pract. 1997;35(1):35-40. [930]. [pmid: 9113473].
Asakawa H, Tokunaga K, Kawakami F. Comparison of risk factors of macrovascular complications. Peripheral vascular disease, cerebral vascular disease, and coronary heart disease in Japanese type 2 diabetes mellitus patients. J Diabetes Complications. 2000;14(6):307-13. [276]. [pmid: 11120454].
Bain R, Rohde R, Hunsicker L G, McGill J, Kobrin S, Lewis E J. A controlled clinical trial of angiotensin-converting enzyme inhibition in type I diabetic nephropathy: study design and patient characteristics. The Collaborative Study Group. J Am Soc Nephrol. 1992;3(4 Suppl):S97-103. [1560]. [pmid: 1457767].
Beilin J, Stanton K G, McCann V J, Knuiman M W, Divitini M L. Microalbuminuria in type 2 diabetes: an independent predictor of cardiovascular mortality. Aust N Z J Med. 1996;26(4):519-25. [1009]. [pmid: 8873935].
Bennett P H, Lee E T, Lu M, Keen H, Fuller J H. Increased urinary albumin excretion and its associations in the WHO Multinational Study of Vascular Disease in Diabetes. Diabetologia. 2001;44(Suppl 2):S37-45. [83]. [pmid: 11587049].
Berglund J. Studies of cardiovascular and renal function in subclinical and manifest diabetic nephropathy. Acta Med Scand Suppl. 1988;722:1-69. [1998]. [pmid: 3163465].
Biderman A, Rosenblatt I, Rosen S, Zangwill L M, Shalev R, Friger M, Weitzman S. Sex differentials in predictors of mortality for patients with adult-onset diabetes: a population-based follow-up study in Beer-Sheva, Israel. Diabetes Care. 2000;23(5):602-5. [392]. [pmid: 10834416].
Borch-Johnsen K, Andersen P K, Deckert T. The effect of proteinuria on relative mortality in type 1 (insulin-dependent) diabetes mellitus. Diabetologia. 1985;28(8):590-6. [2121]. [pmid: 4054448].
Borch-Johnsen K, Kreiner S. Proteinuria: value as predictor of cardiovascular mortality in insulin dependent diabetes mellitus. Br Med J (Clin Res Ed). 1987;294(6588):1651-4. [2018]. [pmid: 3113569].
Brenner B M, Cooper M E, de Zeeuw D, Keane W F, Mitch W E, Parving H H, Remuzzi G, Snapinn S M, Zhang Z, Shahinfar S. Effects of losartan on renal and cardiovascular outcomes in patients with type 2 diabetes and nephropathy. N Engl J Med. 2001;345(12):861-9. [102]. [pmid: 11565518].
Capes S E, Gerstein H C, Negassa A, Yusuf S. Enalapril prevents clinical proteinuria in diabetic patients with low ejection fraction. Diabetes Care. 2000;23(3):377-80. [377]. [pmid: 10868869].
Captopril reduces the risk of nephropathy in IDDM patients with microalbuminuria. The Microalbuminuria Captopril Study Group. Diabetologia 1996; 39 (5): 587–93. [1061].
Casiglia E, Mazza A, Tikhonoff V, Pavei A, Privato G, Schenal N, Pessina A C. Weak effect of hypertension and other classic risk factors in the elderly who have already paid their toll. J Hum Hypertens. 2002;16(1):21-31. [7]. [pmid: 11840226].
Casiglia E, Zanette G, Mazza A, Donadon V, Donada C, Pizziol A, Tikhonoff V, Palatini P, Pessina A C. Cardiovascular mortality in non-insulin-dependent diabetes mellitus. A controlled study among 683 diabetics and 683 age- and sex-matched normal subjects. Eur J Epidemiol. 2000;16(7):677-84. [296]. [pmid: 11078126].
Chan J C, Cheung C K, Cheung M Y, Swaminathan R, Critchley J A, Cockram C S. Abnormal albuminuria as a predictor of mortality and renal impairment in Chinese patients with NIDDM. Diabetes Care. 1995;18(7):1013-6. [1195]. [pmid: 7555533].
Chan J C, Ko G T, Leung D H, Cheung R C, Cheung M Y, So W Y, Swaminathan R, Nicholls M G, Critchley J A, Cockram C S. Long-term effects of angiotensin-converting enzyme inhibition and metabolic control in hypertensive type 2 diabetic patients. Kidney Int. 2000;57(2):590-600. [456]. [pmid: 10652036].
Chances of dying from important causes. Stat Bull Metropol Life Insur Co . 1969; 50 : 2–4. [2447].
Chaturvedi N, Bandinelli S, Mangili R, Penno G, Rottiers R E, Fuller J H. Microalbuminuria in type 1 diabetes: rates, risk factors and glycemic threshold. Kidney Int. 2001;60(1):219-27. [163]. [pmid: 11422754].
Chaturvedi N, Jarrett J, Morrish N, Keen H, Fuller J H. Differences in mortality and morbidity in African Caribbean and European people with non-insulin dependent diabetes mellitus: results of 20 year follow up of a London cohort of a multinational study. BMJ. 1996;313(7061):848-52. [980]. [pmid: 8870570].
Christensen P K, Rossing P, Nielsen F S, Parving H H. Natural course of kidney function in Type 2 diabetic patients with diabetic nephropathy. Diabet Med. 1999;16(5):388-94. [565]. [pmid: 10342338].
Chugh K S, Kumar R, Sakhuja V, Pereira B J, Gupta A. Nephropathy in type 2 diabetes mellitus in Third World countries--Chandigarh study. Int J Artif Organs. 1989;12(5):299-302. [5569]. [pmid: 2786852].
Colhoun H M, Lee E T, Bennett P H, Lu M, Keen H, Wang S L, Stevens L K, Fuller J H. Risk factors for renal failure: the WHO Mulinational Study of Vascular Disease in Diabetes. Diabetologia. 2001;44(Suppl 2):S46-53. [2584]. [pmid: 11587050].
Couper J J, Clarke C F, Byrne G C, Jones T W, Donaghue K C, Nairn J, Boyce D, Russell M, Stephens M, Raymond J, Bates D J, McCaul K. Progression of borderline increases in albuminuria in adolescents with insulin-dependent diabetes mellitus. Diabet Med. 1997;14(9):766-71. [851]. [pmid: 9300227].
Crepaldi G, Carraro A, Brocco E, Adezati L, Andreani D, Bompiani G, Brunetti P, Fedele D, Giorgino R, Giustina G, et al. Hypertension and non-insulin-dependent diabetes. A comparison between an angiotensin-converting enzyme inhibitor and a calcium antagonist. Acta Diabetol. 1995;32(3):203-8. [1158]. [pmid: 8590792].
Damsgaard E M, Froland A, Jorgensen O D, Mogensen C E. Eight to nine year mortality in known non-insulin dependent diabetics and controls. Kidney Int. 1992;41(4):731-5. [1622]. [pmid: 1513094].
Damsgaard E M, Froland A, Jorgensen O D, Mogensen C E. Microalbuminuria as predictor of increased mortality in elderly people. BMJ. 1990;300(6720):297-300. [1819]. [pmid: 2106959]. [pmcid: 1661920].
Damsgaard E M, Froland A, Jorgensen O D, Morgensen C E. Prognostic value of urinary albumin excretion rate and other risk factors in elderly diabetic patients and non-diabetic control subjects surviving the first 5 years after assessment. Diabetologia. 1993;36(10):1030-6. [1429]. [pmid: 8243851].
Davis T M, Stratton I M, Fox C J, Holman R R, Turner R C. U.K. Prospective Diabetes Study 22. Effect of age at diagnosis on diabetic tissue damage during the first 6 years of NIDDM. Diabetes Care. 1997;20(9):1435-41. [856]. [pmid: 9283793].
de Grauw W J, van de Lisdonk E H, van Gerwen W H, Verstappen M, van den Hoogen H J, Willems J L, van Weel C. Microalbuminuria in patients with Type 2 diabetes mellitus from general practice: course and predictive value. Diabet Med. 2001;18(2):139-43. [216]. [pmid: 11251678].
Deckert T, Yokoyama H, Mathiesen E, Ronn B, Jensen T, Feldt-Rasmussen B, Borch-Johnsen K, Jensen J S. Cohort study of predictive value of urinary albumin excretion for atherosclerotic vascular disease in patients with insulin dependent diabetes. BMJ. 1996;312(7035):871-4. [1074]. [pmid: 8611873].
Effects of ramipril on cardiovascular microvascular outcomes in people with diabetes mellitus: results of the HOPE study MICRO-HOPE substudy. Heart Outcomes Prevention Evaluation Study Investigators. Lancet 2000; 355 (9200): 253–9. [450].
Efficacy of atenolol captoprilin reducing risk of macrovascular microvascular complications in type 2 diabetes: UKPDS 39. UK Prospective Diabetes Study Group. BMJ 1998; 317 (7160): 713–20 [680].
Estacio R O, Jeffers B W, Gifford N, Schrier R W. Effect of blood pressure control on diabetic microvascular complications in patients with hypertension and type 2 diabetes. Diabetes Care. 2000;23(Suppl 2):B54-64. [382]. [pmid: 10860192].
Florkowski C M, Scott R S, Coope P A, Moir C L. Predictors of mortality from type 2 diabetes mellitus in Canterbury, New Zealand; a ten-year cohort study. Diabetes Res Clin Pract. 2001;53(2):113-20. [169]. [pmid: 11403860].
Forrest K Y, Becker D J, Kuller L H, Wolfson S K, Orchard T J. Are predictors of coronary heart disease and lower-extremity arterial disease in type 1 diabetes the same? A prospective study. Atherosclerosis. 2000;148(1):159-69. [485]. [pmid: 10580182].
Fuller J H, Stevens L K, Wang S L. International variations in cardiovascular mortality associated with diabetes mellitus: the WHO Multinational Study of Vascular Disease in Diabetes. Ann Med. 1996;28(4):319-22. [1013]. [pmid: 8862686].
Fuller J H, Stevens L K, Wang S L. Risk factors for cardiovascular mortality and morbidity: the WHO Mutinational Study of Vascular Disease in Diabetes. Diabetologia. 2001;44(Suppl 2):S54-64. [82]. [pmid: 11587051].
Gabir M M, Hanson R L, Dabelea D, Imperatore G, Roumain J, Bennett P H, Knowler W C. Plasma glucose and prediction of microvascular disease and mortality: evaluation of 1997 American Diabetes Association and 1999 World Health Organization criteria for diagnosis of diabetes. Diabetes Care. 2000;23(8):1113-8. [348]. [pmid: 10937507].
Gaede P, Vedel P, Parving H H, Pedersen O. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. 1999;353(9153):617-22. [613]. [pmid: 10030326].
Gall M A, Borch-Johnsen K, Hougaard P, Nielsen F S, Parving H H. Albuminuria and poor glycemic control predict mortality in NIDDM. Diabetes. 1995;44(11):1303-9. [1146]. [pmid: 7589828].
Garg S K, Chase H P, Shapiro H, Harris S, Osberg I M. Exercise versus overnight albumin excretion rates in subjects with type 1 diabetes. Diabetes Res Clin Pract. 1995;28(1):51-5. [4478]. [pmid: 7587913].
Gerstein, HC. Diabetes and the HOPE study: implications for macrovascular and microvascular disease. Int J Clin Pract Suppl 2001; (117): 8–12. [52].
Gerstein H C, Mann J F, Yi Q, Zinman B, Dinneen S F, Hoogwerf B, Halle J P, Young J, Rashkow A, Joyce C, Nawaz S, Yusuf S. Albuminuria and risk of cardiovascular events, death, and heart failure in diabetic and nondiabetic individuals. JAMA. 2001;286(4):421-6. [136]. [pmid: 11466120].
Goetz F C, Jacobs D R Jr, Chavers B, Roel J, Yelle M, Sprafka J M. Risk factors for kidney damage in the adult population of Wadena, Minnesota. A prospective study. Am J Epidemiol. 1997;145(2):91-102. [934]. [pmid: 9006305].
Goldstein D E. Diabetic nephropathy. Is a pound of treatment better than an ounce of prevention?. Mo Med. 1994;91(6):291. [4661]. [pmid: 8052219].
Goodkin G. Mortality factors in diabetes. A 20 year mortality study. J Occup Med. 1975;17(11):716-21. [2361]. [pmid: 1195031].
Grimm R H Jr, Svendsen K H, Kasiske B, Keane W F, Wahi M M. Proteinuria is a risk factor for mortality over 10 years of follow-up. MRFIT Research Group. Multiple Risk Factor Intervention Trial. Kidney Int Suppl. 1997;63:S10-4. [815]. [pmid: 9407412].
Hanninen J, Takala J, Keinanen-Kiukaanniemi S. Albuminuria and other risk factors for mortality in patients with non-insulin-dependent diabetes mellitus aged under 65 years: a population-based prospective 5-year study. Diabetes Res Clin Pract. 1999;43(2):121-6. [580]. [pmid: 10221664].
Hebert L A, Bain R P, Verme D, Cattran D, Whittier F C, Tolchin N, Rohde R D, Lewis E J. Remission of nephrotic range proteinuria in type I diabetes. Collaborative Study Group. Kidney Int. 1994;46(6):1688-93. [4565]. [pmid: 7700028].
Hollenberg N K. Higher incidence of diabetic nephropathy in type 2 than in type 1 diabetes in early-onset diabetes in Japan. Curr Hypertens Rep. 2001;3(3):177. [2709]. [pmid: 11421227].
Hovind P, Rossing P, Tarnow L, Smidt U M, Parving H H. Progression of diabetic nephropathy. Kidney Int. 2001;59(2):702-9. [247]. [pmid: 11168952].
Hovind P, Rossing P, Tarnow L, Smidt U M, Parving H H. Remission and regression in the nephropathy of type 1 diabetes when blood pressure is controlled aggressively. Kidney Int. 2001;60(1):277-83. [159]. [pmid: 11422762].
Hovind P, Rossing P, Tarnow L, Toft H, Parving J, Parving H H. Remission of nephrotic-range albuminuria in type 1 diabetic patients. Diabetes Care. 2001;24(11):1972-7. [68]. [pmid: 11679467].
Hoy W E, Baker P R, Kelly A M, Wang Z. Reducing premature death and renal failure in Australian aboriginals. A community-based cardiovascular and renal protective program. Med J Aust. 2000;172(10):473-8. [363]. [pmid: 10901769].
Hoy W E, Wang Z, VanBuynder P, Baker P R, McDonald S M, Mathews J D. The natural history of renal disease in Australian Aborigines. Part 2. Albuminuria predicts natural death and renal failure. Kidney Int. 2001;60(1):249-56. [160]. [pmid: 11422758].
Humphrey L L, Ballard D J, Frohnert P P, Chu C P, O'Fallon W M, Palumbo P J. Chronic renal failure in non-insulin-dependent diabetes mellitus. A population-based study in Rochester, Minnesota. Ann Intern Med. 1989;111(10):788-96. [5508]. [pmid: 2817626].
Hypertension in Diabetes Study (HDS):II. Increased risk of cardiovascular complications in hypertensive type 2 diabetic patients. J Hypertens 1993;11 (3):319–25. [1490].
Jager A, Kostense P J, Ruhe H G, Heine R J, Nijpels G, Dekker J M, Bouter L M, Stehouwer C D. Microalbuminuria and peripheral arterial disease are independent predictors of cardiovascular and all-cause mortality, especially among hypertensive subjects: five-year follow-up of the Hoorn Study. Arterioscler Thromb Vasc Biol. 1999;19(3):617-24. [607]. [pmid: 10073965].
Jerums G, Cooper M E, Seeman E, Murray R M, McNeil J J. Comparison of early renal dysfunction in type I and type II diabetes: differing associations with blood pressure and glycaemic control. Diabetes Res Clin Pract. 1988;4(2):133-41. [5726]. [pmid: 3342732].
Klein R, Klein B E, Moss S E, Cruickshanks K J. Ten-year incidence of gross proteinuria in people with diabetes. Diabetes. 1995;44(8):916-23. [4398]. [pmid: 7621997].
Klein R, Klein B E, Moss S E, Cruickshanks K J, Brazy P C. The 10-year incidence of renal insufficiency in people with type 1 diabetes. Diabetes Care. 1999;22(5):743-51. [3379]. [pmid: 10332675].
Klein R, Moss S E, Klein B E, DeMets D L. Relation of ocular and systemic factors to survival in diabetes. Arch Intern Med. 1989;149(2):266-72. [1910]. [pmid: 2916872].
Knuiman M W, Welborn T A, Whittall D E. An analysis of excess mortality rates for persons with non-insulin-dependent diabetes mellitus in Western Australia using the Cox proportional hazards regression model. Am J Epidemiol. 1992;135(6):638-48. [1626]. [pmid: 1580240].
Krolewski A S, Warram J H, Christlieb A R, Busick E J, Kahn C R. The changing natural history of nephropathy in type I diabetes. Am J Med. 1985;78(5):785-94. [5993]. [pmid: 3993659].
Kumar S, Mangal B D, Alam S M, Srivastava D K, Vajpeyi G N, Garg S K. A study of glycosylated hemoglobin (HbA1) in renal failure. J Assoc Physicians India. 1983;31(2):69-71. [6196]. [pmid: 6885711].
Kussman M J, Goldstein H, Gleason R E. The clinical course of diabetic nephropathy. JAMA. 1976;236(16):1861-3. [2341]. [pmid: 989537].
Lacourciere Y, Belanger A, Godin C, Halle J P, Ross S, Wright N, Marion J. Long-term comparison of losartan and enalapril on kidney function in hypertensive type 2 diabetics with early nephropathy. Kidney Int. 2000;58(2):762-9. [356]. [pmid: 10916100].
Larson T S, Santanello N, Shahinfar S, O'Brien P C, Palumbo P J, Melton L J 3rd, Leibson C L. Trends in persistent proteinuria in adult-onset diabetes: a population-based study. Diabetes Care. 2000;23(1):51-6. [385]. [pmid: 10857968].
Lebovitz H E, Wiegmann T B, Cnaan A, Shahinfar S, Sica D A, Broadstone V, Schwartz S L, Mengel M C, Segal R, Versaggi J A, et al. Renal protective effects of enalapril in hypertensive NIDDM: role of baseline albuminuria. Kidney Int Suppl. 1994;45:S150-5. [1366]. [pmid: 8158885].
Lee E T, Lee V S, Lu M, Lee J S, Russell D, Yeh J. Incidence of renal failure in NIDDM. The Oklahoma Indian Diabetes Study. Diabetes. 1994;43(4):572-9. [4684]. [pmid: 8138063].
Lewis E J, Hunsicker L G, Bain R P, Rohde R D. The effect of angiotensin-converting-enzyme inhibition on diabetic nephropathy. The Collaborative Study Group. N Engl J Med. 1993;329(20):1456-62. [1399]. [pmid: 8413456].
Lewis E J, Hunsicker L G, Clarke W R, Berl T, Pohl M A, Lewis J B, Ritz E, Atkins R C, Rohde R, Raz I. Renoprotective effect of the angiotensin-receptor antagonist irbesartan in patients with nephropathy due to type 2 diabetes. N Engl J Med. 2001;345(12):851-60. [103]. [pmid: 11565517].
Lewis E J, Hunsicker L G, Rodby R A. A clinical trial in type 2 diabetic nephropathy. Am J Kidney Dis. 2001;38(4 Suppl 1):S191-4. [90]. [pmid: 11576953].
Lievre M, Marre M, Chatellier G, Plouin P, Reglier J, Richardson L, Bugnard F, Vasmant D. The non-insulin-dependent diabetes, hypertension, microalbuminuria or proteinuria, cardiovascular events, and ramipril (DIABHYCAR) study: design, organization, and patient recruitment. DIABHYCAR Study Group. Control Clin Trials. 2000;21(4):383-96. [357]. [pmid: 10913814].
Lloyd C E, Kuller L H, Ellis D, Becker D J, Wing R R, Orchard T J. Coronary artery disease in IDDM. Gender differences in risk factors but not risk. Arterioscler Thromb Vasc Biol. 1996;16(6):720-6. [1056]. [pmid: 8640398].
Lovestam-Adrian M, Agardh E, Agardh C D. The incidence of nephropathy in type 1 diabetic patients with proliferative retinopathy: a 10-year follow-up study. Diabetes Res Clin Pract. 1998;39(1):11-7. [731]. [pmid: 9597369].
MacLeod J M, Lutale J, Marshall S M. Albumin excretion and vascular deaths in NIDDM. Diabetologia. 1995;38(5):610-6. [1218]. [pmid: 7489846].
Marso S P, Ellis S G, Gurm H S, Lytle B W, Topol E J. Proteinuria is a key determinant of death in patients with diabetes after isolated coronary artery bypass grafting. Am Heart J. 2000;139(6):939-44. [397]. [pmid: 10827372].
Marso S P, Ellis S G, Tuzcu M, Whitlow P L, Franco I, Raymond R E, Topol E J. The importance of proteinuria as a determinant of mortality following percutaneous coronary revascularization in diabetics. J Am Coll Cardiol. 1999;33(5):1269-77. [592]. [pmid: 10193727].
Mason P, Gerntholtz T. Reducing renal disease in diabetes. Practitioner. 2001;245(1623):557-61. [148]. [pmid: 11436266].
Mathiesen E R, Borch-Johnsen K, Jensen D V, Deckert T. Improved survival in patients with diabetic nephropathy. Diabetologia. 1989;32(12):884-6. [1853]. [pmid: 2612760].
Mattock M B, Barnes D J, Viberti G, Keen H, Burt D, Hughes J M, Fitzgerald A P, Sandhu B, Jackson P G. Microalbuminuria and coronary heart disease in NIDDM: an incidence study. Diabetes. 1998;47(11):1786-92. [659]. [pmid: 9792549].
Mattock M B, Morrish N J, Viberti G, Keen H, Fitzgerald A P, Jackson G. Prospective study of microalbuminuria as predictor of mortality in NIDDM. Diabetes. 1992;41(6):736-41. [1603]. [pmid: 1587400].
McMorrow R G, Galla J H, Luke R G. Quantitative urinary protein excretion in chronic renal failure. Am J Nephrol. 1982;2(4):208-12. [2246]. [pmid: 7148893].
Miettinen H, Haffner S M, Lehto S, Ronnemaa T, Pyorala K, Laakso M. Proteinuria predicts stroke and other atherosclerotic vascular disease events in nondiabetic and non-insulin-dependent diabetic subjects. Stroke. 1996;27(11):2033-9. [977]. [pmid: 8898811].
Mihara T, Oohashi H, Hirata Y. Effects of microangiopathies and hypertension on the mortality of the patients with non-insulin-dependent diabetes mellitus. J Med Assoc Thai. 1987;70(Suppl 2):194-8. [2040]. [pmid: 3598431].
Mlacak B, Jaksic Z, Vuletic S. Albuminuria, cardiovascular morbidity and mortality in diabetic and non-diabetic subjects in a rural general practice. Fam Pract. 1999;16(6):580-5. [465]. [pmid: 10625130].
Mogensen C E. Kidney function and glomerular permeability to macromolecules in juvenile diabetes with special reference to early changes. Dan Med Bull. 1972;19(Suppl 3):1-40. [2416]. [pmid: 4642311].
Morrish N J, Stevens L K, Fuller J H, Jarrett R J, Keen H. Risk factors for macrovascular disease in diabetes mellitus: the London follow-up to the WHO Multinational Study of Vascular Disease in Diabetics. Diabetologia. 1991;34(8):590-4. [1679]. [pmid: 1936663].
Morrish N J, Stevens L K, Head J, Fuller J H, Jarrett R J, Keen H. A prospective study of mortality among middle-aged diabetic patients (the London Cohort of the WHO Multinational Study of Vascular Disease in Diabetics) II: Associated risk factors. Diabetologia. 1990;33(9):542-8. [1769]. [pmid: 2253831].
Morrish N J, Stevens L K, Head J, Fuller J H, Jarrett R J, Keen H. A prospective study of mortality among middle-aged diabetic patients (the London Cohort of the WHO Multinational Study of Vascular Disease in Diabetics) I: Causes and death rates. Diabetologia. 1990;33(9):538-41. [1770]. [pmid: 2253830].
Muhlhauser I, Overmann H, Bender R, Jorgens V, Berger M. Predictors of mortality and end-stage diabetic complications in patients with Type 1 diabetes mellitus on intensified insulin therapy. Diabet Med. 2000;17(10):727-34. [283]. [pmid: 11110506].
Muhlhauser I, Sawicki P T, Blank M, Overmann H, Bender R, Berger M. Prognosis of persons with type 1 diabetes on intensified insulin therapy in relation to nephropathy. J Intern Med. 2000;248(4):333-41. [293]. [pmid: 11086645].
Mulec H, Blohme G, Grande B, Bjorck S. The effect of metabolic control on rate of decline in renal function in insulin-dependent diabetes mellitus with overt diabetic nephropathy. Nephrol Dial Transplant. 1998;13(3):651-5. [756]. [pmid: 9550642].
Natali A, Vichi S, Landi P, Severi S, L'Abbate A, Ferrannini E. Coronary atherosclerosis in Type II diabetes: angiographic findings and clinical outcome. Diabetologia. 2000;43(5):632-41. [389]. [pmid: 10855538].
Neil A, Hawkins M, Potok M, Thorogood M, Cohen D, Mann J. A prospective population-based study of microalbuminuria as a predictor of mortality in NIDDM. Diabetes Care. 1993;16(7):996-1003. [1454]. [pmid: 8359108].
Nelson R G, Bennett P H, Beck G J, Tan M, Knowler W C, Mitch W E, Hirschman G H, Myers B D. Development and progression of renal disease in Pima Indians with non-insulin-dependent diabetes mellitus. Diabetic Renal Disease Study Group. N Engl J Med. 1996;335(22):1636-42. [967]. [pmid: 8929360].
Nelson R G, Gohdes D M, Everhart J E, Hartner J A, Zwemer F L, Pettitt D J, Knowler W C. Lower-extremity amputations in NIDDM. 12-yr follow-up study in Pima Indians. Diabetes Care. 1988;11(1):8-16. [1993]. [pmid: 3338381].
Nelson R G, Knowler W C, McCance D R, Sievers M L, Pettitt D J, Charles M A, Hanson R L, Liu Q Z, Bennett P H. Determinants of end-stage renal disease in Pima Indians with type 2 (non-insulin-dependent) diabetes mellitus and proteinuria. Diabetologia. 1993;36(10):1087-93. [1424]. [pmid: 8243859].
Nelson R G, Pettitt D J, Carraher M J, Baird H R, Knowler W C. Effect of proteinuria on mortality in NIDDM. Diabetes. 1988;37(11):1499-504. [1947]. [pmid: 3181642].
Nelson R G, Sievers M L, Knowler W C, Swinburn B A, Pettitt D J, Saad M F, Liebow I M, Howard B V, Bennett P H. Low incidence of fatal coronary heart disease in Pima Indians despite high prevalence of non-insulin-dependent diabetes. Circulation. 1990;81(3):987-95. [1817]. [pmid: 2306842].
Niskanen L, Voutilainen R, Terasvirta M, Lehtinen J, Teppo A M, Groop L, Uusitupa M. A prospective study of clinical and metabolic associates of proteinuria in patients with type 2 diabetes mellitus. Diabet Med. 1993;10(6):543-9. [1452]. [pmid: 8365091].
Niskanen L K, Penttila I, Parviainen M, Uusitupa M I. Evolution, risk factors, and prognostic implications of albuminuria in NIDDM. Diabetes Care. 1996;19(5):486-93. [1067]. [pmid: 8732714].
Nosadini R, Velussi M, Brocco E, Bruseghin M, Abaterusso C, Saller A, Dalla Vestra M, Carraro A, Bortoloso E, Sambataro M, Barzon I, Frigato F, Muollo B, Chiesura-Corona M, Pacini G, Baggio B, Piarulli F, Sfriso A, Fioretto P. Course of renal function in type 2 diabetic patients with abnormalities of albumin excretion rate. Diabetes. 2000;49(3):476-84. [376]. [pmid: 10868971].
O'Hare P, Bilbous R, Mitchell T, O'Callaghan C J, Viberti G C. Low-dose ramipril reduces microalbuminuria in type 1 diabetic patients without hypertension: results of a randomized controlled trial. Diabetes Care. 2000;23(12):1823-9. [268]. [pmid: 11128360].
Overlack A, Adamczak M, Bachmann W, Bonner G, Bretzel R G, Derichs R, Krone W, Lederle R M, Reimann H J, Zschiedrich H, et al. ACE-inhibition with perindopril in essential hypertensive patients with concomitant diseases. The Perindopril Therapeutic Safety Collaborative Research Group. Am J Med. 1994;97(2):126-34. [1304]. [pmid: 8059778].
Partamian J O, Bradley R F. Acute myocardial infarction in 258 cases of diabetes. Immediate mortality and five-year survival. N Engl J Med. 1965;273(9):455-61. [2475]. [pmid: 5826160].
Patrick A W, Leslie P J, Clarke B F, Frier B M. The natural history and associations of microalbuminuria in type 2 diabetes during the first year after diagnosis. Diabet Med. 1990;7(10):902-8. [6804]. [pmid: 2149687].
Pylypchuk G, Beaubien E. Diabetic nephropathy. Prevention and early referral. Can Fam Physician. 2000;46:636-42. [257]. [pmid: 10752002]. [pmcid: 2144965].
Rachmani R, Levi Z, Lidar M, Slavachevski I, Half-Onn E, Ravid M. Considerations about the threshold value of microalbuminuria in patients with diabetes mellitus: lessons from an 8-year follow-up study of 599 patients. Diabetes Res Clin Pract. 2000;49(23):187-94. [336]. [pmid: 10963831].
Relimpio F, Pumar A, Losada F, Molina J, Maynar A, Acosta D, Astorga R. Urinary albumin excretion rate and cardiovascular disease in Spaniard type 2 diabetic patients. Diabetes Res Clin Pract. 1997;36(2):127-34. [889]. [pmid: 9229197].
Rodby R A, Rohde R, Evans J, Bain R P, Mulcahy W S, Lewis E J. The study of the effect of intensity of blood pressure management on the progression of type 1 diabetic nephropathy: study design and baseline patient characteristics. Collaborative Study Group. J Am Soc Nephrol. 1995;5(10):1775-81. [1222]. [pmid: 7787145].
Rossing P, Hougaard P, Borch-Johnsen K, Parving H H. Predictors of mortality in insulin dependent diabetes: 10 year observational follow up study. BMJ. 1996;313(7060):779-84. [991]. [pmid: 8842069].
Sasaki A, Horiuchi N, Hasagawa K, Uehara M. Persistent albuminuria as an index of diabetic nephropathy in type 2 diabetic patients in Osaka, Japan-incidence, risk factors, prognosis and causes of death. Diabetes Res Clin Pract. 1989;7(4):299-306. [1857]. [pmid: 2612344].
Sasaki A, Horiuchi N, Hasegawa K, Uehara M. Mortality and causes of death in type 2 diabetic patients. A long-term follow-up study in Osaka District, Japan. Diabetes Res Clin Pract. 1989;7(1):33-40. [1890]. [pmid: 2752888].
Sasaki A, Horiuchi N, Hasegawa K, Uehara M. Mortality from coronary heart disease and cerebrovascular disease and associated risk factors in diabetic patients in Osaka District, Japan. Diabetes Res Clin Pract. 1995;27(1):77-83. [1257]. [pmid: 7781497].
Sasaki A, Uehara M, Horiuchi N, Hasagawa K. A long-term follow-up study of Japanese diabetic patients: mortality and causes of death. Diabetologia. 1983;25(4):309-12. [2201]. [pmid: 6642095].
Sasaki A, Uehara M, Horiuchi N, Hasegawa K, Shimizu T. A 15-year follow-up study of patients with non-insulin-dependent diabetes mellitus (NIDDM) in Osaka, Japan. Factors predictive of the prognosis of diabetic patients. Diabetes Res Clin Pract. 1997;36(1):41-7. [900]. [pmid: 9187414].
Sasaki A, Uehara M, Horiuchi N, Hasegawa K, Shimizu T. A 15 year follow-up study of patients with non-insulin dependent diabetes mellitus (NIDDM) in Osaka, Japan. Long-term prognosis and causes of death. Diabetes Res Clin Pract. 1996;34(1):47-55. [995]. [pmid: 8968690].
Sawicki P T, Muhlhauser I, Didjurgeit U, Reimann M, Bender R, Berger M. Mortality and morbidity in treated hypertensive type 2 diabetic patients with micro- or macroproteinuria. Diabet Med. 1995;12(10):893-8. [1151]. [pmid: 8846680].
Schmitz A, Vaeth M. Microalbuminuria: a major risk factor in non-insulin-dependent diabetes. A 10-year follow-up study of 503 patients. Diabet Med. 1988;5(2):126-34. [1986]. [pmid: 2964977].
Schrier R W, Estacio R O, Jeffers B. Appropriate Blood Pressure Control in NIDDM (ABCD) Trial. Diabetologia. 1996;39(12):1646-54. [951]. [pmid: 8960857].
Segura J, Campo C, Rodicio J L, Ruilope L M. ACE inhibitors and appearance of renal events in hypertensive nephrosclerosis. Hypertension. 2001;38(3 Pt 2):645-9. [2610]. [pmid: 11566948].
Simmons D, Schaumkel J, Cecil A, Scott D J, Kenealy T. High impact of nephropathy on five-year mortality rates among patients with Type 2 diabetes mellitus from a multi-ethnic population in New Zealand. Diabet Med. 1999;16(11):926-31. [478]. [pmid: 10588522].
Standl E, Balletshofer B, Dahl B, Weichenhain B, Stiegler H, Hormann A, Holle R. Predictors of 10-year macrovascular and overall mortality in patients with NIDDM: the Munich General Practitioner Project. Diabetologia. 1996;39(12):1540-5. [956]. [pmid: 8960840].
Stehouwer C D, Gall M A, Twisk J W, Knudsen E, Emeis J J, Parving H H. Increased urinary albumin excretion, endothelial dysfunction, and chronic low-grade inflammation in type 2 diabetes: progressive, interrelated, and independently associated with risk of death. Diabetes. 2002;51(4):1157-65. [6834]. [pmid: 11916939].
Stiegler H, Standl E, Schulz K, Roth R, Lehmacher W. Morbidity, mortality, and albuminuria in type 2 diabetic patients: a three-year prospective study of a random cohort in general practice. Diabet Med. 1992;9(7):646-53. [1583]. [pmid: 1511572].
Torffvit O, Agardh C. The prognosis for type 2 diabetic patients with heart disease. A 10-year observation study of 385 patients. J Diabetes Complications. 2000;14(6):301-6. [277]. [pmid: 11120453].
Torffvit O, Agardh C D. The impact of metabolic and blood pressure control on incidence and progression of nephropathy. A 10-year study of 385 type 2 diabetic patients. J Diabetes Complications. 2001;15(6):307-13. [2545]. [pmid: 11711324].
Torffvit O, Agardh C D. The predictive value of albuminuria for cardiovascular and renal disease. A 5-year follow-up study of 476 patients with type I diabetes mellitus. J Diabetes Complications. 1993;7(1):49-56. [1508]. [pmid: 8481551].
Trevisan R, Tiengo A. Effect of low-dose ramipril on microalbuminuria in normotensive or mild hypertensive non-insulin-dependent diabetic patients. North-East Italy Microalbuminuria Study Group. Am J Hypertens. 1995;8(9):876-83. [1171]. [pmid: 8541002].
Tuomilehto J, Borch-Johnsen K, Molarius A, Forsen T, Rastenyte D, Sarti C, Reunanen A. Incidence of cardiovascular disease in Type 1 (insulin-dependent) diabetic subjects with and without diabetic nephropathy in Finland. Diabetologia. 1998;41(7):784-90. [698]. [pmid: 9686919].
Uusitupa M I, Niskanen L K, Siitonen O, Voutilainen E, Pyorala K. Ten-year cardiovascular mortality in relation to risk factors and abnormalities in lipoprotein composition in type 2 (non-insulin-dependent) diabetic and non-diabetic subjects. Diabetologia. 1993;36(11):1175-84. [1408]. [pmid: 8270133].
Valmadrid C T, Klein R, Moss S E, Klein B E. The risk of cardiovascular disease mortality associated with microalbuminuria and gross proteinuria in persons with older-onset diabetes mellitus. Arch Intern Med. 2000;160(8):1093-100. [411]. [pmid: 10789601].
Villar G, Garcia Y, Goicolea I, Vazquez J A. Determinants of development of microalbuminuria in normotensive patients with type 1 and type 2 diabetes. Diabetes Metab. 1999;25(3):246-54. [503]. [pmid: 10499194].
Vora J P, Dolben J, Williams J D, Peters J R, Owens D R. Impact of initial treatment on renal function in newly-diagnosed type 2 (non-insulin-dependent) diabetes mellitus. Diabetologia. 1993;36(8):734-40. [1443]. [pmid: 8405740].
Wang S L, Head J, Stevens L, Fuller J H. Excess mortality and its relation to hypertension and proteinuria in diabetic patients. The world health organization multinational study of vascular disease in diabetes. Diabetes Care. 1996;19(4):305-12. [1077]. [pmid: 8729151].
Watts G F, Powrie J K, O'Brien S F, Shaw K M. Apolipoprotein B independently predicts progression of very-low-level albuminuria in insulin-dependent diabetes mellitus. Metabolism. 1996;45(9):1101-7. [1004]. [pmid: 8781297].
Watts G F, Taub N A, Mazurkiewicz J, Shaw K M. An examination of the covariability of subclinical albuminuria in insulin-dependent diabetes mellitus: implications for monitoring microalbuminuria. Diabetes Res Clin Pract. 1993;21(23):177-85. [1447]. [pmid: 8269820].
Wilhelmsen L. Synergistic effects of risk factors. Clin Exp Hypertens A. 1990;12(5):845-63. [1836]. [pmid: 2208755].
Wilmer W A, Hebert L A, Lewis E J, Rohde R D, Whittier F, Cattran D, Levey A S, Lewis J B, Spitalewitz S, Blumenthal S, Bain R P. Remission of nephrotic syndrome in type 1 diabetes: long-term follow-up of patients in the Captopril Study. Am J Kidney Dis. 1999;34(2):308-14. [3319]. [pmid: 10430979].
Wirta O, Pasternack A, Mustonen J, Laippala P. Renal and cardiovascular predictors of 9-year total and sudden cardiac mortality in non-insulin-dependent diabetic subjects. Nephrol Dial Transplant. 1997;12(12):2612-7. [796]. [pmid: 9430860].
Yokoyama H, Tomonaga O, Hirayama M, Ishii A, Takeda M, Babazono T, Ujihara U, Takahashi C, Omori Y. Predictors of the progression of diabetic nephropathy and the beneficial effect of angiotensin-converting enzyme inhibitors in NIDDM patients. Diabetologia. 1997;40(4):405-11. [3938]. [pmid: 9112017].
Yoshino G, Hirano T, Kazumi T. Atherogenic lipoproteins and diabetes mellitus. J Diabetes Complications. 2002;16(1):29-34. [2476]. [pmid: 11872363].