# Glycohemoglobin Bibliography (N=330)

NOTE: Numbers in brackets correspond to study numbers in the Evidence Tables.

Abraira, Colwell J, Nuttall F, Sawin C T, Henderson W, Comstock J P, Emanuele N V, Levin S R, Pacold I, Lee H S. Cardiovascular events and correlates in the Veterans Affairs Diabetes Feasibility Trial. Veterans Affairs Cooperative Study on Glycemic Control and Complications in Type II Diabetes. Arch Intern Med. 1997;157(2):181-8. [4270]. [pmid: 9009975].
Abraira, McGuire D K. Intensive insulin therapy in patients with type 2 diabetes: implications of the Veterans affairs (VA CSDM) feasibility trial. Am Heart J. 1999;138(5 Pt 1):S360-5. [320]. [pmid: 10539798].
The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial. Diabetes . 1996; 45 (10): 1289–98. [718].
Adachi, Hirai Y, Tsuruta M, Fujiura Y, Imaizuml T. Is insulin resistance or diabetes mellitus associated with stroke? An 18-year follow-up study. Diabetes Res Clin Pract. 2001;51(3):215-23. [4055]. [pmid: 11269894].
Adler, Boyko E J, Ahroni J H, Smith D G. Lower-extremity amputation in diabetes. The independent effects of peripheral vascular disease, sensory neuropathy, and foot ulcers. Diabetes Care. 1999;22(7):1029-35. [3309]. [pmid: 10388962].
Adler, Boyko E J, Ahroni J H, Stensel V, Forsberg R C, Smith D G. Risk factors for diabetic peripheral sensory neuropathy. Results of the Seattle Prospective Diabetic Foot Study. Diabetes Care. 1997;20(7):1162-7. [3431]. [pmid: 9203456].
Adler, Neil H A, Manley S E, Holman R R, Turner R C. Hyperglycemia and hyperinsulinemia at diagnosis of diabetes and their association with subsequent cardiovascular disease in the United Kingdom prospective diabetes study (UKPDS 47). Am Heart J. 1999;138(5 Pt 1):S353-9. [4124]. [pmid: 10539797].
Agardh, Agardh E, Torffvit O. The association between retinopathy, nephropathy, cardiovascular disease and long-term metabolic control in type 1 diabetes mellitus: a 5 year follow-up study of 442 adult patients in routine care. Diabetes Res Clin Pract. 1997;35(23):113-21. [656]. [pmid: 9179466].
Agardh, Agardh C D, Koul S, Torffvit O. A four-year follow-up study on the incidence of diabetic retinopathy in older onset diabetes mellitus. Diabet Med. 1994;11(3):273-8. [992]. [pmid: 8033526].
Agardh, Agardh C D, Torffvit O. A 5-year follow-up study on the incidence of retinopathy in type 1 diabetes mellitus in relation to medical risk indicators. J Intern Med. 1994;235(4):353-8. [989]. [pmid: 8151268].
Alaveras, Thomas S M, Sagriotis A, Viberti G C. Promoters of progression of diabetic nephropathy: the relative roles of blood glucose and blood pressure control. Nephrol Dial Transplant. 1997;12(Suppl 2):71-4. [681]. [pmid: 9269705].
Alderman, Cohen H, Madhavan S. Diabetes and cardiovascular events in hypertensive patients. Hypertension. 1999;33(5):1130-4. [4146]. [pmid: 10334799].
Allen, Shen G, Palta M, Lotz B, Jacobson R, D'Alessio D. Long-term hyperglycemia is related to peripheral nerve changes at a diabetes duration of 4 years. The Wisconsin Diabetes Registry. Diabetes Care. 1997;20(7):1154-8. [3432]. [pmid: 9203454].
Almdal, Norgaard K, Feldt-Rasmussen B, Deckert T. The predictive value of microalbuminuria in IDDM. A five-year follow-up study. Diabetes Care. 1994;17(2):120-5. [1009]. [pmid: 8137681].
Alvarsson, Grill V E. Effect of long term glycemic control on the onset of retinopathy in iddm subjects. A longitudinal and retrospective study. Diabetes Res. 1989;10(2):75-80. [2814]. [pmid: 2743712].
Amador-Licona, Guizar-Mendoza J, Vargas E, Sanchez-Camargo G, Zamora-Mata L. The short-term effect of a switch from glibenclamide to metformin on blood pressure and microalbuminuria in patients with type 2 diabetes mellitus. Arch Med Res. 2000;31(6):571-5. [128]. [pmid: 11257323].
Apelqvist, Agardh C D. The association between clinical risk factors and outcome of diabetic foot ulcers. Diabetes Res Clin Pract. 1992;18(1):43-53. [1154]. [pmid: 1446576].
Araki, Ito H, Hattori A, Inoue J, Sato T, Shiraki M, Orimo H. Risk factors for development of retinopathy in elderly Japanese patients with diabetes mellitus. Diabetes Care. 1993;16(8):1184-6. [2535]. [pmid: 8375248].
Arfken, Reno P L, Santiago J V, Klein R. Development of proliferative diabetic retinopathy in African-Americans and whites with type 1 diabetes. Diabetes Care. 1998;21(5):792-5. [2157]. [pmid: 9589242].
Azad, Emanuele N V, Abraira C, Henderson W G, Colwell J, Levin S R, Nuttall F Q, Comstock J P, Sawin C T, Silbert C, Rubino F A. The effects of intensive glycemic control on neuropathy in the VA cooperative study on type II diabetes mellitus (VA CSDM). J Diabetes Complications. 1999;13(56):307-13. [3267]. [pmid: 10765007].
Baba. Nifedipine and enalapril equally reduce the progression of nephropathy in hypertensive type 2 diabetics. Diabetes Res Clin Pract. 2001;54(3):191-201. [33]. [pmid: 11689274].
Ballard, Humphrey L L, Melton L J 3rd, Frohnert P P, Chu P C, O'Fallon W M, Palumbo P J. Epidemiology of persistent proteinuria in type II diabetes mellitus. Population-based study in Rochester, Minnesota. Diabetes. 1988;37(4):405-12. [1489]. [pmid: 3378684].
Bangstad, Hanssen K F, Dahl-Jorgensen K, Aagenaes O. Microalbuminuria is associated with long term poor glycemic control in adolescent insulin dependent diabetics. Diabetes Res. 1989;12(2):71-4. [1413]. [pmid: 2634509].
Bangstad, Kofoed-Enevoldsen A, Dahl-Jorgensen K, Hanssen K F. Glomerular charge selectivity and the influence of improved blood glucose control in type 1 (insulin-dependent) diabetic patients with microalbuminuria. Diabetologia. 1992;35(12):1165-9. [1141]. [pmid: 1478369].
Barnas, Schmidt A, Illievich A, Kiener H P, Rabensteiner D, Kaider A, Prager R, Abrahamian H, Irsigler K, Mayer G. Evaluation of risk factors for the development of nephropathy in patients with IDDM: insertion/deletion angiotensin converting enzyme gene polymorphism, hypertension and metabolic control. Diabetologia. 1997;40(3):327-31. [662]. [pmid: 9084972].
Bauer, Reams G P, Hewett J, Klachko D, Lau A, Messina C, Knaus V. A randomized, double-blind, placebo-controlled trial to evaluate the effect of enalapril in patients with clinical diabetic nephropathy. Am J Kidney Dis. 1992;20(5):443-57. [1151]. [pmid: 1442757].
Beatty, Ritchie C M, Bell P M, Hadden D R, Kennedy L, Atkinson A B. Microalbuminuria as identified by a spot morning urine specimen in non-insulin-treated diabetes: an eight-year follow-up study. Diabet Med. 1995;12(3):261-6. [899]. [pmid: 7758264].
Bell, Ketchum C H, Robinson C A, Wagenknecht L E, Williams B T. Microalbuminuria associated with diabetic neuropathy. Diabetes Care. 1992;15(4):528-31. [1206]. [pmid: 1499470].
Bendick, Glover J L, Kuebler T W, Dilley R S. Progression of atherosclerosis in diabetics. Surgery. 1983;93(6):834-8. [3043]. [pmid: 6857501].
Bending, Viberti G C, Bilous R W, Keen H. Eight-month correction of hyperglycemia in insulin-dependent diabetes mellitus is associated with a significant and sustained reduction of urinary albumin excretion rates in patients with microalbuminuria. Diabetes. 1985;34(Suppl 3):69-73. [1607]. [pmid: 4018422].
Blood glucose control and the evolution of diabetic retinopathy and albuminuria. A preliminary multicenter trial. The Kroc Collaborative Study Group. N Engl J Med 1984; 311 (6): 365–72. [1632].
Bojestig, Arnqvist H J, Karlberg B E, Ludvigsson J. Glycemic control and prognosis in type I diabetic patients with microalbuminuria. Diabetes Care. 1996;19(4):313-7. [760]. [pmid: 8729152].
Bojestig, Arnqvist H J, Karlberg B E, Ludvigsson J. Unchanged incidence of severe retinopathy in a population of Type 1 diabetic patients with marked reduction of nephropathy. Diabet Med. 1998;15(10):863-9. [460]. [pmid: 9796888].
Bonney, Hing S J, Fung A T, Stephens M M, Fairchild J M, Donaghue K C, Howard N J, Silink M. Development and progression of diabetic retinopathy: adolescents at risk. Diabet Med. 1995;12(11):967-73. [2379]. [pmid: 8582128].
Brichard, Santoni J P, Thomas J R, van de Voorde K, Ketelslegers J M, Lambert A E. Long term reduction of microalbuminuria after 1 year of angiotensin converting enzyme inhibition by perindopril in hypertensive insulin-treated diabetic patients. Diabete Metab. 1990;16(1):30-6. [1392]. [pmid: 2185055].
Brinchmann-Hansen, Dahl-Jorgensen K, Hanssen K F, Sandvik L. Oscillatory potentials, retinopathy, and long-term glucose control in insulin-dependent diabetes. Acta Ophthalmol (Copenh). 1992;70(6):705-12. [2586]. [pmcid: 358319]. [pmid: 1488874].
Brinchmann-Hansen, Dahl-Jorgensen K, Sandvik L, Hanssen K F. Blood glucose concentrations and progression of diabetic retinopathy: the seven year results of the Oslo study. BMJ. 1992;304(6818):19-22. [2645]. [pmid: 1734985]. [pmcid: 1880908].
Brocco, Velussi M, Cernigoi A M, Abaterusso C, Bruseghin M, Carraro A, Sambataro M, Piarulli F, Sfriso A, Nosadini R. Evidence of a threshold value of glycated hemoglobin to improve the course of renal function in type 2 diabetes with typical diabetic glomerulopathy. J Nephrol. 2001;14(6):461-71. [13]. [pmid: 11783602].
Captopril reduces the risk of nephropathy in IDDM patients with microalbuminuria. The Microalbuminuria Captopril Study Group. Diabetologia 1996; 39 (5): 587–93. [745].
Chase, Garg S K, Jackson W E, Thomas M A, Harris S, Marshall G, Crews M J. Blood pressure and retinopathy in type I diabetes. Ophthalmology. 1990;97(2):155-9. [1380]. [pmid: 2326002].
Chase, Jackson W E, Hoops S L, Cockerham R S, Archer P G, O'Brien D. Glucose control and the renal and retinal complications of insulin-dependent diabetes. JAMA. 1989;261(8):1155-60. [1444]. [pmid: 2915437].
Chase, Marshall G, Garg S K, Harris S, Osberg I. Borderline increases in albumin excretion rate and the relation to glycemic control in subjects with type I diabetes. Clin Chem. 1991;37(12):2048-52. [1237]. [pmid: 1764780].
Chaturvedi, Bandinelli S, Mangili R, Penno G, Rottiers R E, Fuller J H. Microalbuminuria in type 1 diabetes: rates, risk factors and glycemic threshold. Kidney Int. 2001;60(1):219-27. [84]. [pmid: 11422754].
Chaturvedi, Sjoelie A K, Porta M, Aldington S J, Fuller J H, Songini M, Kohner E M. Markers of insulin resistance are strong risk factors for retinopathy incidence in type 1 diabetes. Diabetes Care. 2001;24(2):284-9. [140]. [pmid: 11213880].
Chen, Kao C S, Fu C C, Chen C J, Tai T Y. Incidence and progression of diabetic retinopathy among non-insulin-dependent diabetic subjects: a 4-year follow-up. Int J Epidemiol. 1995;24(4):787-95. [2392]. [pmid: 8550277].
Chiarelli, Cipollone F, Romano F, Tumini S, Costantini F, di Ricco L, Pomilio M, Pierdomenico S D, Marini M, Cuccurullo F, Mezzetti A. Increased circulating nitric oxide in young patients with type 1 diabetes and persistent microalbuminuria: relation to glomerular hyperfiltration. Diabetes. 2000;49(7):1258-63. [228]. [pmid: 10909986].
Christen, Manson J E, Bubes V, Glynn R J. Risk factors for progression of distal symmetric polyneuropathy in type 1 diabetes mellitus. Sorbinil Retinopathy Trial Research Group. Am J Epidemiol. 1999;150(11):1142-51. [1999]. [pmid: 10588075].
Christensen, Rossing P, Nielsen F S, Parving H H. Natural course of kidney function in Type 2 diabetic patients with diabetic nephropathy. Diabet Med. 1999;16(5):388-94. [379]. [pmid: 10342338].
Cohen, Jeffers B W, Faldut D, Marcoux M, Schrier R W. Risks for sensorimotor peripheral neuropathy and autonomic neuropathy in non-insulin-dependent diabetes mellitus (NIDDM). Muscle Nerve. 1998;21(1):72-80. [584]. [pmid: 9427226].
Cohen, Hennekens C H, Christen W G, Krolewski A, Nathan D M, Peterson M J, LaMotte F, Manson J E. Determinants of retinopathy progression in type 1 diabetes mellitus. Am J Med. 1999;107(1):45-51. [2039]. [pmid: 10403352].
Colhoun, Lee E T, Bennett P H, Lu M, Keen H, Wang S L, Stevens L K, Fuller J H. Risk factors for renal failure: the WHO Mulinational Study of Vascular Disease in Diabetes. Diabetologia. 2001;44(Suppl 2):S46-53. [42]. [pmid: 11587050].
Colwell. The feasibility of intensive insulin management in non-insulin-dependent diabetes mellitus. Implications of the Veterans Affairs Cooperative Study on Glycemic Control and Complications in NIDDM. Ann Intern Med. 1996;124(1 Pt 2):131-5. [2368]. [pmid: 8554205].
Cook, Daneman D. Microalbuminuria in adolescents with insulin-dependent diabetes mellitus. Am J Dis Child. 1990;144(2):234-7. [1381]. [pmid: 2301330].
Coonrod, Ellis D, Becker D J, Bunker C H, Kelsey S F, Lloyd C E, Drash A L, Kuller L H, Orchard T J. Predictors of microalbuminuria in individuals with IDDM. Pittsburgh Epidemiology of Diabetes Complications Study. Diabetes Care. 1993;16(10):1376-83. [1036]. [pmid: 8269796].
Couper, Clarke C F, Byrne G C, Jones T W, Donaghue K C, Nairn J, Boyce D, Russell M, Stephens M, Raymond J, Bates D J, McCaul K. Progression of borderline increases in albuminuria in adolescents with insulin-dependent diabetes mellitus. Diabet Med. 1997;14(9):766-71. [604]. [pmid: 9300227].
d'Annunzio, Malvezzi F, Vitali L, Barone C, Giacchero R, Klersy C, Zanette S, Lorini R. A 3–19-year follow-up study on diabetic retinopathy in patients diagnosed in childhood and treated with conventional therapy. Diabet Med. 1997;14(11):951-8. [587]. [pmid: 9400919].
D'Antonio, Ellis D, Doft B H, Becker D J, Drash A L, Kuller L H, Orchard T J. Diabetes complications and glycemic control. The Pittsburgh Prospective Insulin-Dependent Diabetes Cohort Study Status Report after 5 yr of IDDM. Diabetes Care. 1989;12(10):694-70. [1409]. [pmid: 2612304].
Dahl-Jorgensen. Near-normoglycemia and late diabetic complications. The Oslo Study. Acta Endocrinol Suppl (Copenh). 1987;284:1-38. [2910]. [pmid: 3300128].
Dahl-Jorgensen, Hanssen K F, Kierulf P, Bjoro T, Sandvik L, Aagenaes O. Reduction of urinary albumin excretion after 4 years of continuous subcutaneous insulin infusion in insulin-dependent diabetes mellitus. The Oslo Study. Acta Endocrinol (Copenh). 1988;117(1):19-25. [1503]. [pmid: 3289293].
Dahlquist, Aperia A, Broberger O, Persson B, Wilton P. Renal function in relation to metabolic control in children with diabetes of different duration. Acta Paediatr Scand. 1983;72(6):903-9. [1658]. [pmid: 6369870].
Dahlquist, Stattin E L, Rudberg S. Urinary albumin excretion rate and glomerular filtration rate in the prediction of diabetic nephropathy; a long-term follow-up study of childhood onset type-1 diabetic patients. Nephrol Dial Transplant. 2001;16(7):1382-6. [80]. [pmid: 11427629].
Danne, Weber B, Hartmann R, Enders I, Burger W, Hovener G. Long-term glycemic control has a nonlinear association to the frequency of background retinopathy in adolescents with diabetes. Follow-up of the Berlin Retinopathy Study. Diabetes Care. 1994;17(12):1390-6. [934]. [pmid: 7882807].
Davis, Constable I J, Nicol D J, McCann V J, Welborn T A. Association of retinopathy and glycosylated haemoglobin levels in diabetes mellitus. Med J Aust. 1980;2(10):558-60. [3100]. [pmid: 7007836].
Derby, Warram J H, Laffel L M, Krolewski A S. Elevated blood pressure predicts the development of persistent proteinuria in the presence of poor glycemic control, in patients with type I diabetes. Diabete Metab. 1989;15(5 Pt 2):320-6. [1453]. [pmid: 2612716].
Dillon. The quantitative relationship between treated blood pressure and progression of diabetic renal disease. Am J Kidney Dis. 1993;22(6):798-802. [1024]. [pmid: 8250025].
Does improved control of glycemia prevent or ameliorate diabetic polyneuropathy? Committee on Health Care Issues, American Neurological Association. Ann Neurol . 1986; 19 (3): 288–90. [3895].
Doft, Kingsley L A, Orchard T J, Kuller L, Drash A, Becker D. The association between long-term diabetic control and early retinopathy. Ophthalmology. 1984;91(7):763-9. [3006]. [pmid: 6472813].
Donaghue, Fung A T, Fairchild J M, Howard N J, Silink M. Prospective assessment of autonomic and peripheral nerve function in adolescents with diabetes. Diabet Med. 1996;13(1):65-71. [3533]. [pmid: 8741815].
Duck, Wei F F, Parke J, Swick H M. Role of height and glycosylated hemoglobin in abnormal nerve conduction in pediatric patients with type I diabetes mellitus after 4–9 yr of disease. Diabetes Care. 1991;14(5):386-92. [3734]. [pmid: 2060450].
Duvnjak, Vuckovic S, Car N, Metelko Z. Relationship between autonomic function, 24-h blood pressure, and albuminuria in normotensive, normoalbuminuric patients with Type 1 diabetes. J Diabetes Complications. 2001;15(6):314-9. [27]. [pmid: 11711325].
Dyck, Davies J L, Wilson D M, Service F J, Melton L J 3rd, O'Brien P C. Risk factors for severity of diabetic polyneuropathy: intensive longitudinal assessment of the Rochester Diabetic Neuropathy Study cohort. Diabetes Care. 1999;22(9):1479-86. [2022]. [pmid: 10480512].
Earle, Morocutti A, Viberti G. Permissive role of hypertension in the development of proteinuria and progression of renal disease in insulin-dependent diabetic patients. J Hypertens. 1997;15(2):191-6. [566]. [pmid: 9469795].
Early worsening of diabetic retinopathy in the Diabetes Control and Complications Trial. Arch Ophthalmol . 1998; 116 (7): 874–86. [2136].
Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). UK Prospective Diabetes Study (UKPDS) Group. Lancet 1998; 352 (9131): 854–65. [4185].
The effect of intensive diabetes therapy on measures of autonomic nervous system function in the Diabetes Control and Complications Trial (DCCT). Diabetologia . 1998; 41 (4): 416–23. [2162].
Effect of intensive diabetes treatment on carotid artery wall thickness in the epidemiology of diabetes interventions and complications. Epidemiology of Diabetes Interventions and Complications (EDIC) Research Group. Diabetes 1999; 48 (2): 383–90. [4147].
The effect of intensive diabetes treatment on the progression of diabetic retinopathy in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial. Arch Ophthalmol 1995; 113 (1): 36–51. [2438].
Effect of intensive therapy on residual beta-cell function in patients with type 1 diabetes in the diabetes control and complications trial. A randomized, controlled trial. The Diabetes Control and Complications Trial Research Group. Ann Intern Med 1998; 128 (7): 517–23. [2148].
The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group. N Engl J Med 1993; 329 (14): 977–86. [4638].
Eichold, Kemp S F, Hennessey P T. Graded Smelo response as a measure of neurologic integrity and glycemia status of children with diabetes mellitus. Ala Med. 1986;55(7):35-8. [3896]. [pmid: 3953336].
Einhorn, Rendell M, Rosenzweig J, Egan J W, Mathisen A L, Schneider R L. Pioglitazone hydrochloride in combination with metformin in the treatment of type 2 diabetes mellitus: a randomized, placebo-controlled study. The Pioglitazone 027 Study Group. Clin Ther. 2000;22(12):1395-409. [149]. [pmid: 11192132].
Emanuele, Klein R, Abraira C, Colwell J, Comstock J, Henderson W G, Levin S, Nuttall F, Sawin C, Silbert C, Lee H S, Johnson-Nagel N. Evaluations of retinopathy in the VA Cooperative Study on Glycemic Control and Complications in Type II Diabetes (VA CSDM). A feasibility study. Diabetes Care. 1996;19(12):1375-81. [703]. [pmid: 8941467].
Fedele, Coscelli C, Cucinotta D, Forti G, Santeusanio F, Viaggi S, Fiori G, Velona T, Lavezzari M. Incidence of erectile dysfunction in Italian men with diabetes. J Urol. 2001;166(4):1368-71. [3157]. [pmid: 11547076].
Feldt-Rasmussen, Mathiesen E R, Jensen T, Lauritzen T, Deckert T. Effect of improved metabolic control on loss of kidney function in type 1 (insulin-dependent) diabetic patients: an update of the Steno studies. Diabetologia. 1991;34(3):164-70. [1299]. [pmid: 1884887].
Florkowski, Scott R S, Coope P A, Graham P J, Moir C L. Age at diagnosis, glycaemic control and the development of retinopathy in a population-based cohort of Type 1 diabetic subjects in Canterbury, New Zealand. Diabetes Res Clin Pract. 2001;52(2):125-31. [1854]. [pmid: 11311967].
Florkowski, Scott R S, Moir C L, Graham P J. Clinical and biochemical outcomes of type 2 diabetes mellitus in Canterbury, New Zealand: a 6-year cohort study. Diabetes Res Clin Pract. 1998;40(3):167-73. [481]. [pmid: 9716920].
Florkowski, Scott R S, Moir C L, Graham P J. Lipid but not glycaemic parameters predict total mortality from type 2 diabetes mellitus in Canterbury, New Zealand. Diabet Med. 1998;15(5):386-92. [519]. [pmid: 9609360].
Forrest, Becker D J, Kuller L H, Wolfson S K, Orchard T J. Are predictors of coronary heart disease and lower-extremity arterial disease in type 1 diabetes the same? A prospective study. Atherosclerosis. 2000;148(1):159-69. [316]. [pmid: 10580182].
Forsblom, Groop P H, Ekstrand A, Totterman K J, Sane T, Saloranta C, Groop L. Predictors of progression from normoalbuminuria to microalbuminuria in NIDDM. Diabetes Care. 1998;21(11):1932-8. [456]. [pmid: 9802746].
Frank, Hoffman W H, Podgor M J, Joondeph H C, Lewis R A, Margherio R R, Nachazel D P Jr, Weiss H, Christopherson K W, Cronin M A. Retinopathy in juvenile-onset type I diabetes of short duration. Diabetes. 1982;31(10):874-82. [3067]. [pmid: 7152126].
Friberg, Rosenstock J, Sanborn G, Vaghefi A, Raskin P. The effect of long-term near normal glycemic control on mild diabetic retinopathy. Ophthalmology. 1985;92(8):1051-8. [2967]. [pmid: 4047600].
Frost, Friedl A, Beischer W. Determinants of early carotid atherosclerosis progression in young patients with type 1 diabetes mellitus. Exp Clin Endocrinol Diabetes. 2002;110(2):92-4. [4594]. [pmid: 11928073].
Fu, Chang C J, Tseng C H, Chen M S, Kao C S, Wu T J, Wu H P, Chuang L M, Chen C J, Tai T Y. Development of macrovascular diseases in NIDDM patients in northern Taiwan. A 4-yr follow-up study. Diabetes Care. 1993;16(1):137-43. [4403]. [pmid: 8422768].
Funatsu, Yamashita H, Ohashi Y, Ishigaki T. Correlation between progression of diabetic retinopathy and blood glucose control. Jpn J Ophthalmol. 1991;35(3):306-16. [2718]. [pmid: 1770671].
Gaede, Vedel P, Parving H H, Pedersen O. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. 1999;353(9153):617-22. [416]. [pmid: 10030326].
Gall, Borch-Johnsen K, Hougaard P, Nielsen F S, Parving H H. Albuminuria and poor glycemic control predict mortality in NIDDM. Diabetes. 1995;44(11):1303-9. [827]. [pmid: 7589828].
Gall, Hougaard P, Borch-Johnsen K, Parving H H. Risk factors for development of incipient and overt diabetic nephropathy in patients with non-insulin dependent diabetes mellitus: prospective, observational study. BMJ. 1997;314(7083):783-8. [654]. [pmid: 9080995]. [pmcid: 2126209].
Glycaemic control reduces incidence of morbidity. Elder Care . 1994; 6 (6): 33. [2455].
Goetz, Jacobs D R Jr, Chavers B, Roel J, Yelle M, Sprafka J M. Risk factors for kidney damage in the adult population of Wadena, Minnesota. A prospective study. Am J Epidemiol. 1997;145(2):91-102. [678]. [pmid: 9006305].
Goldstein, Blinder KJ, Ide CH, Wilson RJ, Wiedmeyer HM, Little RR, England JD, Eddy M, Hewett JE, and Anderson SK. Glycemic control and development of retinopathy in youth-onset insulin-dependent diabetes mellitus. Results of a 12-year longitudinal study. Ophthalmology . 1993; 100 (8): 1125–31; discussion 1131–2. [2538].
Goriya, Suzuki T, Takizawa S, Natto M. Follow-up of elderly diabetics with or without hypertension and hyperlipidemia. J Environ Pathol Toxicol Oncol. 2000;19(12):159-65. [231]. [pmid: 10905522].
Gorman, Sochett E, Daneman D. The natural history of microalbuminuria in adolescents with type 1 diabetes. J Pediatr. 1999;134(3):333-7. [415]. [pmid: 10064671].
Groop, Teir H, Koskimies S, Groop P H, Matikainen E, Verkkala E, Scheinin T, Kontiainen S, Teppo A M, Tolppanen E M, et al. Risk factors and markers associated with proliferative retinopathy in patients with insulin-dependent diabetes. Diabetes. 1986;35(12):1397-403. [1560]. [pmid: 3770315].
Guillausseau, Massin P, Charles M A, Allaguy H, Guvenli Z, Virally M, Tielmans D, Assayag M, Warnet A, Lubetzki J. Glycaemic control and development of retinopathy in type 2 diabetes mellitus: a longitudinal study. Diabet Med. 1998;15(2):151-5. [556]. [pmid: 9507917].
Hadden, Patterson C C, Atkinson A B, Kennedy L, Bell P M, McCance D R, Weaver J A. Macrovascular disease and hyperglycaemia: 10-year survival analysis in Type 2 diabetes mellitus: the Belfast Diet Study. Diabet Med. 1997;14(8):663-72. [4237]. [pmid: 9272593].
Haffner, Fong D, Stern M P, Pugh J A, Hazuda H P, Patterson J K, van Heuven W A, Klein R. Diabetic retinopathy in Mexican Americans and non-Hispanic whites. Diabetes. 1988;37(7):878-84. [2847]. [pmid: 3384186].
Haneda, Kikkawa R, Togawa M, Koya D, Kajiwara N, Uzu T, Shigeta Y. High blood pressure is a risk factor for the development of microalbuminuria in Japanese subjects with non-insulin-dependent diabetes mellitus. J Diabetes Complications. 1992;6(3):181-5. [1172]. [pmid: 1472744].
Hansson-Lundblad, Agardh E, Agardh C D. Retinal examination intervals in diabetic patients on diet treatment only. Acta Ophthalmol Scand. 1997;75(3):244-8. [2234]. [pmid: 9253966].
Hasslacher, Bostedt-Kiesel A, Kempe H P, Wahl P. Effect of metabolic factors and blood pressure on kidney function in proteinuric type 2 (non-insulin-dependent) diabetic patients. Diabetologia. 1993;36(10):1051-6. [1044]. [pmid: 8243854].
Hellman, Regan J, Rosen H. Effect of intensive treatment of diabetes of the risk of death or renal failure in NIDDM and IDDM. Diabetes Care. 1997;20(3):258-64. [670]. [pmid: 9051368].
Helve, Laatikainen L, Merenmies L, Koivisto V A. Continuous insulin infusion therapy and retinopathy in patients with type I diabetes. Acta Endocrinol (Copenh). 1987;115(3):313-9. [2885]. [pmid: 3303785].
Henricsson, Gottsater A, Jeppsson J O, Fernlund P, Sundkvist G. The frequency and severity of retinopathy are related to HbA1c values after, but not at, the diagnosis of NIDDM. J Intern Med. 1998;244(2):149-54. [2073]. [pmid: 10095801].
Henricsson, Groop L, Heijl A. Progression of retinopathy is related to glycaemic control even in patients with mild diabetes mellitus. Acta Ophthalmol Scand. 1996;74(6):528-32. [2292]. [pmid: 9017035].
Henricsson, Heijl A, Janzon L. Diabetic retinopathy before and after cataract surgery. Br J Ophthalmol. 1996;80(9):789-93. [2313]. [pmid: 8942374]. [pmcid: 505613].
Henricsson, Nilsson A, Heijl A, Janzon L, Groop L. Mortality in diabetic patients participating in an ophthalmological control and screening programme. Diabet Med. 1997;14(7):576-83. [2228]. [pmid: 9223396].
Henricsson, Nilsson A, Janzon L, Groop L. The effect of glycaemic control and the introduction of insulin therapy on retinopathy in non-insulin-dependent diabetes mellitus. Diabet Med. 1997;14(2):123-31. [2281]. [pmid: 9047089].
Henricsson, Sellman A, Tyrberg M, Groop L. Progression to proliferative retinopathy and macular oedema requiring treatment. Assessment of the alternative classification of the Wisconsin Study. Acta Ophthalmol Scand. 1999;77(2):218-23. [2062]. [pmid: 10321543].
Henricsson, Tyrberg M, Heijl A, Janzon L. Incidence of blindness and visual impairment in diabetic patients participating in an ophthalmological control and screening programme. Acta Ophthalmol Scand. 1996;74(6):533-8. [2291]. [pmid: 9017036].
Holman, Dornan T L, Mayon-White V, Howard-Williams J, Orde-Peckar C, Jenkins L, Steemson J, Rolfe R, Smith B, Barbour D, McPherson K, Poon P, Rizza C, Mann J I, Knight A H, Bron A J, Turner R C. Prevention of deterioration of renal and sensory-nerve function by more intensive management of insulin-dependent diabetic patients. A two-year randomised prospective study. Lancet. 1983;1(8318):204-8. [1673]. [pmid: 6130244].
Hommel, Andersen P, Gall M A, Nielsen F, Jensen B, Rossing P, Dyerberg J, Parving H H. Plasma lipoproteins and renal function during simvastatin treatment in diabetic nephropathy. Diabetologia. 1992;35(5):447-51. [1193]. [pmid: 1521727].
Hovind, Rossing P, Tarnow L, Smidt U M, Parving H H. Progression of diabetic nephropathy. Kidney Int. 2001;59(2):702-9. [154]. [pmid: 11168952].
Hovind, Rossing P, Tarnow L, Smidt U M, Parving H H. Remission and regression in the nephropathy of type 1 diabetes when blood pressure is controlled aggressively. Kidney Int. 2001;60(1):277-83. [83]. [pmid: 11422762].
Howard-Williams, Hillson R M, Bron A, Awdry P, Mann J I, Hockaday T D. Retinopathy is associated with higher glycaemia in maturity-onset type diabetes. Diabetologia. 1984;27(2):198-202. [3003]. [pmid: 6386582].
Howard-Williams, Patel P, Jelfs R, Carter R D, Awdry P, Bron A, Mann J I, Hockaday T D. Polyunsaturated fatty acids and diabetic retinopathy. Br J Ophthalmol. 1985;69(1):15-8. [2990]. [pmid: 3965024]. [pmcid: 1040514].
Hsu, Bates D W, Kuperman G J, Curhan G C. Diabetes, hemoglobin A(1c), cholesterol, and the risk of moderate chronic renal insufficiency in an ambulatory population. Am J Kidney Dis. 2000;36(2):272-81. [225]. [pmid: 10922305].
Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group. Lancet 1998; 352 (9131): 837–53. [2113].
Intensive therapy and progression to clinical albuminuria in patients with insulin dependent diabetes mellitus and microalbuminuria. Microalbuminuria Collaborative Study Group, United Kingdom. BMJ 1995; 311 (7011): 973–7. [829].
Iribarren, Karter A J, Go A S, Ferrara A, Liu J Y, Sidney S, Selby J V. Glycemic control and heart failure among adult patients with diabetes. Circulation. 2001;103(22):2668-73. [4042]. [pmid: 11390335].
Isomaa, Almgren P, Tuomi T, Forsen B, Lahti K, Nissen M, Taskinen M R, Groop L. Cardiovascular morbidity and mortality associated with the metabolic syndrome. Diabetes Care. 2001;24(4):683-9. [110]. [pmid: 11315831].
Izumi, Hoshi M, Kuno S, Okuno G, Yamazaki Y, Isshiki G, Sasaki A. Glycemic control, growth and complications in children with insulin-dependent diabetes mellitus--a study of children enrolled in a Summer camp program for diabetics in Kinki district, Japan. Diabetes Res Clin Pract. 1995;28(3):185-90. [871]. [pmid: 8529497].
Janghorbani, Jones R B, Allison S P. Incidence of and risk factors for proliferative retinopathy and its association with blindness among diabetes clinic attenders. Ophthalmic Epidemiol. 2000;7(4):225-41. [1865]. [pmid: 11262670].
Janka, Warram J H, Rand L I, Krolewski A S. Risk factors for progression of background retinopathy in long-standing IDDM. Diabetes. 1989;38(4):460-4. [2809]. [pmid: 2647552].
Jarrett, Keen H, Boyns D R, Chlouverakis C, Fuller J. The concomitants of raised blood sugar: studies in newly-detected hyperglycaemics. I. A comparative assessment of neurological functions in blood sugar groups. Guys Hosp Rep. 1969;118(2):237-46. [3999]. [pmid: 5804066].
Jerums, Allen T J, Cooper M E. Triphasic changes in selectivity with increasing proteinuria in type 1 and type 2 diabetes. Diabet Med. 1989;6(9):772-9. [1406]. [pmid: 2533035].
Jerums, Allen T J, Tsalamandris C, Akdeniz A, Sinha A, Gilbert R, Cooper M E. Relationship of progressively increasing albuminuria to apoprotein(a) and blood pressure in type 2 (non-insulin-dependent) and type 1 (insulin-dependent) diabetic patients. Diabetologia. 1993;36(10):1037-44. [1045]. [pmid: 8243852].
Jerums, Cooper M E, Seeman E, Murray R M, McNeil J J. Comparison of early renal dysfunction in type I and type II diabetes: differing associations with blood pressure and glycaemic control. Diabetes Res Clin Pract. 1988;4(2):133-41. [1499]. [pmid: 3342732].
Jerums, Murray R M, Seeman E, Cooper M E, Edgley S, Marwick K, Larkins R G, Martin T J. Lack of effect of gliclazide on early diabetic nephropathy and retinopathy: a two-year controlled study. Diabetes Res Clin Pract. 1987;3(2):71-80. [1543]. [pmid: 3552537].
Jones, Leese G P, Kerr S, Bestwick K, Isherwood D I, Vora J P, Hughes D A, Smith C. Development and progression of microalbuminuria in a clinic sample of patients with insulin dependent diabetes mellitus. Arch Dis Child. 1998;78(6):518-23. [482]. [pmid: 9713006].
Kalter-Leibovici, Leibovici L, Loya N, Kremer I, Axer-Siegel R, Karp M, Laron Z. The development and progression of diabetic retinopathy in type I diabetic patients: a cohort study. Diabet Med. 1997;14(10):858-66. [2207]. [pmid: 9371479].
Kalter-Leibovici, Van Dyk D J, Leibovici L, Loya N, Erman A, Kremer I, Boner G, Rosenfeld J B, Karp M, Laron Z. Risk factors for development of diabetic nephropathy and retinopathy in Jewish IDDM patients. Diabetes. 1991;40(2):204-10. [1305]. [pmid: 1991571].
Karavanaki, Davies A G, Morgan M H, Baum J D. Autonomic function in a cohort of children with diabetes. J Pediatr Endocrinol Metab. 1997;10(6):599-607. [3402]. [pmid: 9467130].
Kato, Fukada Y, Hori S, Tanaka Y, Oshika T. Influence of phacoemulsification and intraocular lens implantation on the course of diabetic retinopathy. J Cataract Refract Surg. 1999;25(6):788-93. [2046]. [pmid: 10374158].
Kawazu, Tomono S, Shimizu M, Kato N, Ohno T, Ishii C, Murata K, Watanabe T, Negishi K, Suzuki M, et al. The relationship between early diabetic nephropathy and control of plasma glucose in non-insulin-dependent diabetes mellitus. The effect of glycemic control on the development and progression of diabetic nephropathy in an 8-year follow-up study. J Diabetes Complications. 1994;8(1):13-7. [1016]. [pmid: 8167381].
Kazumi, Hozumi T, Ishida Y, Ikeda Y, Kishi K, Hayakawa M, Yoshino G. Increased urinary transferrin excretion predicts microalbuminuria in patients with type 2 diabetes. Diabetes Care. 1999;22(7):1176-80. [366]. [pmid: 10388985].
Keen, Chlouverakis C, Fuller J, Jarrett R J. The consomitants of raised blood sugar: studies in newly-detected hyperglycaemics. II. Urinary albumin excretion, blood pressure and their relation to blood sugar levels. Guys Hosp Rep. 1969;118(2):247-54. [1756]. [pmid: 5804067].
Khaw, Wareham N, Luben R, Bingham S, Oakes S, Welch A, Day N. Glycated haemoglobin, diabetes, and mortality in men in Norfolk cohort of european prospective investigation of cancer and nutrition (EPIC-Norfolk). BMJ. 2001;322(7277):15-8. [4066]. [pmcid: 26599]. [pmid: 11141143].
Kim, Kim C H, Kim S W, Park J Y, Hong S K, Yoon Y H, Lee K U. Development and progression of diabetic retinopathy in Koreans with NIDDM. Diabetes Care. 1998;21(1):134-8. [2171]. [pmid: 9538984].
Kingsley, Dorman J S, Doft B H, Orchard T J, LaPorte R E, Kuller L H, Drash A L. An epidemiologic approach to the study of retinopathy: the Pittsburgh diabetic morbidity and retinopathy studies. Diabetes Res Clin Pract. 1988;4(2):99-109. [2864]. [pmid: 3342736].
Klein, Klein R, Lee K E. Diabetes, cardiovascular disease, selected cardiovascular disease risk factors, and the 5-year incidence of age-related cataract and progression of lens opacities: the Beaver Dam Eye Study. Am J Ophthalmol. 1998;126(6):782-90. [2092]. [pmid: 9860001].
Klein, Klein B E, Lee K E, Moss S E, Cruickshanks K J. Prevalence of self-reported erectile dysfunction in people with long-term IDDM. Diabetes Care. 1996;19(2):135-41. [2354]. [pmid: 8718433].
Klein, Klein B E, Moss S E. Incidence of gross proteinuria in older-onset diabetes. A population-based perspective. Diabetes. 1993;42(3):381-9. [1103]. [pmid: 8432408].
Klein, Klein B E, Moss S E. The incidence of gross proteinuria in people with insulin-dependent diabetes mellitus. Arch Intern Med. 1991;151(7):1344-8. [2691]. [pmid: 2064485].
Klein, Klein B E, Moss S E. Relation of glycemic control to diabetic microvascular complications in diabetes mellitus. Ann Intern Med. 1996;124(1 Pt 2):90-6. [809]. [pmid: 8554220].
Klein, Klein B E, Moss S E, Cruickshanks K J. Relationship of hyperglycemia to the long-term incidence and progression of diabetic retinopathy. Arch Intern Med. 1994;154(19):2169-78. [2458]. [pmid: 7944837].
Klein, Klein B E, Moss S E, Cruickshanks K J. Ten-year incidence of gross proteinuria in people with diabetes. Diabetes. 1995;44(8):916-23. [853]. [pmid: 7621997].
Klein, Klein B E, Moss S E, Cruickshanks K J. The Wisconsin Epidemiologic Study of Diabetic Retinopathy. XV. The long-term incidence of macular edema. Ophthalmology. 1995;102(1):7-16. [2437]. [pmid: 7831044].
Klein, Klein B E, Moss S E, Cruickshanks K J. The Wisconsin Epidemiologic Study of Diabetic Retinopathy: XVII. The 14-year incidence and progression of diabetic retinopathy and associated risk factors in type 1 diabetes. Ophthalmology. 1998;105(10):1801-15. [2108]. [pmid: 9787347].
Klein, Klein B E, Moss S E, Cruickshanks K J, Brazy P C. The 10-year incidence of renal insufficiency in people with type 1 diabetes. Diabetes Care. 1999;22(5):743-51. [387]. [pmid: 10332675].
Klein, Klein B E, Moss S E, Davis M D, DeMets D L. Glycosylated hemoglobin predicts the incidence and progression of diabetic retinopathy. JAMA. 1988;260(19):2864-71. [2832]. [pmid: 3184351].
Klein, Moss S E, Klein B E. Change in glycemia in a four-year interval in younger-onset insulin-dependent diabetes. Ann Epidemiol. 1992;2(3):283-94. [1194]. [pmid: 1342279].
Klein, Moss S E, Klein B E, Davis M D, DeMets D L. The Wisconsin epidemiologic study of diabetic retinopathy. XI. The incidence of macular edema. Ophthalmology. 1989;96(10):1501-10. [2787]. [pmid: 2587045].
Klein, Palta M, Allen C, Shen G, Han D P, D'Alessio D J. Incidence of retinopathy and associated risk factors from time of diagnosis of insulin-dependent diabetes. Arch Ophthalmol. 1997;115(3):351-6. [2270]. [pmid: 9076207].
Knuiman, Welborn T A, Whittall D E. An analysis of excess mortality rates for persons with non-insulin-dependent diabetes mellitus in Western Australia using the Cox proportional hazards regression model. Am J Epidemiol. 1992;135(6):638-48. [1207]. [pmid: 1580240].
Kordonouri, Hartmann R, Muller C, Danne T, Weber B. Predictive value of tubular markers for the development of microalbuminuria in adolescents with diabetes. Horm Res. 1998;50(Suppl 1):23-7. [498]. [pmid: 9676993].
Kovacs, Mukerji P, Drash A, Iyengar S. Biomedical and psychiatric risk factors for retinopathy among children with IDDM. Diabetes Care. 1995;18(12):1592-9. [2372]. [pmid: 8722057].
Krolewski, Laffel L M, Krolewski M, Quinn M, Warram J H. Glycosylated hemoglobin and the risk of microalbuminuria in patients with insulin-dependent diabetes mellitus. N Engl J Med. 1995;332(19):1251-5. [882]. [pmid: 7708068].
Krolewski, Warram J H, Christlieb A R, Busick E J, Kahn C R. The changing natural history of nephropathy in type I diabetes. Am J Med. 1985;78(5):785-94. [1610]. [pmid: 3993659].
Krolewski, Warram J H, Rand L I, Christlieb A R, Busick E J, Kahn C R. Risk of proliferative diabetic retinopathy in juvenile-onset type I diabetes: a 40-yr follow-up study. Diabetes Care. 1986;9(5):443-52. [1570]. [pmid: 3769714].
Krolewski, Eggers P W, Warram J H. Magnitude of end-stage renal disease in IDDM: a 35 year follow-up study. Kidney Int. 1996;50(6):2041-6. [701]. [pmid: 8943488].
Kullberg, Arnqvist H J. Elevated long-term glycated haemoglobin precedes proliferative retinopathy and nephropathy in type 1 (insulin-dependent) diabetic patients. Diabetologia. 1993;36(10):961-5. [1040]. [pmid: 8243877].
Kullberg, Arnqvist H J. Glycemic control in patients with type I diabetes and normoalbuminuria after long diabetes duration. J Diabetes Complications. 1997;11(3):151-7. [640]. [pmid: 9174895].
Kullberg, Arnqvist H J. Good blood glucose control characterizes patients without retinopathy after long diabetes duration. Diabet Med. 1995;12(4):314-20. [2423]. [pmid: 7600746].
Kullberg, Arnqvist H J. Impaired vibration perception threshold and long-term mean HbA1c in patients with type 1 diabetes mellitus. Diabet Med. 1996;13(12):1027-32. [694]. [pmid: 8973883].
Kullberg, Finnstrom K, Arnqvist H J. Severity of background retinopathy in type 1 diabetes increases with the level of long-term glycated haemoglobin. Acta Ophthalmol (Copenh). 1994;72(2):181-8. [2489]. [pmcid: 358319]. [pmid: 8079623].
Kuusisto, Mykkanen L, Pyorala K, Laakso M. NIDDM and its metabolic control predict coronary heart disease in elderly subjects. Diabetes. 1994;43(8):960-7. [4349]. [pmid: 8039603].
Kuusisto, Mykkanen L, Pyorala K, Laakso M. Non-insulin-dependent diabetes and its metabolic control are important predictors of stroke in elderly subjects. Stroke. 1994;25(6):1157-64. [4356]. [pmid: 8202973].
Laakso. Glycemic control and the risk for coronary heart disease in patients with non-insulin-dependent diabetes mellitus. The Finnish studies. Ann Intern Med. 1996;124(1 Pt 2):127-30. [4311]. [pmid: 8554204].
Lee, Robinson M, Wong N, Chan E, Charles M A. The effect of pentoxifylline on current perception thresholds in patients with diabetic sensory neuropathy. J Diabetes Complications. 1997;11(5):274-8. [3421]. [pmid: 9334909].
Lehto, Ronnemaa T, Haffner S M, Pyorala K, Kallio V, Laakso M. Dyslipidemia and hyperglycemia predict coronary heart disease events in middle-aged patients with NIDDM. Diabetes. 1997;46(8):1354-9. [4240]. [pmid: 9231662].
Lehto, Ronnemaa T, Pyorala K, Laakso M. Poor glycemic control predicts coronary heart disease events in patients with type 1 diabetes without nephropathy. Arterioscler Thromb Vasc Biol. 1999;19(4):1014-9. [397]. [pmid: 10195930].
Lehto, Ronnemaa T, Pyorala K, Laakso M. Predictors of stroke in middle-aged patients with non-insulin-dependent diabetes. Stroke. 1996;27(1):63-8. [4313]. [pmid: 8553405].
Lehto, Ronnemaa T, Pyorala K, Laakso M. Risk factors predicting lower extremity amputations in patients with NIDDM. Diabetes Care. 1996;19(6):607-12. [2330]. [pmid: 8725860].
Levin, Coburn J W, Abraira C, Henderson W G, Colwell J A, Emanuele N V, Nuttall F Q, Sawin C T, Comstock J P, Silbert C K. Effect of intensive glycemic control on microalbuminuria in type 2 diabetes. Veterans Affairs Cooperative Study on Glycemic Control and Complications in Type 2 Diabetes Feasibility Trial Investigators. Diabetes Care. 2000;23(10):1478-85. [195]. [pmid: 11023140].
Litzelman, Marriott D J, Vinicor F. Independent physiological predictors of foot lesions in patients with NIDDM. Diabetes Care. 1997;20(8):1273-8. [3427]. [pmid: 9250453].
Liu, Pettitt D J, Hanson R L, Charles M A, Klein R, Bennett P H, Knowler W C. Glycated haemoglobin, plasma glucose and diabetic retinopathy: cross-sectional and prospective analyses. Diabetologia. 1993;36(5):428-32. [2558]. [pmid: 8314447].
Lloyd, Becker D, Ellis D, Orchard T J. Incidence of complications in insulin-dependent diabetes mellitus: a survival analysis. Am J Epidemiol. 1996;143(5):431-41. [777]. [pmid: 8610658].
Lloyd, Klein R, Maser R E, Kuller L H, Becker D J, Orchard T J. The progression of retinopathy over 2 years: the Pittsburgh Epidemiology of Diabetes Complications (EDC) Study. J Diabetes Complications. 1995;9(3):140-8. [870]. [pmid: 7548977].
Lovestam-Adrian, Agardh C D, Torffvit O, Agardh E. Diabetic retinopathy, visual acuity, and medical risk indicators: a continuous 10-year follow-up study in Type 1 diabetic patients under routine care. J Diabetes Complications. 2001;15(6):287-94. [29]. [pmid: 11711321].
Lowe, Liu K, Greenland P, Metzger B E, Dyer A R, Stamler J. Diabetes, asymptomatic hyperglycemia, and 22-year mortality in black and white men. The Chicago Heart Association Detection Project in Industry Study. Diabetes Care. 1997;20(2):163-9. [4267]. [pmid: 9118765].
Lozano, Llisterri J L, Aznar J, Redon J. Losartan reduces microalbuminuria in hypertensive microalbuminuric type 2 diabetics. Nephrol Dial Transplant. 2001;16(Suppl 1):85-9. [92]. [pmid: 11369830].
Madsbad, Kilhovd B, Lager I, Mustajoki P, Dejgaard A. Comparison between repaglinide and glipizide in Type 2 diabetes mellitus: a 1-year multicentre study. Diabet Med. 2001;18(5):395-401. [71]. [pmid: 11472451].
Makimattila, Schlenzka A, Mantysaari M, Bergholm R, Summanen P, Saar P, Erkkila H, Yki-Jarvinen H. Predictors of abnormal cardiovascular autonomic function measured by frequence domain analysis of heart rate variability and conventional tests in patients with type 1 diabetes. Diabetes Care. 2000;23(11):1686-93. [184]. [pmid: 11092293].
Malone, Grizzard S, Espinoza L R, Achenbach K E, Van Cader T C. Risk factors for diabetic retinopathy in youth. Pediatrics. 1984;73(6):756-61. [3011]. [pmid: 6610167].
Marshall, Garg S K, Jackson W E, Holmes D L, Chase H P. Factors influencing the onset and progression of diabetic retinopathy in subjects with insulin-dependent diabetes mellitus. Ophthalmology. 1993;100(8):1133-9. [2537]. [pmid: 8341492].
Mathiesen, Ronn B, Jensen T, Storm B, Deckert T. Relationship between blood pressure and urinary albumin excretion in development of microalbuminuria. Diabetes. 1990;39(2):245-9. [1383]. [pmid: 2227133].
Mattock, Morrish N J, Viberti G, Keen H, Fitzgerald A P, Jackson G. Prospective study of microalbuminuria as predictor of mortality in NIDDM. Diabetes. 1992;41(6):736-41. [1182]. [pmid: 1587400].
McCance, Atkinson A B, Hadden D R, Kennedy L. Long-term glycemic control and neurological function in IDDM patients. Diabetes Care. 1993;16(9):1291-3. [1054]. [pmid: 8404434].
McCance, Hadden D R, Atkinson A B, Johnston H, Kennedy L. The relationship between long-term glycaemic control and diabetic nephropathy. Q J Med. 1992;82(297):53-61. [1229]. [pmid: 1438668].
Molyneaux, Constantino M I, McGill M, Zilkens R, Yue D K. Better glycaemic control and risk reduction of diabetic complications in Type 2 diabetes: comparison with the DCCT. Diabetes Res Clin Pract. 1998;42(2):77-83. [424]. [pmid: 9886743].
Monson, Koios G, Toms G C, Kopelman P G, Boucher B J, Evans S J, Alexander W L. Relationship between retinopathy and glycaemic control in insulin-dependent and non-insulin-dependent diabetes. J R Soc Med. 1986;79(5):274-6. [2939]. [pmid: 3723520]. [pmcid: 1290311].
Morisaki, Watanabe S, Kobayashi J, Kanzaki T, Takahashi K, Yokote K, Tezuka M, Tashiro J, Inadera H, Saito Y, et al. Diabetic control and progression of retinopathy in elderly patients: five-year follow-up study. J Am Geriatr Soc. 1994;42(2):142-5. [2502]. [pmid: 8126325].
Moss, Klein R, Klein B E. The 14-year incidence of lower-extremity amputations in a diabetic population. The Wisconsin Epidemiologic Study of Diabetic Retinopathy. Diabetes Care. 1999;22(6):951-9. [2047]. [pmid: 10372248].
Moss, Klein R, Klein B E. The 14-year incidence of visual loss in a diabetic population. Ophthalmology. 1998;105(6):998-1003. [2145]. [pmid: 9627648].
Moss, Klein R, Klein B E. The incidence of vision loss in a diabetic population. Ophthalmology. 1988;95(10):1340-8. [2835]. [pmid: 3265775].
Moss, Klein R, Klein B E. Long-term incidence of lower-extremity amputations in a diabetic population. Arch Fam Med. 1996;5(7):391-8. [2326]. [pmid: 8664997].
Moss, Klein R, Klein B E. The prevalence and incidence of lower extremity amputation in a diabetic population. Arch Intern Med. 1992;152(3):610-6. [2636]. [pmid: 1546925].
Moss, Klein R, Klein B E. Ten-year incidence of visual loss in a diabetic population. Ophthalmology. 1994;101(6):1061-70. [2482]. [pmid: 8008348].
Moss, Klein R, Klein B E, Meuer S M. The association of glycemia and cause-specific mortality in a diabetic population. Arch Intern Med. 1994;154(21):2473-9. [4338]. [pmid: 7979844].
Muhlhauser, Overmann H, Bender R, Jorgens V, Berger M. Predictors of mortality and end-stage diabetic complications in patients with Type 1 diabetes mellitus on intensified insulin therapy. Diabet Med. 2000;17(10):727-34. [178]. [pmid: 11110506].
Muhlhauser, Sawicki P T, Blank M, Overmann H, Bender R, Berger M. Prognosis of persons with type 1 diabetes on intensified insulin therapy in relation to nephropathy. J Intern Med. 2000;248(4):333-41. [185]. [pmid: 11086645].
Mulec, Blohme G, Grande B, Bjorck S. The effect of metabolic control on rate of decline in renal function in insulin-dependent diabetes mellitus with overt diabetic nephropathy. Nephrol Dial Transplant. 1998;13(3):651-5. [540]. [pmid: 9550642].
Myrup, Mathiesen E R, Ronn B, Deckert T. Endothelial function and serum lipids in the course of developing microalbuminuria in insulin-dependent diabetes mellitus. Diabetes Res. 1994;26(1):33-9. [1022]. [pmid: 7664535].
Nakagami, Kawahara R, Hori S, Omori Y. Glycemic control and prevention of retinopathy in Japanese NIDDM patients. A 10-year follow-up study. Diabetes Care. 1997;20(4):621-2. [2259]. [pmid: 9096990].
Near-normal urinary albumin concentrations predict progression to diabetic nephropathy in Type 1 diabetes mellitus. Diabet Med . 2000; 17 (11): 782–91. [165].
Nelson, Gohdes D M, Everhart J E, Hartner J A, Zwemer F L, Pettitt D J, Knowler W C. Lower-extremity amputations in NIDDM. 12-yr follow-up study in Pima Indians. Diabetes Care. 1988;11(1):8-16. [1501]. [pmid: 3338381].
Nelson, Knowler W C, Pettitt D J, Hanson R L, Bennett P H. Incidence and determinants of elevated urinary albumin excretion in Pima Indians with NIDDM. Diabetes Care. 1995;18(2):182-7. [911]. [pmid: 7729295].
Newman, Hollevoet J J, Frohlich K L. The diabetes project at Fort Totten, North Dakota, 1984-1988. Diabetes Care. 1993;16(1):361-3. [1124]. [pmid: 8422811].
Nichols, Hillier T A, Erbey J R, Brown J B. Congestive heart failure in type 2 diabetes: prevalence, incidence, and risk factors. Diabetes Care. 2001;24(9):1614-9. [4025]. [pmid: 11522708].
Niskanen, Turpeinen A, Penttila I, Uusitupa M I. Hyperglycemia and compositional lipoprotein abnormalities as predictors of cardiovascular mortality in type 2 diabetes: a 15-year follow-up from the time of diagnosis. Diabetes Care. 1998;21(11):1861-9. [457]. [pmid: 9802734].
Niskanen, Voutilainen R, Terasvirta M, Lehtinen J, Teppo A M, Groop L, Uusitupa M. A prospective study of clinical and metabolic associates of proteinuria in patients with type 2 diabetes mellitus. Diabet Med. 1993;10(6):543-9. [1071]. [pmid: 8365091].
Niskanen, Penttila I, Parviainen M, Uusitupa M I. Evolution, risk factors, and prognostic implications of albuminuria in NIDDM. Diabetes Care. 1996;19(5):486-93. [749]. [pmid: 8732714].
Nosadini, Velussi M, Brocco E, Bruseghin M, Abaterusso C, Saller A, Dalla Vestra M, Carraro A, Bortoloso E, Sambataro M, Barzon I, Frigato F, Muollo B, Chiesura-Corona M, Pacini G, Baggio B, Piarulli F, Sfriso A, Fioretto P. Course of renal function in type 2 diabetic patients with abnormalities of albumin excretion rate. Diabetes. 2000;49(3):476-84. [245]. [pmid: 10868971].
Ohkubo, Kishikawa H, Araki E, Miyata T, Isami S, Motoyoshi S, Kojima Y, Furuyoshi N, Shichiri M. Intensive insulin therapy prevents the progression of diabetic microvascular complications in Japanese patients with non-insulin-dependent diabetes mellitus: a randomized prospective 6-year study. Diabetes Res Clin Pract. 1995;28(2):103-17. [888]. [pmid: 7587918].
Okada, Ichiki K, Hamada H, Matsuo N, Ota Z. Estimated urinary albumin index: a predictor of microalbuminuria in type 2 diabetes. J Int Med Res. 1996;24(1):47-58. [807]. [pmid: 8674800].
Okudaira, Yokoyama H, Otani T, Uchigata Y, Iwamoto Y. Slightly elevated blood pressure as well as poor metabolic control are risk factors for the progression of retinopathy in early-onset Japanese Type 2 diabetes. J Diabetes Complications. 2000;14(5):281-7. [1899]. [pmid: 11113692].
Olsen, Johannesen J, Sjolie A K, Borch-Johnsen K, Hougarrdss P, Thorsteinsson B, Prammingss S, Marinelli K, Mortensen H B. Metabolic control and prevalence of microvascular complications in young Danish patients with Type 1 diabetes mellitus. Danish Study Group of Diabetes in Childhood. Diabet Med. 1999;16(1):79-85. [2065]. [pmid: 10229298].
Olsen, Sjolie A, Hougaard P, Johannesen J, Borch-Johnsen K, Marinelli K, Thorsteinsson B, Pramming S, Mortensen H B. A 6-year nationwide cohort study of glycaemic control in young people with type 1 diabetes. Risk markers for the development of retinopathy, nephropathy and neuropathy. Danish Study Group of Diabetes in Childhood. J Diabetes Complications. 2000;14(6):295-300. [173]. [pmid: 11120452].
Olson, Erbey J R, Forrest K Y, Williams K, Becker D J, Orchard T J. Glycemia (or, in women, estimated glucose disposal rate) predict lower extremity arterial disease events in type 1 diabetes. Metabolism. 2002;51(2):248-54. [7]. [pmid: 11833057].
Orchard, Forrest K Y, Ellis D, Becker D J. Cumulative glycemic exposure and microvascular complications in insulin-dependent diabetes mellitus. The glycemic threshold revisited. Arch Intern Med. 1997;157(16):1851-6. [606]. [pmid: 9290544].
Orchard, LLoyd C E, Maser R E, Kuller L H. Why does diabetic autonomic neuropathy predict IDDM mortality? An analysis from the Pittsburgh Epidemiology of Diabetes Complications Study. Diabetes Res Clin Pract. 1996;34(Suppl):S165-71. [710]. [pmid: 9015687].
Oue, Namba M, Nakajima H, Ono A, Horikawa Y, Yamamoto K, Hamaguchi T, Fujino-Kurihara H, Yamasaki T, Tomita K, Miyagawa J, Hanafusa T, Matsuzawa Y. Risk factors for the progression of microalbuminuria in Japanese type 2 diabetic patients--a 10 year follow-up study. Diabetes Res Clin Pract. 1999;46(1):47-55. [315]. [pmid: 10580616].
Park, Kim H K, Chung Y E, Kim S W, Hong S K, Lee K U. Incidence and determinants of microalbuminuria in Koreans with type 2 diabetes. Diabetes Care. 1998;21(4):530-4. [534]. [pmid: 9571337].
Park, Barrett-Connor E, Wingard D L, Shan J, Edelstein S. GHb is a better predictor of cardiovascular disease than fasting or postchallenge plasma glucose in women without diabetes. The Rancho Bernardo Study. Diabetes Care. 1996;19(5):450-6. [4292]. [pmid: 8732708].
Partanen, Niskanen L, Lehtinen J, Mervaala E, Siitonen O, Uusitupa M. Natural history of peripheral neuropathy in patients with non-insulin-dependent diabetes mellitus. N Engl J Med. 1995;333(2):89-94. [3556]. [pmid: 7777034].
Patrick, Leslie P J, Clarke B F, Frier B M. The natural history and associations of microalbuminuria in type 2 diabetes during the first year after diagnosis. Diabet Med. 1990;7(10):902-8. [1327]. [pmid: 2149687].
Pettitt, Knowler W C, Lisse J R, Bennett P H. Development of retinopathy and proteinuria in relation to plasma-glucose concentrations in Pima Indians. Lancet. 1980;2(8203):1050-2. [3101]. [pmid: 6107679].
Porta, Sjoelie A K, Chaturvedi N, Stevens L, Rottiers R, Veglio M, Fuller J H. Risk factors for progression to proliferative diabetic retinopathy in the EURODIAB Prospective Complications Study. Diabetologia. 2001;44(12):2203-9. [1769]. [pmid: 11793022].
Powrie, Watts G F, Ingham J N, Taub N A, Talmud P J, Shaw K M. Role of glycaemic control in development of microalbuminuria in patients with insulin dependent diabetes. BMJ. 1994;309(6969):1608-12. [929]. [pmid: 7819935].
Predictors of the development of microalbuminuria in patients with Type 1 diabetes mellitus: a seven-year prospective study. The Microalbuminuria Collaborative Study Group. Diabet Med 1999; 16(11): 918–25. [310].
Raal, Kalk W J, Taylor D R, Osler C E, Panz V R. The relationship between the development and progression of microalbuminuria and arterial blood pressure in type 1 (insulin-dependent) diabetes mellitus. Diabetes Res Clin Pract. 1992;16(3):221-7. [1185]. [pmid: 1425143].
Ramani, Kundaje G N. Aetiology of diabetic foot ulceration. J Assoc Physicians India. 1990;38(11):843-5. [3751]. [pmid: 2079469].
Rasmidatta, Khunsuk-Mengrai K, Warunyuwong C. Risk factors of diabetic retinopathy in non-insulin dependent diabetes mellitus. J Med Assoc Thai. 1998;81(3):169-74. [2147]. [pmid: 9623007].
Ravid, Brosh D, Ravid-Safran D, Levy Z, Rachmani R. Main risk factors for nephropathy in type 2 diabetes mellitus are plasma cholesterol levels, mean blood pressure, and hyperglycemia. Arch Intern Med. 1998;158(9):998-1004. [531]. [pmid: 9588433].
Ravid, Savin H, Jutrin I, Bental T, Katz B, Lishner M. Long-term stabilizing effect of angiotensin-converting enzyme inhibition on plasma creatinine and on proteinuria in normotensive type II diabetic patients. Ann Intern Med. 1993;118(8):577-81. [1092]. [pmid: 8452322].
Reichard. Are there any glycemic thresholds for the serious microvascular diabetic complications?. J Diabetes Complications. 1995;9(1):25-30. [921]. [pmid: 7734740].
Reichard. Risk factors for progression of microvascular complications in the Stockholm Diabetes Intervention Study (SDIS). Diabetes Res Clin Pract. 1992;16(2):151-6. [1188]. [pmid: 1600854].
Reichard, Berglund B, Britz A, Cars I, Nilsson B Y, Rosenqvist U. Intensified conventional insulin treatment retards the microvascular complications of insulin-dependent diabetes mellitus (IDDM): the Stockholm Diabetes Intervention Study (SDIS) after 5 years. J Intern Med. 1991;230(2):101-8. [1266]. [pmid: 1865159].
Reichard, Britz A, Carlsson P, Cars I, Lindblad L, Nilsson B Y, Rosenqvist U. Metabolic control and complications over 3 years in patients with insulin dependent diabetes (IDDM): the Stockholm Diabetes Intervention Study (SDIS). J Intern Med. 1990;228(5):511-7. [1333]. [pmid: 2254723].
Reichard, Britz A, Cars I, Nilsson B Y, Sobocinsky-Olsson B, Rosenqvist U. The Stockholm Diabetes Intervention Study (SDIS): 18 months' results. Acta Med Scand. 1988;224(2):115-22. [1509]. [pmid: 3048052].
Reichard, Jensen-Urstad K, Ericsson M, Jensen-Urstad M, Lindblad L E. Autonomic neuropathy--a complication less pronounced in patients with Type 1 diabetes mellitus who have lower blood glucose levels. Diabet Med. 2000;17(12):860-6. [3209]. [pmid: 11168329].
Reichard, Nilsson B Y, Rosenqvist U. The effect of long-term intensified insulin treatment on the development of microvascular complications of diabetes mellitus. N Engl J Med. 1993;329(5):304-9. [1069]. [pmid: 8147960].
Reichard, Pihl M. Mortality and treatment side-effects during long-term intensified conventional insulin treatment in the Stockholm Diabetes Intervention Study. Diabetes. 1994;43(2):313-7. [1007]. [pmid: 8288056].
Reichard, Pihl M, Rosenqvist U, Sule J. Complications in IDDM are caused by elevated blood glucose level: the Stockholm Diabetes Intervention Study (SDIS) at 10-year follow up. Diabetologia. 1996;39(12):1483-8. [699]. [pmid: 8960830].
Reichard, Rosenqvist U. Nephropathy is delayed by intensified insulin treatment in patients with insulin-dependent diabetes mellitus and retinopathy. J Intern Med. 1989;226(2):81-7. [1421]. [pmid: 2671247].
The relationship of glycemic exposure (HbA1c) to the risk of development and progression of retinopathy in the diabetes control and complications trial. Diabetes . 1995; 44 (8): 968–83. [852].
Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group. N Engl J Med 2000; 342 (6): 381–9. [292].
Risk factors for development of microalbuminuria in insulin dependent diabetic patients: a cohort study Microalbuminuria Collaborative Study Group, United Kingdom. BMJ 1993; 306 (6887): 1235–9. [1085].
Romero, Salinas I, Lucas A, Abad E, Reverter J L, Johnston S, Sanmarti A. Renal function changes in microalbuminuric normotensive type II diabetic patients treated with angiotensin-converting enzyme inhibitors. Diabetes Care. 1993;16(4):597-600. [1095]. [pmid: 8462386].
Romero, Salinas I, Lucas A, Teixido J, Audi L, Sanmarti A. Comparative effects of captopril versus nifedipine on proteinuria and renal function of type 2 diabetic patients. Diabetes Res Clin Pract. 1992;17(3):191-8. [1159]. [pmid: 1425158].
Rosenstock, Friberg T, Raskin P. Effect of glycemic control on microvascular complications in patients with type I diabetes mellitus. Am J Med. 1986;81(6):1012-8. [2919]. [pmid: 3541587].
Rossing, Hougaard P, Borch-Johnsen K, Parving H H. Predictors of mortality in insulin dependent diabetes: 10 year observational follow up study. BMJ. 1996;313(7060):779-84. [719]. [pmid: 8842069].
Rudberg, Dahlquist G. Determinants of progression of microalbuminuria in adolescents with IDDM. Diabetes Care. 1996;19(4):369-71. [758]. [pmid: 8729162].
Rudberg, Persson B, Dahlquist G. Increased glomerular filtration rate as a predictor of diabetic nephropathy--an 8-year prospective study. Kidney Int. 1992;41(4):822-8. [1204]. [pmid: 1513104].
Rudberg, Ullman E, Dahlquist G. Relationship between early metabolic control and the development of microalbuminuria--a longitudinal study in children with type 1 (insulin-dependent) diabetes mellitus. Diabetologia. 1993;36(12):1309-14. [1023]. [pmid: 8307261].
Salardi, Rubbi F, Puglioli R, Brancaleoni A, Bacchi-Reggiani L, Ragni L, Cacciari E. Diabetic retinopathy in childhood: long-term follow-up by fluorescein angiography beginning in the first months of disease. J Pediatr Endocrinol Metab. 2001;14(5):507-15. [1838]. [pmid: 11393571].
Sands, Shetterly S M, Franklin G M, Hamman R F. Incidence of distal symmetric (sensory) neuropathy in NIDDM. The San Luis Valley Diabetes Study. Diabetes Care. 1997;20(3):322-9. [2275]. [pmid: 9051381].
Sato, Lee Z, Hayashi Y. Subclassification of preproliferative diabetic retinopathy and glycemic control: relationship between mean hemoglobin A1C value and development of proliferative diabetic retinopathy. Jpn J Ophthalmol. 2001;45(5):523-7. [1804]. [pmid: 11583677].
Sawicki, Bender R, Berger M, Muhlhauser I. Non-linear effects of blood pressure and glycosylated haemoglobin on progression of diabetic nephropathy. J Intern Med. 2000;247(1):131-8. [289]. [pmid: 10672141].
Sawicki, Didjurgeit U, Muhlhauser I, Bender R, Heinemann L, Berger M. Smoking is associated with progression of diabetic nephropathy. Diabetes Care. 1994;17(2):126-31. [1008]. [pmid: 8137682].
Schmitz, Vaeth M, Mogensen C E. Systolic blood pressure relates to the rate of progression of albuminuria in NIDDM. Diabetologia. 1994;37(12):1251-8. [932]. [pmid: 7895955].
Schultz, Konopelska-Bahu T, Dalton R N, Carroll T A, Stratton I, Gale E A, Neil A, Dunger D B. Microalbuminuria prevalence varies with age, sex, and puberty in children with type 1 diabetes followed from diagnosis in a longitudinal study. Oxford Regional Prospective Study Group. Diabetes Care. 1999;22(3):495-502. [405]. [pmid: 10097935].
Schultz, Neil H A, Dalton R N, Dunger D B. Risk of nephropathy can be detected before the onset of microalbuminuria during the early years after diagnosis of type 1 diabetes. Diabetes Care. 2000;23(12):1811-5. [169]. [pmid: 11128358].
Schultz, Neil H A, Dalton R N, Konopelska-Bahu T, Dunger D B. Blood pressure does not rise before the onset of microalbuminuria in children followed from diagnosis of type 1 diabetes. Oxford Regional Prospective Study Group. Diabetes Care. 2001;24(3):555-60. [117]. [pmid: 11289484].
Scott, Warram J H, Hanna L S, Laffel L M, Ryan L, Krolewski A S. A nonlinear effect of hyperglycemia and current cigarette smoking are major determinants of the onset of microalbuminuria in type 1 diabetes. Diabetes. 2001;50(12):2842-9. [25]. [pmid: 11723069].
Shichiri, Kishikawa H, Ohkubo Y, Wake N. Long-term results of the Kumamoto Study on optimal diabetes control in type 2 diabetic patients. Diabetes Care. 2000;23(Suppl 2):B21-9. [247]. [pmid: 10860187].
Simons, McCallum J, Friedlander Y, Simons J. Diabetes, mortality and coronary heart disease in the prospective Dubbo study of Australian elderly. Aust N Z J Med. 1996;26(1):66-74. [4303]. [pmid: 8775531].
Smulders, Rakic M, Stehouwer C D, Weijers R N, Slaats E H, Silberbusch J. Determinants of progression of microalbuminuria in patients with NIDDM.A prospective study. Diabetes Care. 1997;20(6):999-1005. [634]. [pmid: 9167114].
Solders, Thalme B, Aguirre-Aquino M, Brandt L, Berg U, Persson A. Nerve conduction and autonomic nerve function in diabetic children. A 10-year follow-up study. Acta Paediatr. 1997;86(4):361-6. [652]. [pmid: 9174220].
Song, Yoon K H, Kang M L, Cha B Y, Lee K W, Son H Y, Kang S K. Progression to overt proteinuria in microalbuminuric Koreans with non-insulin-dependent diabetes mellitus. Diabetes Res Clin Pract. 1998;42(2):117-21. [423]. [pmid: 9886748].
Sosenko, Kato M, Soto R, Bild D E. A prospective study of sensory function in patients with type 2 diabetes. Diabet Med. 1993;10(2):110-4. [3654]. [pmid: 8458186].
Spallone, Maiello M R, Cicconetti E, Menzinger G. Autonomic neuropathy and cardiovascular risk factors in insulin-dependent and non insulin-dependent diabetes. Diabetes Res Clin Pract. 1997;34(3):169-79. [682]. [pmid: 9069569].
Standl, Balletshofer B, Dahl B, Weichenhain B, Stiegler H, Hormann A, Holle R. Predictors of 10-year macrovascular and overall mortality in patients with NIDDM: the Munich General Practitioner Project. Diabetologia. 1996;39(12):1540-5. [4276]. [pmid: 8960840].
Stella, Ellis D, Maser R E, Orchard T J. Cardiovascular autonomic neuropathy (expiration and inspiration ratio) in type 1 diabetes. Incidence and predictors. J Diabetes Complications. 2000;14(1):1-6. [224]. [pmid: 10925059].
Stratton, Adler A I, Neil H A, Matthews D R, Manley S E, Cull C A, Hadden D, Turner R C, Holman R R. Association of glycaemia with macrovascular and microvascular complications of type 2 diabetes (UKPDS 35): prospective observational study. BMJ. 2000;321(7258):405-12. [4087]. [pmcid: 27454]. [pmid: 10938048].
Stratton, Kohner E M, Aldington S J, Turner R C, Holman R R, Manley S E, Matthews D R. UKPDS 50: risk factors for incidence and progression of retinopathy in Type II diabetes over 6 years from diagnosis. Diabetologia. 2001;44(2):156-63. [1863]. [pmid: 11270671].
Tai, Chuang L M, Tseng C H, Wu H P, Chen M S, Lin B J. Microalbuminuria and diabetic complications in Chinese non-insulin-dependent diabetic patients: a prospective study. Diabetes Res Clin Pract. 1990;9(1):59-63. [1365]. [pmid: 2351042].
Tarnow, Kjeld T, Knudsen E, Major-Pedersen A, Parving H H. Lack of synergism between long-term poor glycaemic control and three gene polymorphisms of the renin angiotensin system on risk of developing diabetic nephropathy in type I diabetic patients. Diabetologia. 2000;43(6):794-9. [229]. [pmid: 10907125].
Testa, Puklin J E, Sherwin R S, Simonson D C. Clinical predictors of retinopathy and its progression in patients with type I diabetes during CSII or conventional insulin treatment. Diabetes. 1985;34(Suppl 3):61-8. [2973]. [pmid: 3894129].
Torffvit, Agardh C D. The impact of metabolic and blood pressure control on incidence and progression of nephropathy. A 10-year study of 385 type 2 diabetic patients. J Diabetes Complications. 2001;15(6):307-13. [28]. [pmid: 11711324].
Torffvit, Agardh C D. The predictive value of albuminuria for cardiovascular and renal disease. A 5-year follow-up study of 476 patients with type I diabetes mellitus. J Diabetes Complications. 1993;7(1):49-56. [1113]. [pmid: 8481551].
Toyry, Niskanen L K, Mantysaari M J, Lansimies E A, Uusitupa M I. Occurrence, predictors, and clinical significance of autonomic neuropathy in NIDDM. Ten-year follow-up from the diagnosis. Diabetes. 1996;45(3):308-15. [3527]. [pmid: 8593935].
Tudor, Hamman R F, Baron A, Johnson D W, Shetterly S M. Incidence and progression of diabetic retinopathy in Hispanics and non-Hispanic whites with type 2 diabetes. San Luis Valley Diabetes Study, Colorado. Diabetes Care. 1998;21(1):53-61. [2173]. [pmid: 9538971].
Turner, Millns H, Neil H A, Stratton I M, Manley S E, Matthews D R, Holman R R. Risk factors for coronary artery disease in non-insulin dependent diabetes mellitus: United Kingdom Prospective Diabetes Study (UKPDS: 23). BMJ. 1998;316(7134):823-8. [4217]. [pmcid: 28484]. [pmid: 9549452].
Twyman, Rowe D, Mansell P, Schapira D, Betts P, Leatherdale B. Longitudinal study of urinary albumin excretion in young diabetic patients--Wessex Diabetic Nephropathy Project. Diabet Med. 2001;18(5):402-8. [70]. [pmid: 11472452].
UK Prospective Diabetes Study (UKPDS). IX: Relationships of urinary albumin and N-acetylglucosaminidase to glycaemia and hypertension at diagnosis of type 2 (non-insulin-dependent) diabetes mellitus and after 3 months diet therapy. Diabetologia. 1993;36(9):835-42. [1052]. [pmid: 8405755].
UK Prospective Diabetes Study (UKPDS). X. Urinary albumin excretion over 3 years in diet-treated type 2, (non-insulin-dependent) diabetic patients, and association with hypertension, hyperglycaemia and hypertriglyceridaemia. Diabetologia. 1993;36(10):1021-9. [1046]. [pmid: 8243850].
United Kingdom Prospective Diabetes Study 24: a 6-year randomized, controlled trial comparing sulfonylurea, insulin, and metformin therapy in patients with newly diagnosed type 2 diabetes that could not be controlled with diet therapy. United Kingdom Prospective Diabetes Study Group. Ann Intern Med 1998; 128 (3): 165–75. [2192].
Van Wersch, Westerhuis L W, Venekamp W J. HbA1C and serum fructosamine in diabetic patients: relationship to age, clotting and fibrinolysis parameters and urinary microalbumin excretion. Clin Chim Acta. 1991;201(12):99-104. [1250]. [pmid: 1790631].
Veelken, Delles C, Hilgers K F, Schmieder R E. Outcome survey in unselected hypertensive patients with type 2 diabetes mellitus: effects of ACE inhibition. Am J Hypertens. 2001;14(7 Pt 1):672-8. [73]. [pmid: 11465652].
Verrotti, Chiarelli F, Morgese G. Autonomic dysfunction in newly diagnosed insulin-dependent diabetes mellitus children. Pediatr Neurol. 1996;14(1):49-52. [3537]. [pmid: 8652016].
Villar, Garcia Y, Goicolea I, Vazquez J A. Determinants of development of microalbuminuria in normotensive patients with type 1 and type 2 diabetes. Diabetes Metab. 1999;25(3):246-54. [325]. [pmid: 10499194].
Viswanathan, Snehalatha C, Ramachandran A, Viswanathan M. Proteinuria in NIDDM in south India: analysis of predictive factors. Diabetes Res Clin Pract. 1995;28(1):41-6. [897]. [pmid: 7587911].
Vitale, Maguire M G, Murphy R P, Hiner C, Rourke L, Sackett C, Patz A. Interval between onset of mild nonproliferative and proliferative retinopathy in type I diabetes. Arch Ophthalmol. 1997;115(2):194-8. [2282]. [pmid: 9046254].
Vitale, Maguire M G, Murphy R P, Hiner C J, Rourke L, Sackett C, Patz A. Clinically significant macular edema in type I diabetes. Incidence and risk factors. Ophthalmology. 1995;102(8):1170-6. [2391]. [pmid: 9097743].
Vora, Dolben J, Williams J D, Peters J R, Owens D R. Impact of initial treatment on renal function in newly-diagnosed type 2 (non-insulin-dependent) diabetes mellitus. Diabetologia. 1993;36(8):734-40. [1059]. [pmid: 8405740].
Voutilainen-Kaunisto, Terasvirta M E, Uusitupa M I, Niskanen L K. Occurrence and predictors of retinopathy and visual acuity in Type 2 diabetic patients and control subjects. 10-year follow-up from the diagnosis. J Diabetes Complications. 2001;15(1):24-33. [1867]. [pmid: 11259923].
Wainai, Katsukawa F, Takei I, Maruyama H, Kataoka K, Saruta T. Influence of glycemic control and hypertension on urinary microprotein excretion in non-insulin-dependent diabetes mellitus. J Diabet Complications. 1991;5(23):160-1. [1297]. [pmid: 1722805].
Waltman. Sequential vitreous fluorophotometry in diabetes mellitus: a five-year prospective study. Trans Am Ophthalmol Soc. 1984;82:827-49. [3029]. [pmid: 6535330]. [pmcid: 1298680].
Wannamethee, Perry I J, Shaper A G. Nonfasting serum glucose and insulin concentrations and the risk of stroke. Stroke. 1999;30(9):1780-6. [4133]. [pmid: 10471423].
Warram, Scott L J, Hanna L S, Wantman M, Cohen S E, Laffel L M, Ryan L, Krolewski A S. Progression of microalbuminuria to proteinuria in type 1 diabetes: nonlinear relationship with hyperglycemia. Diabetes. 2000;49(1):94-100. [304]. [pmid: 10615955].
Watanabe, Sako Y, Umeda F, Nawata H. Effects of cilostazol, a phosphodiesterase inhibitor, on urinary excretion of albumin and prostaglandins in non-insulin-dependent diabetic patients. Diabetes Res Clin Pract. 1993;22(1):53-9. [1050]. [pmid: 8137717].
Watts, Harris R, Shaw K M. The determinants of early nephropathy in insulin-dependent diabetes mellitus: a prospective study based on the urinary excretion of albumin. Q J Med. 1991;79(288):365-78. [1282]. [pmid: 1852860].
Watts, Taub N A, Mazurkiewicz J, Shaw K M. An examination of the covariability of subclinical albuminuria in insulin-dependent diabetes mellitus: implications for monitoring microalbuminuria. Diabetes Res Clin Pract. 1993;21(23):177-85. [1063]. [pmid: 8269820].
Weber, Burger W, Hartmann R, Hovener G, Malchus R, Oberdisse U. Risk factors for the development of retinopathy in children and adolescents with type 1 (insulin-dependent) diabetes mellitus. Diabetologia. 1986;29(1):23-9. [2946]. [pmid: 3956894].
White, Cleary P A, Dahms W, Goldstein D, Malone J, Tamborlane W V. Beneficial effects of intensive therapy of diabetes during adolescence: outcomes after the conclusion of the Diabetes Control and Complications Trial (DCCT). J Pediatr. 2001;139(6):804-12. [19]. [pmid: 11743505].
Wiegmann, Chonko A M, MacDougall M L, Moore W V. The role of disease duration and hypertension in albumin excretion of type I diabetes mellitus. J Am Soc Nephrol. 1992;2(11):1587-92. [1187]. [pmid: 1610979].
Wirta, Pasternack A, Laippala P, Turjanmaa V. Glomerular filtration rate and kidney size after six years disease duration in non-insulin-dependent diabetic subjects. Clin Nephrol. 1996;45(1):10-7. [808]. [pmid: 8616951].
Wirta, Pasternack A I, Mustonen J T, Koivula T A, Harmoinen A. Urinary albumin excretion rate and its determinants after 6 years in non-insulin-dependent diabetic patients. Nephrol Dial Transplant. 1996;11(3):449-56. [775]. [pmid: 8671814].
Wong, Moss S E, Klein R, Klein B E. Is the pulse rate useful in assessing risk of diabetic retinopathy and macular oedema? The Wisconsin Epidemiological Study of Diabetic Retinopathy. Br J Ophthalmol. 2001;85(8):925-7. [1825]. [pmid: 11466246]. [pmcid: 1724060].
Yamasaki, Kodama M, Nishizawa H, Sakamoto K, Matsuhisa M, Kajimoto Y, Kosugi K, Shimizu Y, Kawamori R, Hori M. Carotid intima-media thickness in Japanese type 2 diabetic subjects: predictors of progression and relationship with incident coronary heart disease. Diabetes Care. 2000;23(9):1310-5. [4081]. [pmid: 10977024].
Yarnell, Pickering J E, Elwood P C, Baker I A, Bainton D, Dawkins C, Phillips D I. Does non-diabetic hyperglycemia predict future IHD? Evidence from the Caerphilly and Speedwell studies. J Clin Epidemiol. 1994;47(4):383-8. [4366]. [pmid: 7730863].
Yokoyama, Okudaira M, Otani T, Watanabe C, Takaike H, Miuira J, Yamada H, Mutou K, Satou A, Uchigata Y, Iwamoto Y. High incidence of diabetic nephropathy in early-onset Japanese NIDDM patients. Risk analysis. Diabetes Care. 1998;21(7):1080-5. [503]. [pmid: 9653599].
Yokoyama, Tomonaga O, Hirayama M, Ishii A, Takeda M, Babazono T, Ujihara U, Takahashi C, Omori Y. Predictors of the progression of diabetic nephropathy and the beneficial effect of angiotensin-converting enzyme inhibitors in NIDDM patients. Diabetologia. 1997;40(4):405-11. [653]. [pmid: 9112017].
Yokoyama, Uchigata Y, Otani T, Saeki A, Aoki K, Kasahara T, Omori Y, Borch-Johnsen K. Metabolic regulation and microangiopathy in a cohort of Japanese IDDM-patients. Diabetes Res Clin Pract. 1995;29(3):203-9. [2386]. [pmid: 8591714].
Yoshida, Hagura R, Hara Y, Sugasawa G, Akanuma Y. Risk factors for the development of diabetic retinopathy in Japanese type 2 diabetic patients. Diabetes Res Clin Pract. 2001;51(3):195-203. [1864]. [pmid: 11269892].
Young, Macintyre C C, Martyn C N, Prescott R J, Ewing D J, Smith A F, Viberti G, Clarke B F. Progression of subclinical polyneuropathy in young patients with type 1 (insulin-dependent) diabetes: associations with glycaemic control and microangiopathy (microvascular complications). Diabetologia. 1986;29(3):156-61. [1584]. [pmid: 3699306].
Zander, Herfurth S, Bohl B, Heinke P, Herrmann U, Kohnert K D, Kerner W. Maculopathy in patients with diabetes mellitus type 1 and type 2: associations with risk factors. Br J Ophthalmol. 2000;84(8):871-6. [230]. [pmid: 10906094]. [pmcid: 1723591].
Zhang, Krzentowski G, Albert A, Lefebvre P J. Risk of developing retinopathy in Diabetes Control and Complications Trial type 1 diabetic patients with good or poor metabolic control. Diabetes Care. 2001;24(7):1275-9. [1833]. [pmid: 11423515].
Ziegler, Dannehl K, Wiefels K, Gries F A. Differential effects of near-normoglycaemia for 4 years on somatic nerve dysfunction and heart rate variation in type 1 diabetic patients. Diabet Med. 1992;9(7):622-9. [3676]. [pmid: 1511568].
Ziegler, Wiefels K, Dannehl K, Gries F A. Effects of one year of near-normoglycemia on peripheral nerve function in type 1 (insulin-dependent) diabetic patients. Klin Wochenschr. 1988;66(9):388-96. [3835]. [pmid: 2839729].