# References

NOTE: Numbers in brackets correspond to study numbers in the Evidence Tables.

The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control Complications Trial. Diabetes 1996; 45 (10): 1289–98. [718].
Adler A I, Neil H A, Manley S E, Holman R R, Turner R C. Hyperglycemia and hyperinsulinemia at diagnosis of diabetes and their association with subsequent cardiovascular disease in the United Kingdom prospective diabetes study (UKPDS 47). Am Heart J. 1999;138(5 Pt 1):S353-9. [4124]. [pmid: 10539797].
Agardh C D, Agardh E, Torffvit O. The prognostic value of albuminuria for the development of cardiovascular disease and retinopathy: a 5-year follow-up of 451 patients with type 2 diabetes mellitus. Diabetes Res Clin Pract. 1996;32(12):35-44. [1075]. [pmid: 8803480].
Alaveras A E, Thomas S M, Sagriotis A, Viberti G C. Promoters of progression of diabetic nephropathy: the relative roles of blood glucose and blood pressure control. Nephrol Dial Transplant. 1997;12(Suppl 2):71-4. [681]. [pmid: 9269705].
American Association of Clinical Endocrinologists Medical Guidelines for Management of Diabetes Mellitus. Endocr. Pract. 2001; Suppl. 1 . [92180].
American Association of Clinical Endocrinologists Medical Guidelines for Management of Diabetes Mellitus. 2002; 8 . [92181].
American Diabetes Association. Diabetic Nephropathy. Diabetes Care. 2002;25(90001):85S-89. [2]. [pmid: 12401753].
American Diabetes Association: Clinical Practice Recommendations 2002. Diabetes Care 2002; 25 Supp. 1 : S1–S147. [92176].
Araki A, Ito H, Hattori A, Inoue J, Sato T, Shiraki M, Orimo H. Risk factors for development of retinopathy in elderly Japanese patients with diabetes mellitus. Diabetes Care. 1993;16(8):1184-6. [2535]. [pmid: 8375248].
Araki S, Haneda M, Togawa M, Sugimoto T, Shikano T, Nakagawa T, Isono M, Hidaka H, Kikkawa R. Microalbuminuria is not associated with cardiovascular death in Japanese NIDDM. Diabetes Res Clin Pract. 1997;35(1):35-40. [930]. [pmid: 9113473].
Arfken C L, Reno P L, Santiago J V, Klein R. Development of proliferative diabetic retinopathy in African-Americans and whites with type 1 diabetes. Diabetes Care. 1998;21(5):792-5. [2157]. [pmid: 9589242].
Assadi F K. Quantitation of microalbuminuria using random urine samples. Pediatr Nephrol. 2002;17(2):107-10. [9]. [pmid: 11875673].
Bakker A J. Detection of microalbuminuria. Receiver operating characteristic curve analysis favors albumin-to-creatinine ratio over albumin concentration. Diabetes Care. 1999;22(2):307-13. [8]. [pmid: 10333950].
Beilin J, Stanton K G, McCann V J, Knuiman M W, Divitini M L. Microalbuminuria in type 2 diabetes: an independent predictor of cardiovascular mortality. Aust N Z J Med. 1996;26(4):519-25. [1009]. [pmid: 8873935].
Biderman A, Rosenblatt I, Rosen S, Zangwill L M, Shalev R, Friger M, Weitzman S. Sex differentials in predictors of mortality for patients with adult-onset diabetes: a population-based follow-up study in Beer-Sheva, Israel. Diabetes Care. 2000;23(5):602-5. [392]. [pmid: 10834416].
Bojestig M, Arnqvist H J, Karlberg B E, Ludvigsson J. Unchanged incidence of severe retinopathy in a population of Type 1 diabetic patients with marked reduction of nephropathy. Diabet Med. 1998;15(10):863-9. [460]. [pmid: 9796888].
Bonney M, Hing S J, Fung A T, Stephens M M, Fairchild J M, Donaghue K C, Howard N J, Silink M. Development and progression of diabetic retinopathy: adolescents at risk. Diabet Med. 1995;12(11):967-73. [2379]. [pmid: 8582128].
Borch-Johnsen K, Kreiner S. Proteinuria: value as predictor of cardiovascular mortality in insulin dependent diabetes mellitus. Br Med J (Clin Res Ed). 1987;294(6588):1651-4. [5]. [pmid: 3113569].
Bry L, Chen P C, Sacks D B. Effects of hemoglobin variants and chemically modified derivatives on assays for glycohemoglobin. Clin Chem. 2001;47(2):153-63. [92179]. [pmid: 11159762].
Captopril reduces the risk of nephropathy in IDDM patients with microalbuminuria. The Microalbuminuria Captopril Study Group. Diabetologia 1996; 39 (5): 587–93. [1061].
Chalmers T C, Smith H Jr, Blackburn B, Silverman B, Schroeder B, Reitman D, Ambroz A. A method for assessing the quality of a randomized control trial. Control Clin Trials. 1981;2(1):31-49. [565]. [pmid: 7261638].
Chan J C, Cheung C K, Cheung M Y, Swaminathan R, Critchley J A, Cockram C S. Abnormal albuminuria as a predictor of mortality and renal impairment in Chinese patients with NIDDM. Diabetes Care. 1995;18(7):1013-6. [1195]. [pmid: 7555533].
Chase H P, Jackson W E, Hoops S L, Cockerham R S, Archer P G, O'Brien D. Glucose control and the renal and retinal complications of insulin-dependent diabetes. JAMA. 1989;261(8):1155-60. [1444]. [pmid: 2915437].
Chaturvedi N, Bandinelli S, Mangili R, Penno G, Rottiers R E, Fuller J H. Microalbuminuria in type 1 diabetes: rates, risk factors and glycemic threshold. Kidney Int. 2001;60(1):219-27. [84]. [pmid: 11422754].
Chaturvedi N, Sjoelie A K, Porta M, Aldington S J, Fuller J H, Songini M, Kohner E M. Markers of insulin resistance are strong risk factors for retinopathy incidence in type 1 diabetes. Diabetes Care. 2001;24(2):284-9. [140]. [pmid: 11213880].
Chen M S, Kao C S, Fu C C, Chen C J, Tai T Y. Incidence and progression of diabetic retinopathy among non-insulin-dependent diabetic subjects: a 4-year follow-up. Int J Epidemiol. 1995;24(4):787-95. [2392]. [pmid: 8550277].
Christen W G, Manson J E, Bubes V, Glynn R J. Risk factors for progression of distal symmetric polyneuropathy in type 1 diabetes mellitus. Sorbinil Retinopathy Trial Research Group. Am J Epidemiol. 1999;150(11):1142-51. [1999]. [pmid: 10588075].
Cohen R A, Hennekens C H, Christen W G, Krolewski A, Nathan D M, Peterson M J, LaMotte F, Manson J E. Determinants of retinopathy progression in type 1 diabetes mellitus. Am J Med. 1999;107(1):45-51. [2039]. [pmid: 10403352].
Coutinho M, Gerstein H C, Wang Y, Yusuf S. The relationship between glucose and incident cardiovascular events. A metaregression analysis of published data from 20 studies of 95,783 individuals followed for 12.4 years. Diabetes Care. 1999;22(2):233-40. [4645]. [pmid: 10333939].
Crepaldi G, Carraro A, Brocco E, Adezati L, Andreani D, Bompiani G, Brunetti P, Fedele D, Giorgino R, Giustina G, et al. Hypertension and non-insulin-dependent diabetes. A comparison between an angiotensin-converting enzyme inhibitor and a calcium antagonist. Acta Diabetol. 1995;32(3):203-8. [1158]. [pmid: 8590792].
d'Annunzio G, Malvezzi F, Vitali L, Barone C, Giacchero R, Klersy C, Zanette S, Lorini R. A 3–19-year follow-up study on diabetic retinopathy in patients diagnosed in childhood and treated with conventional therapy. Diabet Med. 1997;14(11):951-8. [587]. [pmid: 9400919].
Damsgaard E M, Froland A, Jorgensen O D, Mogensen C E. Eight to nine year mortality in known non-insulin dependent diabetics and controls. Kidney Int. 1992;41(4):731-5. [1622]. [pmid: 1513094].
Damsgaard E M, Froland A, Jorgensen O D, Morgensen C E. Prognostic value of urinary albumin excretion rate and other risk factors in elderly diabetic patients and non-diabetic control subjects surviving the first 5 years after assessment. Diabetologia. 1993;36(10):1030-6. [1429]. [pmid: 8243851].
Danne T, Weber B, Hartmann R, Enders I, Burger W, Hovener G. Long-term glycemic control has a nonlinear association to the frequency of background retinopathy in adolescents with diabetes. Follow-up of the Berlin Retinopathy Study. Diabetes Care. 1994;17(12):1390-6. [934]. [pmid: 7882807].
Danne T, Weber B, Hartmann R, Enders I, Burger W, Hovener G. Long-term glycemic control has a nonlinear association to the frequency of background retinopathy in adolescents with diabetes. Follow-up of the Berlin Retinopathy Study. Diabetes Care. 1994;17(12):1390-6. [92174]. [pmid: 7882807].
de Grauw W J, van de Lisdonk E H, van Gerwen W H, Verstappen M, van den Hoogen H J, Willems J L, van Weel C. Microalbuminuria in patients with Type 2 diabetes mellitus from general practice: course and predictive value. Diabet Med. 2001;18(2):139-43. [216]. [pmid: 11251678].
de Vegt F, Dekker J M, Ruhe H G, Stehouwer C D, Nijpels G, Bouter L M, Heine R J. Hyperglycaemia is associated with all-cause and cardiovascular mortality in the Hoorn population: the Hoorn Study. Diabetologia. 1999;42(8):926-31. [92182]. [pmid: 10491751].
Deckert T, Yokoyama H, Mathiesen E, Ronn B, Jensen T, Feldt-Rasmussen B, Borch-Johnsen K, Jensen J S. Cohort study of predictive value of urinary albumin excretion for atherosclerotic vascular disease in patients with insulin dependent diabetes. BMJ. 1996;312(7035):871-4. [1074]. [pmid: 8611873].
Dinneen S F, Gerstein H C. The association of microalbuminuria and mortality in non-insulin-dependent diabetes mellitus. A systematic overview of the literature. Arch Intern Med. 1997;157(13):1413-8. [6]. [pmid: 9224218].
Donahue R P, Orchard T J. Diabetes mellitus and macrovascular complications. An epidemiological perspective. Diabetes Care. 1992;15(9):1141-55. [4649]. [pmid: 1396012].
Donahue R P, Orchard T J. Diabetes mellitus and macrovascular complications. An epidemiological perspective. Diabetes Care. 1992;15(9):1141-55. [4]. [pmid: 1396012].
Dyck P J, Davies J L, Wilson D M, Service F J, Melton L J 3rd, O'Brien P C. Risk factors for severity of diabetic polyneuropathy: intensive longitudinal assessment of the Rochester Diabetic Neuropathy Study cohort. Diabetes Care. 1999;22(9):1479-86. [2022]. [pmid: 10480512].
Earle K A, Morocutti A, Viberti G. Permissive role of hypertension in the development of proteinuria and progression of renal disease in insulin-dependent diabetic patients. J Hypertens. 1997;15(2):191-6. [566]. [pmid: 9469795].
Effect of intensive diabetes treatment on carotid artery wall thickness in the epidemiology of diabetes interventions complications. Epidemiology of Diabetes Interventions and Complications (EDIC) Research Group. Diabetes 1999; 48 (2): 383–90. [4147].
The effect of intensive diabetes treatment on the progression of diabetic retinopathy in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial. Arch Ophthalmol 1995; 113 (1): 36–51. [2438].
The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group. N Engl J Med 1993; 329 (14): 977–86. [4638].
Eshoj O, Feldt-Rasmussen B, Larsen M L, Mogensen E F. Comparison of overnight, morning and 24-hour urine collections in the assessment of diabetic microalbuminuria. Diabet Med. 1987;4(6):531-3. [12]. [pmid: 2962808].
Florkowski C M, Scott R S, Moir C L, Graham P J. Clinical and biochemical outcomes of type 2 diabetes mellitus in Canterbury, New Zealand: a 6-year cohort study. Diabetes Res Clin Pract. 1998;40(3):167-73. [481]. [pmid: 9716920].
Florkowski C M, Scott R S, Moir C L, Graham P J. Lipid but not glycaemic parameters predict total mortality from type 2 diabetes mellitus in Canterbury, New Zealand. Diabet Med. 1998;15(5):386-92. [519]. [pmid: 9609360].
Fu C C, Chang C J, Tseng C H, Chen M S, Kao C S, Wu T J, Wu H P, Chuang L M, Chen C J, Tai T Y. Development of macrovascular diseases in NIDDM patients in northern Taiwan. A 4-yr follow-up study. Diabetes Care. 1993;16(1):137-43. [4403]. [pmid: 8422768].
Gaede P, Vedel P, Parving H H, Pedersen O. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. 1999;353(9153):617-22. [416]. [pmid: 10030326].
Gaede P, Vedel P, Parving H H, Pedersen O. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. 1999;353(9153):617-22. [613]. [pmid: 10030326].
Gall M A, Borch-Johnsen K, Hougaard P, Nielsen F S, Parving H H. Albuminuria and poor glycemic control predict mortality in NIDDM. Diabetes. 1995;44(11):1303-9. [827]. [pmid: 7589828].
Gall M A, Borch-Johnsen K, Hougaard P, Nielsen F S, Parving H H. Albuminuria and poor glycemic control predict mortality in NIDDM. Diabetes. 1995;44(11):1303-9. [1146]. [pmid: 7589828].
Gall M A, Hougaard P, Borch-Johnsen K, Parving H H. Risk factors for development of incipient and overt diabetic nephropathy in patients with non-insulin dependent diabetes mellitus: prospective, observational study. BMJ. 1997;314(7083):783-8. [654]. [pmid: 9080995]. [pmcid: 2126209].
Gerstein H C, Mann J F, Yi Q, Zinman B, Dinneen S F, Hoogwerf B, Halle J P, Young J, Rashkow A, Joyce C, Nawaz S, Yusuf S. Albuminuria and risk of cardiovascular events, death, and heart failure in diabetic and nondiabetic individuals. JAMA. 2001;286(4):421-6. [136]. [pmid: 11466120].
Goldstein D E, Little R R, Lorenz R A, Malone J I, Nathan D, Peterson C M. Tests of glycemia in diabetes. Diabetes Care. 1995;18(6):896-909. [4644]. [pmid: 7555528].
Guillausseau P J, Massin P, Charles M A, Allaguy H, Guvenli Z, Virally M, Tielmans D, Assayag M, Warnet A, Lubetzki J. Glycaemic control and development of retinopathy in type 2 diabetes mellitus: a longitudinal study. Diabet Med. 1998;15(2):151-5. [556]. [pmid: 9507917].
Haneda M, Kikkawa R, Togawa M, Koya D, Kajiwara N, Uzu T, Shigeta Y. High blood pressure is a risk factor for the development of microalbuminuria in Japanese subjects with non-insulin-dependent diabetes mellitus. J Diabetes Complications. 1992;6(3):181-5. [1172]. [pmid: 1472744].
Hanninen J, Takala J, Keinanen-Kiukaanniemi S. Albuminuria and other risk factors for mortality in patients with non-insulin-dependent diabetes mellitus aged under 65 years: a population-based prospective 5-year study. Diabetes Res Clin Pract. 1999;43(2):121-6. [580]. [pmid: 10221664].
Henricsson M, Nilsson A, Janzon L, Groop L. The effect of glycaemic control and the introduction of insulin therapy on retinopathy in non-insulin-dependent diabetes mellitus. Diabet Med. 1997;14(2):123-31. [2281]. [pmid: 9047089].
Hovind P, Rossing P, Tarnow L, Smidt U M, Parving H H. Progression of diabetic nephropathy. Kidney Int. 2001;59(2):702-9. [154]. [pmid: 11168952].
Hoy W E, Wang Z, VanBuynder P, Baker P R, McDonald S M, Mathews J D. The natural history of renal disease in Australian Aborigines. Part 2. Albuminuria predicts natural death and renal failure. Kidney Int. 2001;60(1):249-56. [160]. [pmid: 11422758].
Huang E S, Meigs J B, Singer D E. The effect of interventions to prevent cardiovascular disease in patients with type 2 diabetes mellitus. Am J Med. 2001;111(8):633-42. [4647]. [pmid: 11755507].
Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group. Lancet 1998; 352 (9131): 837–53. [2113].
Izumi K, Hoshi M, Kuno S, Okuno G, Yamazaki Y, Isshiki G, Sasaki A. Glycemic control, growth and complications in children with insulin-dependent diabetes mellitus--a study of children enrolled in a Summer camp program for diabetics in Kinki district, Japan. Diabetes Res Clin Pract. 1995;28(3):185-90. [871]. [pmid: 8529497].
Janka H U, Warram J H, Rand L I, Krolewski A S. Risk factors for progression of background retinopathy in long-standing IDDM. Diabetes. 1989;38(4):460-4. [2809]. [pmid: 2647552].
Janka H U, Warram J H, Rand L I, Krolewski A S. Risk factors for progression of background retinopathy in long-standing IDDM. Diabetes. 1989;38(4):460-4. [92173]. [pmid: 2647552].
Jones C A, Leese G P, Kerr S, Bestwick K, Isherwood D I, Vora J P, Hughes D A, Smith C. Development and progression of microalbuminuria in a clinic sample of patients with insulin dependent diabetes mellitus. Arch Dis Child. 1998;78(6):518-23. [482]. [pmid: 9713006].
Khaw K T, Wareham N, Luben R, Bingham S, Oakes S, Welch A, Day N. Glycated haemoglobin, diabetes, and mortality in men in Norfolk cohort of european prospective investigation of cancer and nutrition (EPIC-Norfolk). BMJ. 2001;322(7277):15-8. [92184]. [pmcid: 26599]. [pmid: 11141143].
Kim H K, Kim C H, Kim S W, Park J Y, Hong S K, Yoon Y H, Lee K U. Development and progression of diabetic retinopathy in Koreans with NIDDM. Diabetes Care. 1998;21(1):134-8. [2171]. [pmid: 9538984].
Kim H K, Kim C H, Kim S W, Park J Y, Hong S K, Yoon Y H, Lee K U. Development and progression of diabetic retinopathy in Koreans with NIDDM. Diabetes Care. 1998;21(1):134-8. [92171]. [pmid: 9538984].
Klein R, Klein B E, Moss S E. Incidence of gross proteinuria in older-onset diabetes. A population-based perspective. Diabetes. 1993;42(3):381-9. [1103]. [pmid: 8432408].
Klein R, Klein B E, Moss S E. The incidence of gross proteinuria in people with insulin-dependent diabetes mellitus. Arch Intern Med. 1991;151(7):1344-8. [2691]. [pmid: 2064485].
Klein R, Klein B E, Moss S E. Relation of glycemic control to diabetic microvascular complications in diabetes mellitus. Ann Intern Med. 1996;124(1 Pt 2):90-6. [809]. [pmid: 8554220].
Klein R, Klein B E, Moss S E, Cruickshanks K J. Relationship of hyperglycemia to the long-term incidence and progression of diabetic retinopathy. Arch Intern Med. 1994;154(19):2169-78. [2458]. [pmid: 7944837].
Klein R, Klein B E, Moss S E, Cruickshanks K J. Ten-year incidence of gross proteinuria in people with diabetes. Diabetes. 1995;44(8):916-23. [853]. [pmid: 7621997].
Klein R, Klein B E, Moss S E, Cruickshanks K J. The Wisconsin Epidemiologic Study of Diabetic Retinopathy. XV. The long-term incidence of macular edema. Ophthalmology. 1995;102(1):7-16. [2437]. [pmid: 7831044].
Klein R, Klein B E, Moss S E, Cruickshanks K J. The Wisconsin Epidemiologic Study of Diabetic Retinopathy: XVII. The 14-year incidence and progression of diabetic retinopathy and associated risk factors in type 1 diabetes. Ophthalmology. 1998;105(10):1801-15. [2108]. [pmid: 9787347].
Klein R, Klein B E, Moss S E, Cruickshanks K J, Brazy P C. The 10-year incidence of renal insufficiency in people with type 1 diabetes. Diabetes Care. 1999;22(5):743-51. [387]. [pmid: 10332675].
Klein R, Klein B E, Moss S E, Cruickshanks K J, Brazy P C. The 10-year incidence of renal insufficiency in people with type 1 diabetes. Diabetes Care. 1999;22(5):743-51. [3379]. [pmid: 10332675].
Klein R, Klein B E, Moss S E, Davis M D, DeMets D L. Glycosylated hemoglobin predicts the incidence and progression of diabetic retinopathy. JAMA. 1988;260(19):2864-71. [2832]. [pmid: 3184351].
Klein R, Klein B E, Moss S E, Davis M D, DeMets D L. Glycosylated hemoglobin predicts the incidence and progression of diabetic retinopathy. JAMA. 1988;260(19):2864-71. [92172]. [pmid: 3184351].
Klein R, Moss S E, Klein B E, Davis M D, DeMets D L. The Wisconsin epidemiologic study of diabetic retinopathy. XI. The incidence of macular edema. Ophthalmology. 1989;96(10):1501-10. [2787]. [pmid: 2587045].
Klein R, Palta M, Allen C, Shen G, Han D P, D'Alessio D J. Incidence of retinopathy and associated risk factors from time of diagnosis of insulin-dependent diabetes. Arch Ophthalmol. 1997;115(3):351-6. [2270]. [pmid: 9076207].
Kovacs M, Mukerji P, Drash A, Iyengar S. Biomedical and psychiatric risk factors for retinopathy among children with IDDM. Diabetes Care. 1995;18(12):1592-9. [2372]. [pmid: 8722057].
Krolewski A S, Laffel L M, Krolewski M, Quinn M, Warram J H. Glycosylated hemoglobin and the risk of microalbuminuria in patients with insulin-dependent diabetes mellitus. N Engl J Med. 1995;332(19):1251-5. [92175]. [pmid: 7708068].
Laakso M. Hyperglycemia and cardiovascular disease in type 2 diabetes. Diabetes. 1999;48(5):937-42. [4648]. [pmid: 10331395].
Lawson M L, Gerstein H C, Tsui E, Zinman B. Effect of intensive therapy on early macrovascular disease in young individuals with type 1 diabetes. A systematic review and meta-analysis. Diabetes Care. 1999;22(Suppl 2):B35-9. [4646]. [pmid: 10097897].
Lebovitz H E, Wiegmann T B, Cnaan A, Shahinfar S, Sica D A, Broadstone V, Schwartz S L, Mengel M C, Segal R, Versaggi J A, et al. Renal protective effects of enalapril in hypertensive NIDDM: role of baseline albuminuria. Kidney Int Suppl. 1994;45:S150-5. [1366]. [pmid: 8158885].
Lehto S, Ronnemaa T, Haffner S M, Pyorala K, Kallio V, Laakso M. Dyslipidemia and hyperglycemia predict coronary heart disease events in middle-aged patients with NIDDM. Diabetes. 1997;46(8):1354-9. [4240]. [pmid: 9231662].
Lehto S, Ronnemaa T, Pyorala K, Laakso M. Poor glycemic control predicts coronary heart disease events in patients with type 1 diabetes without nephropathy. Arterioscler Thromb Vasc Biol. 1999;19(4):1014-9. [397]. [pmid: 10195930].
Lehto S, Ronnemaa T, Pyorala K, Laakso M. Predictors of stroke in middle-aged patients with non-insulin-dependent diabetes. Stroke. 1996;27(1):63-8. [4313]. [pmid: 8553405].
Lehto S, Ronnemaa T, Pyorala K, Laakso M. Risk factors predicting lower extremity amputations in patients with NIDDM. Diabetes Care. 1996;19(6):607-12. [2330]. [pmid: 8725860].
Leong S O, Lui K F, Ng W Y, Thai A C. The use of semi-quantitative urine test-strip (Micral Test) for microalbuminuria screening in patients with diabetes mellitus. Singapore Med J. 1998;39(3):101-3. [16]. [pmid: 9632966].
Little R R, Rohlfing C L, Wiedmeyer H M, Myers G L, Sacks D B, Goldstein D E. The national glycohemoglobin standardization program: a five-year progress report. Clin Chem. 2001;47(11):1985-92. [4643]. [pmid: 11673367].
Lloyd C E, Becker D, Ellis D, Orchard T J. Incidence of complications in insulin-dependent diabetes mellitus: a survival analysis. Am J Epidemiol. 1996;143(5):431-41. [777]. [pmid: 8610658].
Lloyd C E, Klein R, Maser R E, Kuller L H, Becker D J, Orchard T J. The progression of retinopathy over 2 years: the Pittsburgh Epidemiology of Diabetes Complications (EDC) Study. J Diabetes Complications. 1995;9(3):140-8. [870]. [pmid: 7548977].
MacLeod J M, Lutale J, Marshall S M. Albumin excretion and vascular deaths in NIDDM. Diabetologia. 1995;38(5):610-6. [1218]. [pmid: 7489846].
Makimattila S, Schlenzka A, Mantysaari M, Bergholm R, Summanen P, Saar P, Erkkila H, Yki-Jarvinen H. Predictors of abnormal cardiovascular autonomic function measured by frequence domain analysis of heart rate variability and conventional tests in patients with type 1 diabetes. Diabetes Care. 2000;23(11):1686-93. [184]. [pmid: 11092293].
Marshall G, Garg S K, Jackson W E, Holmes D L, Chase H P. Factors influencing the onset and progression of diabetic retinopathy in subjects with insulin-dependent diabetes mellitus. Ophthalmology. 1993;100(8):1133-9. [2537]. [pmid: 8341492].
Mattock M B, Barnes D J, Viberti G, Keen H, Burt D, Hughes J M, Fitzgerald A P, Sandhu B, Jackson P G. Microalbuminuria and coronary heart disease in NIDDM: an incidence study. Diabetes. 1998;47(11):1786-92. [659]. [pmid: 9792549].
Mattock M B, Morrish N J, Viberti G, Keen H, Fitzgerald A P, Jackson G. Prospective study of microalbuminuria as predictor of mortality in NIDDM. Diabetes. 1992;41(6):736-41. [1603]. [pmid: 1587400].
Miettinen H, Haffner S M, Lehto S, Ronnemaa T, Pyorala K, Laakso M. Proteinuria predicts stroke and other atherosclerotic vascular disease events in nondiabetic and non-insulin-dependent diabetic subjects. Stroke. 1996;27(11):2033-9. [977]. [pmid: 8898811].
Mlacak B, Jaksic Z, Vuletic S. Albuminuria, cardiovascular morbidity and mortality in diabetic and non-diabetic subjects in a rural general practice. Fam Pract. 1999;16(6):580-5. [465]. [pmid: 10625130].
Mogensen C E, Viberti G C, Peheim E, Kutter D, Hasslacher C, Hofmann W, Renner R, Bojestig M, Poulsen P L, Scott G, Thoma J, Kuefer J, Nilsson B, Gambke B, Mueller P, Steinbiss J, Willamowski K D. Multicenter evaluation of the Micral-Test II test strip, an immunologic rapid test for the detection of microalbuminuria. Diabetes Care. 1997;20(11):1642-6. [15]. [pmid: 9353600].
Molyneaux L M, Constantino M I, McGill M, Zilkens R, Yue D K. Better glycaemic control and risk reduction of diabetic complications in Type 2 diabetes: comparison with the DCCT. Diabetes Res Clin Pract. 1998;42(2):77-83. [424]. [pmid: 9886743].
Morisaki N, Watanabe S, Kobayashi J, Kanzaki T, Takahashi K, Yokote K, Tezuka M, Tashiro J, Inadera H, Saito Y, et al. Diabetic control and progression of retinopathy in elderly patients: five-year follow-up study. J Am Geriatr Soc. 1994;42(2):142-5. [2502]. [pmid: 8126325].
Moss S E, Klein R, Klein B E. The 14-year incidence of lower-extremity amputations in a diabetic population. The Wisconsin Epidemiologic Study of Diabetic Retinopathy. Diabetes Care. 1999;22(6):951-9. [2047]. [pmid: 10372248].
Moss S E, Klein R, Klein B E. The 14-year incidence of visual loss in a diabetic population. Ophthalmology. 1998;105(6):998-1003. [2145]. [pmid: 9627648].
Moss S E, Klein R, Klein B E. Long-term incidence of lower-extremity amputations in a diabetic population. Arch Fam Med. 1996;5(7):391-8. [2326]. [pmid: 8664997].
Moss S E, Klein R, Klein B E. The prevalence and incidence of lower extremity amputation in a diabetic population. Arch Intern Med. 1992;152(3):610-6. [2636]. [pmid: 1546925].
Moss S E, Klein R, Klein B E. Ten-year incidence of visual loss in a diabetic population. Ophthalmology. 1994;101(6):1061-70. [2482]. [pmid: 8008348].
Moss S E, Klein R, Klein B E, Meuer S M. The association of glycemia and cause-specific mortality in a diabetic population. Arch Intern Med. 1994;154(21):2473-9. [4338]. [pmid: 7979844].
Muhlhauser I, Overmann H, Bender R, Jorgens V, Berger M. Predictors of mortality and end-stage diabetic complications in patients with Type 1 diabetes mellitus on intensified insulin therapy. Diabet Med. 2000;17(10):727-34. [178]. [pmid: 11110506].
Muhlhauser I, Overmann H, Bender R, Jorgens V, Berger M. Predictors of mortality and end-stage diabetic complications in patients with Type 1 diabetes mellitus on intensified insulin therapy. Diabet Med. 2000;17(10):727-34. [283]. [pmid: 11110506].
Muhlhauser I, Sawicki P T, Blank M, Overmann H, Bender R, Berger M. Prognosis of persons with type 1 diabetes on intensified insulin therapy in relation to nephropathy. J Intern Med. 2000;248(4):333-41. [185]. [pmid: 11086645].
Muhlhauser I, Sawicki P T, Blank M, Overmann H, Bender R, Berger M. Prognosis of persons with type 1 diabetes on intensified insulin therapy in relation to nephropathy. J Intern Med. 2000;248(4):333-41. [293]. [pmid: 11086645].
Mulec H, Blohme G, Grande B, Bjorck S. The effect of metabolic control on rate of decline in renal function in insulin-dependent diabetes mellitus with overt diabetic nephropathy. Nephrol Dial Transplant. 1998;13(3):651-5. [540]. [pmid: 9550642].
Nakagami T, Kawahara R, Hori S, Omori Y. Glycemic control and prevention of retinopathy in Japanese NIDDM patients. A 10-year follow-up study. Diabetes Care. 1997;20(4):621-2. [2259]. [pmid: 9096990].
Nathan D M, Rosenbaum C, Protasowicki V D. Single-void urine samples can be used to estimate quantitative microalbuminuria. Diabetes Care. 1987;10(4):414-8. [11]. [pmid: 3622198].
National Kidney Foundation. K/DOQI Clinical Practice Guidelines for Chronic Kidney Desease: Evaluation, Classification, and Stratification. Guideline 5. Assessment of Proteinuria. Am J Kidney Dis. 2002;39(suppl 1):s93-s102. [3].
Neil A, Hawkins M, Potok M, Thorogood M, Cohen D, Mann J. A prospective population-based study of microalbuminuria as a predictor of mortality in NIDDM. Diabetes Care. 1993;16(7):996-1003. [1454]. [pmid: 8359108].
Nelson R G, Bennett P H, Beck G J, Tan M, Knowler W C, Mitch W E, Hirschman G H, Myers B D. Development and progression of renal disease in Pima Indians with non-insulin-dependent diabetes mellitus. Diabetic Renal Disease Study Group. N Engl J Med. 1996;335(22):1636-42. [967]. [pmid: 8929360].
Nichols G A, Hillier T A, Erbey J R, Brown J B. Congestive heart failure in type 2 diabetes: prevalence, incidence, and risk factors. Diabetes Care. 2001;24(9):1614-9. [4025]. [pmid: 11522708].
Niskanen L, Turpeinen A, Penttila I, Uusitupa M I. Hyperglycemia and compositional lipoprotein abnormalities as predictors of cardiovascular mortality in type 2 diabetes: a 15-year follow-up from the time of diagnosis. Diabetes Care. 1998;21(11):1861-9. [457]. [pmid: 9802734].
Niskanen L, Voutilainen R, Terasvirta M, Lehtinen J, Teppo A M, Groop L, Uusitupa M. A prospective study of clinical and metabolic associates of proteinuria in patients with type 2 diabetes mellitus. Diabet Med. 1993;10(6):543-9. [1452]. [pmid: 8365091].
Niskanen L K, Penttila I, Parviainen M, Uusitupa M I. Evolution, risk factors, and prognostic implications of albuminuria in NIDDM. Diabetes Care. 1996;19(5):486-93. [749]. [pmid: 8732714].
Niskanen L K, Penttila I, Parviainen M, Uusitupa M I. Evolution, risk factors, and prognostic implications of albuminuria in NIDDM. Diabetes Care. 1996;19(5):486-93. [1067]. [pmid: 8732714].
Nosadini R, Velussi M, Brocco E, Bruseghin M, Abaterusso C, Saller A, Dalla Vestra M, Carraro A, Bortoloso E, Sambataro M, Barzon I, Frigato F, Muollo B, Chiesura-Corona M, Pacini G, Baggio B, Piarulli F, Sfriso A, Fioretto P. Course of renal function in type 2 diabetic patients with abnormalities of albumin excretion rate. Diabetes. 2000;49(3):476-84. [245]. [pmid: 10868971].
Nosadini R, Velussi M, Brocco E, Bruseghin M, Abaterusso C, Saller A, Dalla Vestra M, Carraro A, Bortoloso E, Sambataro M, Barzon I, Frigato F, Muollo B, Chiesura-Corona M, Pacini G, Baggio B, Piarulli F, Sfriso A, Fioretto P. Course of renal function in type 2 diabetic patients with abnormalities of albumin excretion rate. Diabetes. 2000;49(3):476-84. [376]. [pmid: 10868971].
Ohkubo Y, Kishikawa H, Araki E, Miyata T, Isami S, Motoyoshi S, Kojima Y, Furuyoshi N, Shichiri M. Intensive insulin therapy prevents the progression of diabetic microvascular complications in Japanese patients with non-insulin-dependent diabetes mellitus: a randomized prospective 6-year study. Diabetes Res Clin Pract. 1995;28(2):103-17. [888]. [pmid: 7587918].
Okudaira M, Yokoyama H, Otani T, Uchigata Y, Iwamoto Y. Slightly elevated blood pressure as well as poor metabolic control are risk factors for the progression of retinopathy in early-onset Japanese Type 2 diabetes. J Diabetes Complications. 2000;14(5):281-7. [1899]. [pmid: 11113692].
Olson J C, Erbey J R, Forrest K Y, Williams K, Becker D J, Orchard T J. Glycemia (or, in women, estimated glucose disposal rate) predict lower extremity arterial disease events in type 1 diabetes. Metabolism. 2002;51(2):248-54. [7]. [pmid: 11833057].
Oue T, Namba M, Nakajima H, Ono A, Horikawa Y, Yamamoto K, Hamaguchi T, Fujino-Kurihara H, Yamasaki T, Tomita K, Miyagawa J, Hanafusa T, Matsuzawa Y. Risk factors for the progression of microalbuminuria in Japanese type 2 diabetic patients--a 10 year follow-up study. Diabetes Res Clin Pract. 1999;46(1):47-55. [315]. [pmid: 10580616].
Park J Y, Kim H K, Chung Y E, Kim S W, Hong S K, Lee K U. Incidence and determinants of microalbuminuria in Koreans with type 2 diabetes. Diabetes Care. 1998;21(4):530-4. [534]. [pmid: 9571337].
Park S, Barrett-Connor E, Wingard D L, Shan J, Edelstein S. GHb is a better predictor of cardiovascular disease than fasting or postchallenge plasma glucose in women without diabetes. The Rancho Bernardo Study. Diabetes Care. 1996;19(5):450-6. [92183]. [pmid: 8732708].
Piehlmeier W, Renner R, Kimmerling T, Schramm W, Garbe S, Proetzsch R, Fahn J, Piwernetz K, Landgraf R. Evaluation of the Micral-Test S, a qualitative immunologic patient self-test for microalbuminuria: the PROSIT project. Proteinuria Screening and Intervention. Diabet Med. 1998;15(10):883-5. [14]. [pmid: 9796891].
Pirart J. Glycaemic control and development of diabetic nephropathy. Acta Endocrinol Suppl (Copenh). 1981;242:41-2. [4640]. [pmid: 6940400].
Pirart J. Glycaemic control and prevention of complications. Minerva Endocrinol. 1984;9(2):55-8. [4641]. [pmid: 6503916].
Pirart J. Tight glycaemic control prevents diabetic complications. Acta Clin Belg. 1995;50(6):321-5. [4642]. [pmid: 8571727].
Porta M, Sjoelie A K, Chaturvedi N, Stevens L, Rottiers R, Veglio M, Fuller J H. Risk factors for progression to proliferative diabetic retinopathy in the EURODIAB Prospective Complications Study. Diabetologia. 2001;44(12):2203-9. [1769]. [pmid: 11793022].
Powrie J K, Watts G F, Ingham J N, Taub N A, Talmud P J, Shaw K M. Role of glycaemic control in development of microalbuminuria in patients with insulin dependent diabetes. BMJ. 1994;309(6969):1608-12. [929]. [pmid: 7819935].
Predictors of the development of microalbuminuria in patients with Type 1 diabetes mellitus: a seven-year prospective study. The Microalbuminuria Collaborative Study Group. Diabet Med 1999; 16(11):918–25. [310].
Rachmani R, Levi Z, Lidar M, Slavachevski I, Half-Onn E, Ravid M. Considerations about the threshold value of microalbuminuria in patients with diabetes mellitus: lessons from an 8-year follow-up study of 599 patients. Diabetes Res Clin Pract. 2000;49 (2–3):187-94. [336]. [pmid: 10963831].
Rahbar S. An abnormal hemoglobin in red cells of diabetics. Clin Chem Acta. 1968;22:296-8. [92177].
Rahbar S, Blumenfeld O, Ranney H M. Studies of an unusual hemoglobin in patients with diabetes mellitus. Biochem Biophys Res Commun. 1969;36(5):838-43. [92178]. [pmid: 5808299].
Ravid M, Brosh D, Ravid-Safran D, Levy Z, Rachmani R. Main risk factors for nephropathy in type 2 diabetes mellitus are plasma cholesterol levels, mean blood pressure, and hyperglycemia. Arch Intern Med. 1998;158(9):998-1004. [531]. [pmid: 9588433].
Reichard P. Are there any glycemic thresholds for the serious microvascular diabetic complications?. J Diabetes Complications. 1995;9(1):25-30. [921]. [pmid: 7734740].
Reichard P. Risk factors for progression of microvascular complications in the Stockholm Diabetes Intervention Study (SDIS). Diabetes Res Clin Pract. 1992;16(2):151-6. [1188]. [pmid: 1600854].
Reichard P, Berglund B, Britz A, Cars I, Nilsson B Y, Rosenqvist U. Intensified conventional insulin treatment retards the microvascular complications of insulin-dependent diabetes mellitus (IDDM): the Stockholm Diabetes Intervention Study (SDIS) after 5 years. J Intern Med. 1991;230(2):101-8. [1266]. [pmid: 1865159].
Reichard P, Nilsson B Y, Rosenqvist U. The effect of long-term intensified insulin treatment on the development of microvascular complications of diabetes mellitus. N Engl J Med. 1993;329(5):304-9. [1069]. [pmid: 8147960].
Reichard P, Pihl M, Rosenqvist U, Sule J. Complications in IDDM are caused by elevated blood glucose level: the Stockholm Diabetes Intervention Study (SDIS) at 10-year follow up. Diabetologia. 1996;39(12):1483-8. [699]. [pmid: 8960830].
Remuzzi G, Schieppati A, Ruggenenti P. Clinical practice. Nephropathy in patients with type 2 diabetes. N Engl J Med. 2002;346(15):1145-51. [7]. [pmid: 11948275].
Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group. N Engl J Med 2000; 342 (6): 381–9. [292].
Rossing P, Hougaard P, Borch-Johnsen K, Parving H H. Predictors of mortality in insulin dependent diabetes: 10 year observational follow up study. BMJ. 1996;313(7060):779-84. [991]. [pmid: 8842069].
Rudberg S, Persson B, Dahlquist G. Increased glomerular filtration rate as a predictor of diabetic nephropathy--an 8-year prospective study. Kidney Int. 1992;41(4):822-8. [1204]. [pmid: 1513104].
Rudberg S, Ullman E, Dahlquist G. Relationship between early metabolic control and the development of microalbuminuria--a longitudinal study in children with type 1 (insulin-dependent) diabetes mellitus. Diabetologia. 1993;36(12):1309-14. [1023]. [pmid: 8307261].
Sands M L, Shetterly S M, Franklin G M, Hamman R F. Incidence of distal symmetric (sensory) neuropathy in NIDDM. The San Luis Valley Diabetes Study. Diabetes Care. 1997;20(3):322-9. [2275]. [pmid: 9051381].
Sawicki P T, Bender R, Berger M, Muhlhauser I. Non-linear effects of blood pressure and glycosylated haemoglobin on progression of diabetic nephropathy. J Intern Med. 2000;247(1):131-8. [289]. [pmid: 10672141].
Schernthaner G. Cardiovascular mortality and morbidity in type-2 diabetes mellitus. Diabetes Res Clin Pract. 1996;31(Suppl):S3-13. [4650]. [pmid: 8864635].
Schmitz A, Vaeth M. Microalbuminuria: a major risk factor in non-insulin-dependent diabetes. A 10-year follow-up study of 503 patients. Diabet Med. 1988;5(2):126-34. [1986]. [pmid: 2964977].
Schwab S J, Dunn F L, Feinglos M N. Screening for microalbuminuria. A comparison of single sample methods of collection and techniques of albumin analysis. Diabetes Care. 1992;15(11):1581-4. [10]. [pmid: 1468288].
Scott L J, Warram J H, Hanna L S, Laffel L M, Ryan L, Krolewski A S. A nonlinear effect of hyperglycemia and current cigarette smoking are major determinants of the onset of microalbuminuria in type 1 diabetes. Diabetes. 2001;50(12):2842-9. [25]. [pmid: 11723069].
Shichiri M, Kishikawa H, Ohkubo Y, Wake N. Long-term results of the Kumamoto Study on optimal diabetes control in type 2 diabetic patients. Diabetes Care. 2000;23(Suppl 2):B21-9. [247]. [pmid: 10860187].
Singer D E, Nathan D M, Anderson K M, Wilson P W, Evans J C. Association of HbA1c with prevalent cardiovascular disease in the original cohort of the Framingham Heart Study. Diabetes. 1992;41(2):202-8. [92185]. [pmid: 1733810].
Standl E, Balletshofer B, Dahl B, Weichenhain B, Stiegler H, Hormann A, Holle R. Predictors of 10-year macrovascular and overall mortality in patients with NIDDM: the Munich General Practitioner Project. Diabetologia. 1996;39(12):1540-5. [4276]. [pmid: 8960840].
Stehouwer C D, Gall M A, Twisk J W, Knudsen E, Emeis J J, Parving H H. Increased urinary albumin excretion, endothelial dysfunction, and chronic low-grade inflammation in type 2 diabetes: progressive, interrelated, and independently associated with risk of death. Diabetes. 2002;51(4):1157-65. [6834]. [pmid: 11916939].
Stella P, Ellis D, Maser R E, Orchard T J. Cardiovascular autonomic neuropathy (expiration and inspiration ratio) in type 1 diabetes. Incidence and predictors. J Diabetes Complications. 2000;14(1):1-6. [224]. [pmid: 10925059].
Stratton I M, Adler A I, Neil H A, Matthews D R, Manley S E, Cull C A, Hadden D, Turner R C, Holman R R. Association of glycaemia with macrovascular and microvascular complications of type 2 diabetes (UKPDS 35): prospective observational study. BMJ. 2000;321(7258):405-12. [4087]. [pmcid: 27454]. [pmid: 10938048].
Stratton I M, Kohner E M, Aldington S J, Turner R C, Holman R R, Manley S E, Matthews D R. UKPDS 50: risk factors for incidence and progression of retinopathy in Type II diabetes over 6 years from diagnosis. Diabetologia. 2001;44(2):156-63. [1863]. [pmid: 11270671].
Tiu S C, Lee S S, Cheng M W. Comparison of six commercial techniques in the measurement of microalbuminuria in diabetic patients. Diabetes Care. 1993;16(4):616-20. [13]. [pmid: 8462389].
Torffvit O, Agardh C D. The predictive value of albuminuria for cardiovascular and renal disease. A 5-year follow-up study of 476 patients with type I diabetes mellitus. J Diabetes Complications. 1993;7(1):49-56. [1508]. [pmid: 8481551].
Toyry J P, Niskanen L K, Mantysaari M J, Lansimies E A, Uusitupa M I. Occurrence, predictors, and clinical significance of autonomic neuropathy in NIDDM. Ten-year follow-up from the diagnosis. Diabetes. 1996;45(3):308-15. [3527]. [pmid: 8593935].
Tudor S M, Hamman R F, Baron A, Johnson D W, Shetterly S M. Incidence and progression of diabetic retinopathy in Hispanics and non-Hispanic whites with type 2 diabetes. San Luis Valley Diabetes Study, Colorado. Diabetes Care. 1998;21(1):53-61. [2173]. [pmid: 9538971].
Turner R C, Millns H, Neil H A, Stratton I M, Manley S E, Matthews D R, Holman R R. Risk factors for coronary artery disease in non-insulin dependent diabetes mellitus: United Kingdom Prospective Diabetes Study (UKPDS: 23). BMJ. 1998;316(7134):823-8. [4217]. [pmcid: 28484]. [pmid: 9549452].
U.S. Renal Data System. USRDS 2002 Annual Data Report: Atlas of End-Stage Renal Disease in the United States. National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases, Bethesda, MD 2002. [20].
Valmadrid C T, Klein R, Moss S E, Klein B E. The risk of cardiovascular disease mortality associated with microalbuminuria and gross proteinuria in persons with older-onset diabetes mellitus. Arch Intern Med. 2000;160(8):1093-100. [411]. [pmid: 10789601].
Villar G, Garcia Y, Goicolea I, Vazquez J A. Determinants of development of microalbuminuria in normotensive patients with type 1 and type 2 diabetes. Diabetes Metab. 1999;25(3):246-54. [325]. [pmid: 10499194].
Vitale S, Maguire M G, Murphy R P, Hiner C, Rourke L, Sackett C, Patz A. Interval between onset of mild nonproliferative and proliferative retinopathy in type I diabetes. Arch Ophthalmol. 1997;115(2):194-8. [2282]. [pmid: 9046254].
Vitale S, Maguire M G, Murphy R P, Hiner C J, Rourke L, Sackett C, Patz A. Clinically significant macular edema in type I diabetes. Incidence and risk factors. Ophthalmology. 1995;102(8):1170-6. [2391]. [pmid: 9097743].
Vitelli L L, Shahar E, Heiss G, McGovern P G, Brancati F L, Eckfeldt J H, Folsom A R. Glycosylated hemoglobin level and carotid intimal-medial thickening in nondiabetic individuals. The Atherosclerosis Risk in Communities Study. Diabetes Care. 1997;20(9):1454-8. [92186]. [pmid: 9283796].
Voutilainen-Kaunisto R M, Terasvirta M E, Uusitupa M I, Niskanen L K. Occurrence and predictors of retinopathy and visual acuity in Type 2 diabetic patients and control subjects. 10-year follow-up from the diagnosis. J Diabetes Complications. 2001;15(1):24-33. [1867]. [pmid: 11259923].
Waltman S R. Sequential vitreous fluorophotometry in diabetes mellitus: a five-year prospective study. Trans Am Ophthalmol Soc. 1984;82:827-49. [3029]. [pmid: 6535330]. [pmcid: 1298680].
Warram J H, Manson J E, Krolewski A S. Glycosylated hemoglobin and the risk of retinopathy in insulin-dependent diabetes mellitus. N Engl J Med. 1995;332(19):1305-6. [4639]. [pmid: 7708084].
Warram J H, Scott L J, Hanna L S, Wantman M, Cohen S E, Laffel L M, Ryan L, Krolewski A S. Progression of microalbuminuria to proteinuria in type 1 diabetes: nonlinear relationship with hyperglycemia. Diabetes. 2000;49(1):94-100. [304]. [pmid: 10615955].
White N H, Cleary P A, Dahms W, Goldstein D, Malone J, Tamborlane W V. Beneficial effects of intensive therapy of diabetes during adolescence: outcomes after the conclusion of the Diabetes Control and Complications Trial (DCCT). J Pediatr. 2001;139(6):804-12. [19]. [pmid: 11743505].
Yamasaki Y, Kodama M, Nishizawa H, Sakamoto K, Matsuhisa M, Kajimoto Y, Kosugi K, Shimizu Y, Kawamori R, Hori M. Carotid intima-media thickness in Japanese type 2 diabetic subjects: predictors of progression and relationship with incident coronary heart disease. Diabetes Care. 2000;23(9):1310-5. [4081]. [pmid: 10977024].
Yokoyama H, Okudaira M, Otani T, Watanabe C, Takaike H, Miuira J, Yamada H, Mutou K, Satou A, Uchigata Y, Iwamoto Y. High incidence of diabetic nephropathy in early-onset Japanese NIDDM patients. Risk analysis. Diabetes Care. 1998;21(7):1080-5. [503]. [pmid: 9653599].
Yokoyama H, Tomonaga O, Hirayama M, Ishii A, Takeda M, Babazono T, Ujihara U, Takahashi C, Omori Y. Predictors of the progression of diabetic nephropathy and the beneficial effect of angiotensin-converting enzyme inhibitors in NIDDM patients. Diabetologia. 1997;40(4):405-11. [653]. [pmid: 9112017].
Yokoyama H, Uchigata Y, Otani T, Saeki A, Aoki K, Kasahara T, Omori Y, Borch-Johnsen K. Metabolic regulation and microangiopathy in a cohort of Japanese IDDM-patients. Diabetes Res Clin Pract. 1995;29(3):203-9. [2386]. [pmid: 8591714].
Yoshida Y, Hagura R, Hara Y, Sugasawa G, Akanuma Y. Risk factors for the development of diabetic retinopathy in Japanese type 2 diabetic patients. Diabetes Res Clin Pract. 2001;51(3):195-203. [1864]. [pmid: 11269892].
Zhang L, Krzentowski G, Albert A, Lefebvre P J. Risk of developing retinopathy in Diabetes Control and Complications Trial type 1 diabetic patients with good or poor metabolic control. Diabetes Care. 2001;24(7):1275-9. [1833]. [pmid: 11423515].