# Results

## Glycemic Control

### Identification of Relevant Articles

Our computerized MEDLINE^®^ search identified 3336 potentially relevant abstracts. Of these 3336, abstracts were eliminated for the following reasons: no diabetic participants (n= 55), no information relevant to our study questions (n=1669), no human data (n=7), fewer than 50 participants (n=403), no original data (i.e. review articles; n=135), no prospective data (i.e. cross-sectional studies; n= 472), only special diabetic subgroups studied (i.e. diabetes in pregnancy, transplant patients; n=256), data only given in graphical form (n=3), glycated hemoglobin was a confounder and not an exposure variable (n=2), less than 1 year of followup (n=3), and study design unclear (n=1). This left 330 articles for review. Of these, articles were eliminated for the following reasons: no diabetic participants (n=1), outcomes not analyzed specifically in diabetic individuals (n= 5), no information relevant to our study question (n=63), data only given in graphical form (n=8), glycated hemoglobin was a confounder and not an exposure variable (n=6), fewer than 50 participants (n=15), no original data (i.e., review articles; n=2), no prospective data (n=25), no risk data reported (n=57), glycated hemoglobin exposure not clearly defined (n=13), less than 1 year of followup (n=3), study design unclear (n=1), outcomes not clearly defined (n=5), diabetes type not specified (n= 12), and study represented subgroup analysis of main study results already abstracted (n=2). Data were abstracted from the remaining 112 articles.

### Characteristics of Reviewed Studies—Study Population, Design, Location, Recruitment, and Quality

Of the remaining 112 studies, 79 were cohort studies, 24 were cohort studies from previous clinical trial populations, and 9 were randomized clinical trials. For summary purposes, the cohort studies from clinical trials are grouped together with the other cohort studies. The studies were conducted in diverse populations and included 18 studies in Asia, 44 studies in Europe, 1 study in Israel, 44 studies in North America, 4 studies in New Zealand, and 1 study in South America. The majority of studies were conducted in a single city (n= 62) or a single country (n=37). Seven studies were conducted in more than one country. The majority of participants were recruited from a hospital based specialty clinic (n=18), an unspecified hospital based clinic (n= 14), an outpatient specialty (n= 15) or general clinic (n=13), or from a previous or concurrent clinical trial (n=14).

Among the cohort studies, 51 were conducted in individuals with type 1 diabetes, 40 were conducted in individuals with type 2 diabetes, and 12 included individuals with both type 1 and type 2 diabetes. Among the clinical trials, 6 were conducted in individuals with type 1 diabetes and 3 were conducted in individuals with type 2 diabetes. For the summary purposes, individuals described as IDDM or younger/juvenile onset diabetes were considered to have type 1 diabetes and individuals described as NIDDM or older onset diabetes were considered to have type 2 diabetes. Some studies contained individuals with both type 1 and type 2 diabetes.

Among the cohort studies, 48 reported retinopathy outcomes, 40 reported nephropathy outcomes, 9 reported neuropathy outcomes, and 25 reported macrovascular outcomes. Among the clinical trials, 9 reported retinopathy outcomes, 7 reported nephropathy outcomes, 5 reported neuropathy outcomes, and 1 reported a macrovascular outcome. Many studies reported more than one outcome. The mean quality score for the cohort studies was 53.6 (SD=13.8, median=52.8, range 8.6 to 79.2) and for clinical trials was 62.2 (SD=18.6, median=65.9, range 28.1 to 83.4) (see Table 1).

### Reported Baseline Data for Study Participants

Studies varied in their reporting of baseline characteristics. Among the cohort studies, the majority of studies reported data on age (79.4 percent), gender (80.4 percent), and duration of diabetes (63.7 percent). Half of the studies reported on the smoking status and body-mass index of the participants, while few cohort studies specifically described the ethnicity (37.2 percent), cardiovascular disease history (23.5 percent), or fasting glucose (18.6 percent) of the participants (see Table 2). The mean age of participants in the cohort studies included in this review was 42.3 years (range 8.3 to 69.7 years), the average duration of diabetes was 11.0 years (range 0.31 to 27.5 years), and the mean body-mass index was 26.9 kg/m^2^ (range 21.8 to 30.7 kg/m^2^).

Among the clinical trials, all reported data on the age of the participants and the majority of the studies reported data on gender (90 percent) and duration of diabetes (80 percent). Nearly half of the trials reported on ethnicity, smoking status, and body-mass index. Few studies reported cardiovascular disease history (10 percent) or fasting glucose (10 percent) (see Table 3). The mean age of participants in the clinical trials included in this review was 37.3 years (range 26 to 55.2 years), the average duration of diabetes was 8.8 years (2.6 to 18 years), and the mean body-mass index was 22.2 kg/m^2^ (19.2 to 27.8 kg/m^2^). The younger age and lower body-mass index of the participants in the clinical trials compared to participants in the cohort studies likely reflects the fact that the majority of clinical trials included in this review (70 percent) have been conducted in individuals with type 1 diabetes. (See Tables 4 and 5 for reported methods for ascertainment of diabetes in cohort studies and clinical trials, respectively.)

### Glycated hemoglobin exposure data

Glycated hemoglobin data was reported as HbA1c in 60, as HbA1 in 34, and as total GHb in 18. All randomized controlled trials reported glycated hemoglobin exposure data as HbA1c. The glycated hemoglobin assay method was DCCT traceable in 16 studies and was not DCCT traceable or not stated in the remainder of the studies. A variety of biochemical measurement methods were used; however, the most common method was HPLC.

### Outcome Specific data

#### Cohort studies reporting on retinopathy outcomes

Incidence of Retinopathy

[underlined: Type 1 diabetes] (Table 6)

Thirteen cohort studies evaluated the relation between glycated hemoglobin and incident retinopathy in individuals with type 1 diabetes. Seven of these studies measured HbA1c. The followup of these studies ranged from 1.3 to 20 years and included 197 to 1273 individuals (Chaturvedi, et al. 2001 [140]; Bojestig, et al. 1998 [460]; The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial 1996 [718]; Chase, et al. 1989 [1444]; Zhang, et al. 2001 [1833]; Klein, et al. 1997 [2270]; Bonney, et al. 1995 [2379]). The incidence of retinopathy over the followup periods increased with increasing HbA1c, from 1.9 percent to 55.0 percent over 20 years (HbA1c≤8.1 vs. HbA1c≥9.5 percent) (Bojestig, et al. 1998 [460]), 27 percent to 41 percent over 8 years (HbA1c≤10.8 vs. HbA1c≥12.4 percent) (Chase, et al. 1989 [1444]), 0 percent to 1.8 percent over 6.5 years (HbA1c<6.17 vs. >9.49 percent) (Zhang, et al. 2001 [1833]) and 3.4 percent to 10.5 percent over 4 years (HbA1c≤11.9 vs. HbA1c≥12.0 percent) (Klein, et al. 1997 [2270]). In one study, there was a 93 percent increased risk of developing retinopathy for each 1 percent increase over 7.3 years of followup in a population with an average HbA1c of approximately 6.33 percent (RR=1.93; 95 percent CI: 1.52 to 2.44) (Chaturvedi, et al. 2001 [140]). The mean age and duration of diabetes in this study were approximately 29.5 years and 10 years, respectively (see Table 2). In another study, the risk of developing retinopathy over 1.3 years was fourfold greater in individuals with a HbA1c≥8.4 percent, following multivariate adjustment (RR=4.02; 95 percent CI: 2.13 to 7.58) (Bonney, et al. 1995 [2379]). The mean age of this population ranged from 14.6 to 16 years and diabetes duration ranged from 4.8 to 15.2 years (see Table 2). In one followup study from a previous clinical trial, the RRR of retinopathy for a 10 percent change in HbA1c was 37 percent for the whole cohort (The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial 1996 [718]). The RRR was greatest among individuals previously randomized to conventional group with a HbA1c>8 percent (RRR=41 percent; 95 percent CI: 30 to 50) compared to those previously randomized to intensive control group with a HbA1c<8 percent (RRR=26 percent; 95 percent CI: 2 to 44). (The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial 1996 [718]). There was no evidence of a threshold effect of the relation between HbA1c and incident retinopathy in either the primary or secondary prevention cohorts. The mean age of this study population was 7 years and the average diabetes duration was 2.6 years in the primary prevention cohort and approximately 8.8 years in the secondary prevention cohort (see Table 2).

Four studies evaluated the relation between HbA1 and incidence of retinopathy. These studies included 66 to 765 individuals followed for 3 to 13 years (d'Annunzio, et al. 1997 [587]; Danne, et al. 1994 [934]; Kovacs, et al. 1995 [2372]; Klein, et al. 1994 [2458]). The incidence of retinopathy over the followup periods increased with increasing HbA1, from 1.0 percent to 5.4 percent over 13 years (HbA1≤8 vs. HbA1≥10.1 percent) (Danne, et al. 1994 [934]) and from 80 percent to 98 percent over 10 years (HbA1≤9.4 percent vs. HbA1≥12.1 percent) (Klein, et al. 1994 [2458]). In one study, compared to individuals with HbA1 ≤7.0 individuals with HbA1 between 7.1 and 9.0 were over twice as likely to develop retinopathy (RH: 2.39; 95 percent CI: 0.54 to 10.51) and those with HbA1 >9 were nearly 8-times as likely to develop retinopathy (RH=7.71; 95 percent CI: 1.65, 36.12) over 3 years of followup (d'Annunzio, et al. 1997 [587]). The mean age of the study population was 8.3 years (see Table 2). In this same study, where the mean HbA1 level of the population was 7.7 percent, there was a 2- to threefold increased risk of retinopathy for each 1 percent increase in HbA1 following multivariate adjustment (d'Annunzio, et al. 1997 [587]). Similarly, another study showed a significantly increased risk of retinopathy in individuals with HbA1≥14.3 compared to those with HbA1 levels below this cut-point (coefficient of linear regression=6.051, p<0.001) (Kovacs, et al. 1995 [2372]).

In one study, the glycated hemoglobin exposure variable was total GHb. In this study, there was a 40 percent increased risk of incident retinopathy for each 1 percent increase in total GHb in a population with an average total GHb of 12.5 percent (Klein, et al. 1988 [2832]).

[underlined: Type 2 diabetes] (Table 7)

There were 14 cohort studies examining the relation between glycated hemoglobin and incident retinopathy in individuals with type 2 diabetes. Six studies examined the relation between HbA1c and incident retinopathy. The followup ranged between 2.3 and 10 years in 85 to 1919 individual (Molyneaux, et al. 1998 [424]; Stratton, et al. 2001 [1863]; Voutilainen-Kaunisto, et al. 2001 [1867]; Okudaira, et al. 2000 [1899]) (Nakagami, et al. 1997 [2259]; Chen, et al. 1995 [2392]). As for type 1 diabetes, the incidence of retinopathy over the followup periods increased with increasing HbA1c among individuals with type 2 diabetes, from 18.4 percent to 47.4 percent over 10 years (HbA1c≤8.1 vs. HbA1c≥9.7 percent) (Voutilainen-Kaunisto, et al. 2001 [1867]), 0 percent to 54.8 percent over 10 years (HbA1c≤5.9 vs. HbA1c≥9 percent) (Nakagami, et al. 1997 [2259]), and 8.4 percent to 40 percent over 4 years (HbA1c≤6.18 vs. HbA1c≥8.4 percent) (Chen, et al. 1995 [2392]). One study estimated a 24 percent relative risk reduction for a 1.1 unit decrease in HbA1c in a population with mean HbA1c of 9.5 percent, a mean age of 54.9 years, and average diabetes duration of 3.8 years over 2.3 years of followup (RRR=24 percent; 95 percent CI: 16 to 32 percent) (Molyneaux, et al. 1998 [424]) and another study estimated a 25 percent increased risk of incident retinopathy over 5.4 years for each 1 percent increase in HbA1c in a population with a mean HbA1c of 8.5 percent (RH=1.25; 95 percent CI: 1.12 to 1.39) (Okudaira, et al. 2000 [1899]). This relation persisted following multivariate adjustment (Okudaira, et al. 2000 [1899]). The mean age was 26.9 years and the average diabetes duration was 4.4 years (see Table 2). In another study, in which the mean age of the study population was 52.2 years, there was a two-fold increased risk of retinopathy over 6 years in individuals with a HbA1c≥7.5 percent compared to those individuals with HbA1c≤6.2 percent (RR=2.5; 95 percent CI: 2.0 to 3.2) (Stratton, et al. 2001 [1863]).

Four cohort studies examined the relation between HbA1 and incident retinopathy. These studies contained 64 and 834 individuals followed for 5 to 13 years (Guillausseau, et al. 1998 [556]; Kim, et al. 1998 [2171]; Klein, et al. 1994 [2458]; Araki, et al. 1993 [2535]). The incidence rate of retinopathy ranged from 5.1 percent to 37 percent over 5 years (HbA1≤8.5 vs. HbA1≥11.7 percent) (Kim, et al. 1998 [2171]), from 70 percent to 100 percent over 10 years in individuals using insulin (HbA1≤8.8 vs. HbA1≥11.6 percent) (Klein, et al. 1994 [2458]), and from 47 percent to 90 percent over 10 years in individuals not using insulin (HbA1≤7.6 vs. HbA1≥10.1 percent) (Klein, et al. 1994 [2458]). In one study, the incidence rate of retinopathy over 5 years was twice as high in individuals with a HbA1≥8 percent compared to those with a HbA1 below 8 percent (82.8 percent vs. 40.2 percent) and individuals with a HbA1≥8 percent were 54 percent more likely to develop retinopathy (RR=1.54; 95 percent CI: 1.20, 1.98) over 5 years (Araki, et al. 1993 [2535]). In another study, in individuals with an HbA1>8.4 percent the risk of developing retinopathy was two-fold greater than those with HbA1 below 8.4 percent (RR=2.5; 95 percent CI: 0.8, 8.0) (Guillausseau, et al. 1998 [556]). In these studies, the mean ages were 35 (Guillausseau, et al. 1998 [556]) and 69.2 (Araki, et al. 1993 [2535]) years and the average diabetes duration were 7.5 (Guillausseau, et al. 1998 [556]) and 6.9 (Araki, et al. 1993 [2535]) years (see Table 2). In individuals with type 2 diabetes who were using insulin, the risk of retinopathy increased 30 percent for each 1 percent increase in HbA1 (OR=1.3; 95 percent CI: 1.1 to 1.6), whereas in individuals not using insulin, there was a 60 percent increase in the risk of retinopathy for each 1 percent increase in HbA1 (OR=1.6; 95 percent CI: 1.4 to 1.8) (Klein, et al. 1994 [2458]).

Three cohort studies examined the relation between total GHb and incident retinopathy in individuals with type 2 diabetes and similarly found a 20–78 percent increased risk of retinopathy for a 1 percent increase in HbA1c, depending on which factors were considered in multivariate adjustment (Florkowski, et al. 1998 [481]; Tudor, et al. 1998 [2173]; Klein, et al. 1988 [2832]). These studies included 169 to 1780 individuals followed for 4 to 6 years (Florkowski, et al. 1998 [481]; Tudor, et al. 1998 [2173]; Klein, et al. 1988 [2832]). The mean age of the populations in one study was 57 years and the average diabetes duration was 4 year (Tudor, et al. 1998 [2173]) (see Table 2).

##### Incidence of Proliferative Retinopathy and/or Macular Edema

[underlined: Type 1 diabetes] (Table 8)

Fifteen cohort studies in individuals with type 1 diabetes evaluated the relation between glycated hemoglobin and incidence of proliferative retinopathy and/or macular edema. Seven of these studies examined the relation between HbA1c and incidence of proliferative retinopathy/macular edema. The study followup ranged from 4 to 7.3 years with 175 to 1249 individuals (White, et al. 2001 [19]; Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]; Porta, et al. 2001 [1769]; Vitale, et al. 1997 [2282]; Yokoyama, et al. 1995 [2386]; Vitale, et al. 1995 [2391]; Lloyd, et al. 1996 [777]). In two studies that reported followup data on cohorts of individuals from previous clinical trials, the incidence of macular edema, proliferative retinopathy, and focal or scatter laser therapy was lower in individuals previously randomized to intensive glycemic control compared to the former conventional therapy groups, despite the HbA1c values being similar between the two groups during post-trial followup (White, et al. 2001 [19]; Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]). In these two studies, the mean ages were approximately 27 (White, et al. 2001 [19]) and 33.5 years (Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]) and the average durations of diabetes were approximately 4 months (White, et al. 2001 [19]) and 12 years (Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]) (see Table 2). In one of these studies, individuals in the previous intensive therapy group, where the median HbA1c over followup was 7.9 percent, the RRRs of macular edema, proliferative retinopathy, and scatter or focal laser therapy were 77 percent (95 percent CI: 52 to 89 percent), 74 percent (95 percent CI: 46 to 87), and 77 percent (95 percent CI: 45 to 91 percent), respectively (Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]). In three studies the mean/median HbA1c's of the study populations, approximately 6.5 percent, 12 percent, and 12.2 percent, were associated with a threefold (OR=3.03; 95 percent CI: 2.49 to 3.69) (Porta, et al. 2001 [1769]), 26 percent (RH=1.26; 95 percent CI: 1.05 to1.51) (Vitale, et al. 1997 [2282]), and 44 percent (1.44; 95 percent CI: 1.28 to 1.63) (Vitale, et al. 1995 [2391]) increased risk of developing proliferative retinopathy, respectively. In these studies, the mean ages were 31 years (Porta, et al. 2001 [1769]), 17 years (Vitale, et al. 1997 [2282]), and 14 years (Vitale, et al. 1995 [2391]) and in two studies, the average diabetes durations were 13 years (Porta, et al. 2001 [1769]) and 7 years (Vitale, et al. 1997 [2282]) (see Table 2). In one study, the risk of proliferative retinopathy was nearly eightfold greater in individuals with HbA1c≥10.3 percent compared to those with HbA1c≤8.1 percent (Yokoyama, et al. 1995 [2386]) and in another study, the risk was nearly 4-fold greater in individuals with HbA1c≥7.6 percent compared to those with HbA1c≤7.5 percent (Lloyd, et al. 1996 [777]).

Five studies examined the relation between HbA1 and risk of proliferative retinopathy/macular edema. These studies included 312 to 765 individuals followed for 2 to 14 years (Klein, et al. 1996 [809]; Lloyd, et al. 1995 [870]; Klein, et al. 1998 [2108]; Arfken, et al. 1998 [2157]; Klein, et al. 1994 [2458]). The cumulative incidences of proliferative retinopathy and macular edema increased with increasing quartiles of HbA1, from 12.7 percent to 36.8 percent over 14 years of follow for macular edema (HbA1≤9.4 percent vs. HbA1≥12.1 percent) (Klein, et al. 1998 [2108]) and from approximately 10 percent to approximately 50 percent over 10 to 14 years of followup for proliferative retinopathy (HbA1≤9.4 percent vs. HbA1≥12.1 percent) (Klein, et al. 1998 [2108]; Klein, et al. 1994 [2458]). In one study, there was a reduced odds of incident macular edema (OR=0.53; 95 percent CI: 0.43 to 0.66) and proliferative retinopathy (OR=0.58; 95 percent CI: 0.48 to 0.72) for a 2 unit change in HbA1 in a population with an average HbA1 of 10.8 percent (Klein, et al. 1996 [809]). These individuals had a mean age of 29.3 years and an average diabetes duration of 14.7 years (see Table 2). The risk of developing proliferative retinopathy was fourfold greater in individuals with HbA1 levels above approximately 11 percent compared to those with HbA1 level below approximately 9 percent (Lloyd, et al. 1995 [870]; Klein, et al. 1998 [2108]) and in one study, the risk of proliferative retinopathy was sevenfold greater in individuals with a HbA1>approximately 12 percent compared to those with a level below approximately 9 percent (Klein, et al. 1994 [2458]). In two of these studies, the mean ages of these study populations were 27.8 years (Lloyd, et al. 1995 [870]) and 11.2 years (Klein, et al. 1998 [2108]), and the average diabetes durations were 19.4 years (Lloyd, et al. 1995 [870]) and 12.6 years (Klein, et al. 1998 [2108]) (see Table 2). In another study, with a mean age of approximately 24 years, there was nearly a two-fold increased risk of proliferative retinopathy for each 2 unit change in HbA1 in a population with an average HbA1 of 10.4 percent (OR=1.92; 95 percent CI: 1.36 to 2.70) (Arfken, et al. 1998 [2157]). The risk of developing macular edema was not as great as that for developing proliferative retinopathy (RR=1.49; 95 percent CI: 1.34 to 1.65 for 1 percent increase in HbA1 for macular edema vs. RR=1.86; 95 percent CI: 1.67 to 2.08 for 1 percent increase in HbA1 for proliferative retinopathy in multivariate analyses) (Klein, et al. 1998 [2108]).

In three studies, the glycated hemoglobin exposure variable was total GHb and these studies included 610 to 1780 individuals followed for 4 to 10 years (Klein, et al. 1995 [2437]; Klein, et al. 1989 [2787]; Klein, et al. 1988 [2832]). The odds of macular edema increased with increasing quartiles of total GHb, with a fourfold increased risk in individuals with a total GHb≥12.1 percent compared to those with a GHb≤9.4 percent in one study (OR=4.0; 95 percent CI: 2.2 to 7.1) (Klein, et al. 1995 [2437]) and a nine fold increased risk in individuals with a GHb≥14.2 percent compared to those with a GHb≤10.8 in another study (OR=8.9; 95 percent CI: 2.7 to 29.4) (Klein, et al. 1989 [2787]). In two studies, there was approximately 50 percent increased risk of macular edema and proliferative retinopathy for each 1 percent increase in HbA1 following multivariate adjustmen (Klein, et al. 1995 [2437]; Klein, et al. 1988 [2832]).

[underlined: Type 2 diabetes] (Table 9)

Ten cohort studies examined the relation between glycated hemoglobin and incidence of proliferative retinopathy and macular edema in individuals with type 2 diabetes. In four studies, the glycated hemoglobin exposure variable was HbA1c and these studies included 137 to 1919 individuals followed for 4 to 10 years (Stratton, et al. 2001 [1863]; Okudaira, et al. 2000 [1899]; Nakagami, et al. 1997 [2259]; Chen, et al. 1995 [2392]). In one study, the cumulative incidence over 4 years ranged from 0 percent at HbA1c≤6.18 percent to 9.3 percent at HbA1c≥8.41 percent (Chen, et al. 1995 [2392]). The risk of proliferative retinopathy was eightfold higher in individuals with HbA1c≥7.5 percent compared to individuals in the lowest tertile (HbA1c≤6.2 percent; RR=8.1; 95 percent CI: 6.3 to 10.5) (Stratton, et al. 2001 [1863]). This study population had a mean age of 52 years (see Table 2). In another study, the risk of proliferative retinopathy increased 50 percent for each 1 percent increase in HbA1c in a population with a mean HbA1c of 8.5 percent (RH=1.5; 95 percent CI: 1.31 to 1.74), which persisted following multivariate adjustment (RH=1.67; 95 percent CI: 1.41 to 1.97) (Okudaira, et al. 2000 [1899]). The mean age of these participants was 26.9 years and the average diabetes duration was 4.4 years (see Table 2).

In three studies, the glycated hemoglobin exposure variable was HbA1. These studies included 56 to 834 individuals followed for 5 to 10 years (Klein, et al. 1996 [809]; Kim, et al. 1998 [92171]; Klein, et al. 1994 [2458]). The cumulative incidence of proliferative retinopathy increased from 0 percent to 39 percent over 5 years (HbA1≤8.5 percent vs. HbA1≥11.7 percent) (Kim, et al. 1998 [92171]), from 12 percent to 38 percent over 10 years in individuals using insulin (HbA1≤8.8 percent vs. HbA1≥11.6 percent) (Klein, et al. 1994 [2458]), and from 2 percent to 30 percent over 10 years in individuals not using insulin (HbA1≤7.6 percent vs. HbA1≥10.1 percent) (Klein, et al. 1994 [2458]).One study demonstrated a 31 percent lower odds of proliferative retinopathy for each 2 unit change in HbA1 in individuals using insulin (OR=0.69; 95 percent CI: 0.47 to 1.04) and a 38 percent lower odds of macular edema (OR=0.62; 95 percent CI: 0.43 to 0.89) and a 50 percent lower odds of proliferative retinopathy (OR=0.50; 95 percent CI: 0.33 to 0.78) for each 2 unit change in HbA1 in individuals not using insulin (Klein, et al. 1996 [809]). There was not a significant relation between HbA1 and risk of macular edema among individuals using insulin in this study (Klein, et al. 1996 [809]). The mean age of study participants using insulin was 65.2 years and their average diabetes duration was 15 years (see Table 2). The mean age of the study participants not using insulin was 68 years and their average diabetes duration was 8.8 years (see Table 2). Another study showed a nearly 30 percent increased risk of proliferative retinopathy for each 1 percent change in HbA1 in a population with an average HbA1 of approximately 12 percent, a mean age of approximately 55 years, and an average diabetes duration of approximately 9 years (Kim, et al. 1998 [92171]). Similarly, among users of insulin in one study, there was a 50 percent increased risk of proliferative retinopathy (OR=1.5 percent; 95 percent CI: 1.2 to 1.9) and among non-users of insulin, there was a 90 percent increased risk of retinopathy (OR=1.9; 95 percent CI: 1.5 to 2.5) (Klein, et al. 1994 [2458]).

Three cohort studies used total GHb as the exposure variable and included 652 to 1780 individuals followed for 4 to 10 years (Klein, et al. 1995 [2437]; Klein, et al. 1989 [2787]; Klein, et al. 1988 [2832]). The risk of proliferative retinopathy/macular edema increased with increasing GHb and individuals in the highest quartile were nearly 14 times more likely to develop macular edema compared to those in the lowest quartile in one study (GHb≥10.9 percent vs. GHb≤8.1 percent; OR=13.7; 95 percent CI: 6.8 to 27.8) (Klein, et al. 1995 [2437]) and 12 times more likely to develop macular edema in another study (GHb≥12.7 percent vs. GHb≤9.2 percent; OR=12.5; 95 percent CI: 3.0 to 51.8) (Klein, et al. 1989 [2787]). Among individuals using insulin, the risk of proliferative retinopathy increased 30 percent for each 1 percent increase in GHb (OR=1.3; 95 percent CI: 1.0 to 1.6) (Klein, et al. 1988 [2832]).

##### Progression of Retinopathy

[underlined: Type 1 diabetes] (Table 10)

There were 16 cohort studies that examined the relation between glycated hemoglobin and progression of retinopathy in individuals with type 1 diabetes. In 8 studies, the glycated hemoglobin exposure was reported as HbA1c and they included 61 to 1177 individuals over 4 to 8 years of followup (White, et al. 2001 [19]; Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]; The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial 1996 [718]; Reichard 1992 [1188]; Zhang, et al. 2001 [1833]; Chase, et al. 1989 [1444]; Janka, et al. 1989 [2809]; Waltman1984 [3029]). There was an increase in the cumulative incidence of retinopathy progression with increasing levels of HbA1c, from 9.8 to 22.9 percent over 7 years (HbA1c≤6.17 percent vs. HbA1c≥9.49 percent) (Zhang, et al. 2001 [1833]), 15 percent to 37 percent over 8 years (HbA1c≤10.8 percent vs. HbA1c≥12.4 percent) (Chase, et al. 1989 [1444]), 2.9 percent to 44.4 percent over 4 years (HbA1c≤8.3 percent vs. HbA1c≥9.9 percent) (Janka, et al. 1989 [2809]), and 19 percent to 34 percent over 5 years (HbA1c≤8.4 percent vs. HbA1c≥8.5 percent) (Waltman1984 [3029]). Two studies demonstrated significant risk reductions of 77 percent (95 percent CI: 39 to 92 percent) (White, et al. 2001 [19]) and 75 percent (95 percent CI: 64 to 83 percent) (Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]) in progression of retinopathy over four years in followup studies of individuals previously randomized to intensive glycemic control, despite the fact that the HbA1cs were similar at the end of the 4-year post-trial followup. The mean age of these study populations were 27 years (White, et al. 2001 [19]) and approximately 33.5 years (Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]) and the average diabetes durations were approximately 17 years (White, et al. 2001 [19]) and 12 years (Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]) (see Table 2). In one followup study of 6.5 years following a clinical trial of randomization to intensive or conventional control, the RRR was 39 percent (95 percent CI: 34 percent to 44 percent) in the whole cohort (HbA1c approximately 8 percent) for a 10 percent change in HbA1c for a population with a mean age of 27 years and an average diabetes duration of 2.6 years in the primary prevention cohort and approximately 8.8 years in the secondary prevention cohort (The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial 1996 [718]) (See Table 2). There were comparable risk reductions in progression to proliferative retinopathy (White, et al. 2001 [19]; Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]). Similarly, another study showed a significant relative odds reduction of retinopathy progression in individuals with HbA1c<8.9 percent compared to those above this cut-point (ROR=0.10; 95 percent CI: 0.01 to 0.90) (Reichard1992 [1188]). The mean age of these study participants was 30.1 years and the average diabetes duration was 17 years (see Table 2). In one study, there was a 26-fold increased risk of retinopathy progression in individuals in the higher quartile of HbA1c compared to those in the lowest quartile (Janka, et al. 1989 [2809]). The mean age of these participants was approximately 38.4 years and the average diabetes duration was approximately 26 years (see Table 2).

Five studies on progression of retinopathy reported glycated hemoglobin exposure as HbA1. These studies included 277 to 765 individuals and the followup ranged from 2 to14 years (Lloyd, et al. 1995 [870]; Klein, et al. 1998 [2108]; Marshall, et al. 1993 [2537]; Sawicki, et al. 2000 [289]; Klein, et al. 1994 [2458]). In three studies, the risk of proliferative retinopathy was 2.3, 2.64, and 2.9 times higher in the highest quartiles of HbA1≥11.2 percent and≥12.1 percent, respectively, compared to the lowest quartiles (Lloyd, et al. 1995 [870]; Klein, et al. 1998 [2108]; Klein, et al. 1994 [2458]). In two studies, the mean ages were 27.8 years (Lloyd, et al. 1995 [870]) and 11.2 years (Klein, et al. 1998 [2108]) and the average diabetes durations were 19.4 years (Lloyd, et al. 1995 [870]) and 12.6 years (Klein, et al. 1998 [2108]) (see Table 2). In multivariate analyses, the risk of retinopathy progression was increased 20–70 percent with a 1 percent increase in HbA1 (Lloyd, et al. 1995 [870]; Sawicki, et al. 2000 [289]; Marshall, et al. 1993 [2537]; Klein, et al. 1994 [2458]). The mean ages of these participants were 19.4 years (Lloyd, et al. 1995 [870]), 26.4 years (Sawicki, et al. 2000 [289]), and 17.9 years (Marshall, et al. 1993 [2537]) and the average diabetes durations were 19.4 years (Lloyd, et al. 1995 [870]), 8.4 years (Sawicki, et al. 2000 [289]), and 9.7 years (Marshall, et al. 1993 [2537]) (see Table 2).

In two studies on the progression of retinopathy, the glycated hemoglobin exposure variable was total GHb. These studies included 485 and 1780 individuals followed for 3.4 and 4 years, respectively (Cohen, et al. 1999 [2039]; Klein, et al. 1988 [2832]). In one study, the risk of retinopathy progression was fourfold greater in individuals with a total GHb>13.6 percent compared to those in the lowest quartile (total GHb<10 percent) (Cohen, et al. 1999 [2039]). The mean age of this study population was 31.5 years and the average diabetes duration was 6.5 years (see Table 2). In another study, the risk of retinopathy progression increased 50 percent for each 1 percent increase in GHb, following multivariate adjustment in a population with an average total GHb of 12.6 percent (OR=1.5; 95 percent CI: 1.3 to 1.6) (Klein, et al. 1988 [2832]).

[underlined: Type 2 diabetes] (Table 11)

Seven cohort studies examined the relation between glycated hemoglobin and progression of retinopathy among individuals with type 2 diabetes. In five of these studies, the glycated hemoglobin exposure variable was HbA1c. These studies included 114 to 1378 individuals and followup ranged from 3.1 to 7 years (Yoshida, et al. 2001 [1864]; Okudaira, et al. 2000 [1899]; Henricsson, et al. 1997 [2281]; Chen, et al. 1995 [2392]; Morisaki, et al. 1994 [2502]). The cumulative incidence rates ranged from 17.7 percent to 43.1 percent (HbA1c≤6.18 vs. HbA1c≥8.41 percent) over 4 years of followup in one study (Chen, et al. 1995 [2392]) and from 2 percent to 61 percent (HbA1c≤6.9 vs. HbA1c≥9 percent) over 5 years of followup in another study (Morisaki, et al. 1994 [2502]). In two studies, following multivariate adjustment, the risk of retinopathy progression was increased by 42 percent and 47 percent for each 1 percent increase in HbA1c over 5.7 and 7 years of followup, respectively, in populations with a mean HbA1c of 8.5 to 8.6 percent (Yoshida, et al. 2001 [1864]; Okudaira, et al. 2000 [1899]). The mean ages of these study populations were 53.6 years (Yoshida, et al. 2001 [1864]) and 26.9 years (Okudaira, et al. 2000 [1899]) and the average diabetes durations were 8 years (Yoshida, et al. 2001 [1864]) and 4.4 years (Okudaira, et al. 2000 [1899])(see Table 2). In another study, in which the average diabetes duration was approximately 8 years, individuals with a HbA1c≥7.24 percent were 74 percent more likely to have progression of retinopathy over 3 years of followup compared to their counterparts with HbA1c below this cut-point (RR=1.74; 95 percent CI: 1.42 to 2.13) (Henricsson, et al. 1997 [2281]).

One study examined the relation between HbA1 and progression of retinopathy (Klein, et al. 1994 [2458]). In this study, the cumulative incidence of retinopathy progression increased with increasing quartiles of HbA1 in individuals using insulin and in those not using insulin. Among insulin users, the risk of retinopathy progression was twofold higher in those in the highest quartile of HbA1 (≥11.6 percent) compared to those in the lowest quartile (≤8.8 percent) (RR=2.1; 95 percent CI: 1.6 to 2.8) and there was a 40 percent increased risk for each 1 percent change in HbA1 (Klein, et al. 1994 [2458]). Among non-users of insulin, the risk of retinopathy progression was fourfold higher in those in the highest quartile of HbA1 (≥10.1 percent) compared to those in the lowest quartile (≤7.6 percent) (RR=4.3; 95 percent CI: 3.0 to 6.2) and there was an 80 percent increased risk for each 1 percent increase in HbA1 (Klein, et al. 1994 [2458]).

One study examined the relation between total GHb and retinopathy progression over 4 years of followup (Klein, et al. 1988 [2832]). The risk was increased by 30 percent for each 1 percent increase in GHb in individuals using insulin whose average GHb was 11.8 percent and was increased by 40 percent for each 1 percent increase in GHb in individuals not using insulin whose average GHb was 10.2 percent (Klein, et al. 1988 [2832]).

##### Blindness/Visual acuity

[underlined: Type 1 diabetes] (Table 12)

There were five cohort studies examining incidence of blindness and changes in visual acuity in individuals with type 1 diabetes. In one study of 3674 individuals over 10 years of followup, the incidence of blindness was 0.5 percent among normoalbuminuric individuals with a mean HbA1c of 8.1 percent, a mean age of 26.1 years, and average diabetes duration of 8.4 years, and increased to 5.8 percent among macroalbuminuric individuals with a mean HbA1c of 8.4 percent, a mean age of 33.5 years, and an average diabetes duration of 19.7 years (Muhlhauser, et al. 2000 [185]).

Two cohort studies evaluated the relation between HbA1 and incidence of blindness and included 3570 and 634 individuals over 10 and 14 years of followup, respectively (Muhlhauser, et al. 2000 [178]; Moss, et al. 1998 [2145]). Incidence of blindness ranged from 0.6 percent to 2.1 percent (HbA1c≤7 vs. HbA1c≥9) in one study with a mean age of 27.5 years and an average diabetes duration of 22 years (Muhlhauser, et al. 2000 [178]) and from 5.6 percent to 22 percent (HbA1c≤10.8 vs. HbA1c≥14.1 percent) in another study with a mean age of 26.8 years and an average diabetes duration of 12.6 years (Moss, et al. 1998 [2145]). In one of these studies, following multivariate adjustment, the risk of blindness over 14 years increased 46 percent for each 1 percent increase in HbA1 in a population with a mean HbA1 of 10.6 percent (OR=1.46; 95 percent CI: 1.28 to 1.66) (Moss, et al. 1998 [2145]).

One study examined the relation between total GHb and risk of doubling of the visual angle over 10 years and found that the cumulative incidence increased with increasing GHb. In this study, there was a 28 percent increased risk of decline in visual acuity for each 1 percent increase in GHb (OR=1.28; 95 percent CI: 1.15 to 1.42) (Moss, et al. 1994 [2482]).

[underlined: Type 2 diabetes] (Table 13)

One cohort study examined the relation between total GHb and the risk of doubling of visual angle in individuals with type 2 diabetes. The cumulative incidence of worsening visual acuity increased with increasing quartiles of GHb over 10 years of followup (Moss, et al. 1994 [2482]).

##### Cataract extraction (Table 14)

One cohort study examined the relation between glycated hemoglobin and the risk of cataract extraction in individuals with type 2 diabetes (Stratton, et al. 2000 [4087]). In this study, the RRR for cataract extraction was 9 percent to 19 percent for each 1 percent decrease in HbA1c, depending on multivariate adjustment, in a population with a mean age of 53 years (Stratton, et al. 2000 [4087]). There were no cohort studies identified by our search strategy examining the relation between glycated hemoglobin and the risk of cataract extraction in individuals with type 1 diabetes.

#### Randomized controlled trials reporting retinopathy outcomes

##### Incidence of Retinopathy

[underlined: Type 1 diabetes] (Table 15)

There were 3 clinical trials of intensive versus conventional glycemic control that reported the incidence of retinopathy. These studies included 102 to 1441 individuals over 4 to 7.5 years of followup (Gaede, et al. 1999 [416]; Reichard, et al. 1993 [1069] The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group 1993 [4638]). In one study, the RRR for incident proliferative retinopathy was 47 percent in individuals randomized to intensive glycemic control where the mean HbA1c during followup was approximately 7 percent, compared to those in the conventional control group where the HbA1c was approximately 9 percent (The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group 1993 [4638]). The mean ages in the intensive and conventional therapy groups were 27 and 26.5 years, respectively (see Table 3). In one study, the risk of incident retinopathy was nearly threefold for each 1 percent increase in HbA1c (conventional group: HbA1c=8.7 percent, mean age 32 years, average diabetes duration 16 years and intensive group: HbA1c=7.2 percent, mean age 30 years, average diabetes duration 18 years) (OR=2.9; 95 percent CI: 1.5 to 5.7) (Reichard, et al. 1993 [1069]).

[underlined: Type 2 diabetes] (Table 16)

There were two clinical trials conducted in individuals with type 2 diabetes that examined the relation between glycemic control and incident retinopathy, which included 106 and102 individuals over 4 and 6 years of followup, respectively (Ohkubo, et al. 1995 [888]). In one study, the cumulative incidence of retinopathy was lower in the intensively treated group, with a mean HbA1c of 8.4 percent, than in the standard treatment groups, with a mean HbA1c of 8.8 percent (Gaede, et al. 1999 [416]). The participants in this study had a mean age of approximately 55 years and median diabetes duration of 5.5 to 6 years (Gaede, et al. 1999 [416]). In another study, the incidence of retinopathy was lower in the intensively controlled group, which maintained a HbA1c of approximately 7.1 percent (mean age 50.5 years, average diabetes duration approximately 10 years), compared to the conventional group, which maintained a HbA1c of approximately 9.4 percent (mean age 48 years, average diabetes duration approximately 6.4 years)(7.7 percent vs. 32 percent) (Ohkubo, et al. 1995 [888]).

##### Incidence of Proliferative Retinopathy/Macular Edema

[underlined: Type 1 diabetes] (Table 17)

There were 2 clinical trials conducted in individuals with type 1 diabetes that evaluated the relation between tight glycemic control and incidence of proliferative retinopathy and/or macular edema. The study sizes ranged from 89 to 1441 with 6.5–7.5 years of followup (Reichard, et al. 1993 [1069] ;The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group 1993 [4638]). The incidence rate for individuals randomized to intensive control was 27 percent among individuals with mean HbA1c level of 7.2 percent, compared to individuals randomized to conventional control, where the incidence rate was 52 percent among individuals with a mean HbA1c level of 8.7 percent (Reichard, et al. 1993 [1069]). The mean age of individuals in the conventional therapy group was 32 years and in the intensive therapy groups was 30 years (Reichard, et al. 1993 [1069]). The average duration of diabetes in this study was 16 to 18 years (Reichard, et al. 1993 [1069]) (see Table 3). In another study, there was a non-significant RRR for intensive control, where the HbA1c over followup was approximately 7 percent, compared to conventional control, where the HbA1c was approximately 9 percent (RRR=23 percent; 95 percent CI: -13 to 48) (The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group 1993 [4638]).

[underlined: Type 2 diabetes] (Table 18)

There were three clinical trials of glycemic control and incidence of proliferative retinopathy in individuals with type 2 diabetes. These studies included 110 to 4209 individuals over 4 to 10 years of followup, respectively (Shichiri, et al. 2000 [247]; Gaede, et al. 1999 [416]; Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]). In one study, the incidence rate for individuals randomized to intensive control was 9.1 percent among individuals with mean HbA1c level of 8.4 percent, compared to individuals randomized to conventional control, where the incidence rate was 12 percent among individuals with a mean HbA1c level of 8.8 percent (Gaede, et al. 1999 [416]). The RRRs for proliferative retinopathy were 50 percent (Shichiri, et al. 2000 [247]) and 39 percent (Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]) in these two studies, respectively, for individuals randomized to intensive vs. conventional glycemic control. For one study, the median HbA1c over followup was 7.0 for the intensive group compared to 7.9 for the conventional group (Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]). The mean ages in the conventional therapy groups were 49 to 53 years (Shichiri, et al. 2000 [247]) and 53.4 years (Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]) and in the intensive therapy groups, they were 47 to 49 years (Shichiri, et al. 2000 [247]) and 53.2 years (Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]) (see Table 3). In one study, the median diabetes duration was approximately 6 years in the primary prevention cohort and 10 years in the secondary prevention cohort

(Shichiri, et al. 2000 [247]) (see Table 3). Participants in the UKPDS trial were all newlydiagnosed with diabetes.

##### Progression of Retinopathy

[underlined: Type 1 diabetes] (Table 19)

There were 4 clinical trials evaluating the relation between intensive glycemic control and progression of retinopathy in individuals with type 1 diabetes. These studies included 96 to 1441 individuals who were followed for 4 to 7 years (Gaede, et al. 1999 [416]; Reichard, et al. 1991 [1266]; The effect of intensive diabetes treatment on the progression of diabetic retinopathy in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial 1995 [2438]; The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group1993 [4638]). The RRRs for intensive vs. conventional glycemic control ranged from 39 to 79 percent (Gaede, et al. 1999 [416]; The effect of intensive diabetes treatment on the progression of diabetic retinopathy in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial 1995 [2438]; The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group1993 [4638]). The HbA1cs for these studies ranged from approximately 7 to 8 percent in the intensive groups and from 8.7 to 9 percent in the conventional groups (Gaede, et al. 1999 [416]; The effect of intensive diabetes treatment on the progression of diabetic retinopathy in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial 1995 [2438]; The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group 1993 [4638]). In one study, there was an approximately twofold increased risk of progression of retinopathy for a 1 percent increase in HbA1c (Reichard, et al. 1991 [1266]).

[underlined: Type 2 diabetes] (Table 20)

Three clinical trials evaluated the relation between tight glycemic control and progression of retinopathy in type 2 diabetes. These studies included 110 to 160 individuals followed over 4 to 8 years of followup, respectively (Shichiri, et al. 2000 [247]; Gaede, et al. 1999 [416]; Ohkubo, et al. 1995 [888]). In one study, the RRR for intensive therapy vs. conventional therapy was 68 percent for the primary prevention cohort and 57 percent for the secondary prevention cohort (Shichiri, et al. 2000 [247]). In another study, the ROR for progression of retinopathy in intensive group vs. the standard group was 55 percent (Gaede, et al. 1999 [416]). The incidences of retinopathy progression in the conventional groups ranged from 38–56 percent compared to lower incidence rates in the intensive therapy groups of 13.4–24 percent (Shichiri, et al. 2000 [247]) (Ohkubo, et al. 1995 [888]).

##### Blindness/Visual Acuity

[underlined: Type 1 diabetes] (Table 21)

There was one clinical trial of the effect of glycemic control on incident blindness in individuals with type 1 diabetes which included 89 individuals followed over 7.5 years (Reichard, et al. 1993 [1069]). The incidence rates ranged from 14 percent in the intensive therapy groups compared to 35 percent in the conventional therapy group (Reichard, et al. 1993 [1069]). Following multivariate adjustment, the risk of blindness increased twofold for each 1 percent increase in HbA1c (OR=2.2; 95 percent CI: 1.2 to 3.9) (Reichard, et al. 1993 [1069]).

[underlined: Type 2 diabetes] (Table 22)

There were two clinical trials evaluating the relation between HbA1c and incidence of blindness in individuals with type 2 diabetes. These studies included 160 and 4209 individuals followed for 4 and 10 years, respectively (Gaede, et al. 1999 [416]; Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]). There was a non-significant RRR for blindness in the intensive group, with a median HbA1c over followup of 7 percent, compared to the conventional therapy group, where the median HbA1c was 7.9 percent (RR=0.84; 95 percent CI: 0.51, 1.40) (Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group1998 [2113]). In the other study, the incidence of blindness over 4 years was 1.3 percent in the intensive group versus 9 percent in the conventional therapy group (Gaede, et al. 1999 [416]).

##### Cataract Extraction (Table 23)

There was one clinical trial evaluating the relation between tight glycemic control and the risk of cataract extraction, which showed a non-significant reduction in the risk of cataract extraction in the intensively controlled group compared the intensively controlled group (Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]).

#### Cohort studies reporting nephropathy outcomes

##### Incidence of Microalbuminuria

[underlined: Type 1 diabetes] (Table 24)

There were 17 cohort studies evaluating the relation between glycated hemoglobin and development of microalbuminuria in individuals with type 1 diabetes. Thirteen studies used HbA1c as the glycated hemoglobin exposure variable. These studies included 75 to 1273 individuals followed for 2 to 20 years (Chaturvedi, et al. 2001 [84]) (Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]; Villar, et al. 1999 [325]; Jones, et al. 1998 [482]; Reichard, et al. 1996 [699]; Reichard 1992 [1188]; Bojestig, et al. 1998 [460]; Lloyd, et al. 1996 [777]; Rudberg, et al. 1993 [1023]; Rudberg, et al. 1992 [1204]; Chase, et al. 1989 [1444]; Yokoyama, et al. 1995 [2386]; The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial 1996 [718]). The cumulative incidence of microalbuminuria increased with increasing HbA1c, from 0 to 36 percent over 20 years in one study (HbA1c≤8.1 percent vs. HbA1c≥9.5 percent) and from 9 to 29 percent over 8 years in another study (HbA1c≤10.8 percent vs. HbA1c≥12.4 percent) (Bojestig, et al. 1998 [460]; Chase, et al. 1989 [1444]). In three studies, the RR of microalbuminuria was 3- to 5-fold greater in individuals with worse glycemic control (Lloyd, et al. 1996 [777]; Rudberg, et al. 1993 [1023]; Yokoyama, et al. 1995 [2386]). In one of these studies, the mean age was 14 years and the average diabetes duration was 6.9 years (Rudberg, et al. 1993 [1023]) (see Table 2). In a separate study, the risk of microalbuminuria increased 57 percent for every 1 percent increase in HbA1c in a population with a mean HbA1c of approximately 6.5 percent, an mean age of approximately 32.5 years, and an average diabetes duration of approximately 13.5 years (Chaturvedi, et al. 2001 [84]). Another study demonstrated a threefold greater risk of microalbuminuria for each 1 percent increase in HbA1c for a population with a mean HbA1c approximately 9.4 percent (OR=3.55; 95 percent CI: 1.66 to 7.56) (Reichard, et al. 1996 [699]). Two studies showed a significant risk reduction in microalbuminuria in individuals with better glycemic control (Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]; Reichard 1992 [1188]). The mean ages in these studies were approximately 33.5 years (Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group2000 [292]) and 30.1 years (Reichard 1992 [1188]) and the average diabetes durations were approximately 12 years (Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]) and 17 years (Reichard 1992 [1188]) (see Table 2). In one followup study of a previous clinical trial, the RRR was 25 percent in the whole cohort for a 10 percent change in HbA1c for a population with a mean age of 27 years and an average diabetes duration of 2.6 years in the primary prevention cohort and approximately 8.8 years in the secondary prevention cohort (The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial 1996 [718]). One study found no relation between HbA1c and risk of microalbuminuria in a population with a mean age of 16.9 years and average diabetes duration of 11.6 years (Rudberg, et al. 1992 [1204]).

Three studies examined the relation between HbA1 and incidence of microalbuminuria. These studies included 107 to 943 individuals followed for 3 to 4 years (Scott, et al. 2001 [25]; Izumi, et al. 1995 [871]; Klein, et al. 1991 [2691]). The incidence of microalbuminuria increased with increasing HbA1 also, from 8.4 percent to 24.8 percent over 4 years of followup in one study (HbA1≤10.8 percent vs. HbA1≥14.2 percent) (Klein, et al. 1991 [2691]). However, in another study, the incidence of microalbuminuria decreased with increasing HbA1, from 13.6 percent to 5.9 percent over 3.2 years of followup (HbA1≤9.9 percent vs. HbA1≥12.5 percent) (Izumi, et al. 1995 [871]). In two studies, the RR of microalbuminuria ranged from 0.98 to 6.3 with increasing quartiles of HbA1 (Scott, et al. 2001 [25]; Klein, et al. 1991 [2691]). In one of these studies, the mean age was 28.7 years and the average diabetes duration was 13 years (Scott, et al. 2001 [25]).

Two studies evaluated the relation between total GHb and risk of microalbuminuria (Powrie, et al. 1994 [929]; Klein, et al. 1995 [853]). In one study, individuals with total GHb above 12 were nearly 10-times as likely to develop microalbuminuria during the 9.6 years of followup than individuals below this cut-point in a population with a mean age of 31.3 years and an average diabetes duration of 16 years (Powrie, et al. 1994 [929]). In another study, the risk of microalbuminuria was over threefold greater in individuals in the highest quartile of GHb (≥12.1 percent) compared to those in the lowest quartile (≤9.4 percent)(RR=3.45; 95 percent CI: 2.30 to 5.17) (Klein, et al. 1995 [853]).

[underlined: Type 2 diabetes] (Table 25)

There were 8 cohort studies that evaluated the relation between glycated hemoglobin and development of microalbuminuria in individuals with type 2 diabetes. Five of these studies measured HbA1c as a measure of glycated hemoglobin exposure and included 133 to 963 individuals followed for 2 to 10 years (Villar, et al. 1999 [325]; Molyneaux, et al. 1998 [424]; Yokoyama, et al. 1998 [503]; Ravid, et al. 1998 [531]; Niskanen, et al. 1996 [749]). In one study, the RRR was estimated to be 9.9 percent for a 10 percent reduction in HbA1c among a group of individuals with a mean change in HbA1c of 9.5 percent, a mean age of 54.9 years, and an average diabetes duration of 3.8 years (Molyneaux, et al. 1998 [424]). In two studies, the incidence of microalbuminuria increased with increasing HbA1c, from 0 percent to 27 percent over 6.8 years in one study (HbA1c≤6.4 percent vs. HbA1c≥10.5 percent) and from 15 percent to 54.9 percent over 7.8 years in another study (HbA1c≤8.9 percent vs. HbA1c≥9 percent) (Yokoyama, et al. 1998 [503]; Ravid, et al. 1998 [531]). In one study, following multivariate adjustment, the risk of microalbuminuria increased by 56 to 63 percent for each 1 percent increase in HbA1c in a population with a mean HbA1c of 8.4 percent, a mean age of 27 years, and an average diabetes duration of 4.4 years (Yokoyama, et al. 1998 [503]). In another study, individuals with a HbA1c above 9.0 percent were over 8-times as likely to develop microalbuminuria during 7.8 years of followup compared to individuals with a HbA1c below 9 percent in a population with a mean age of 47.7 years and an average diabetes duration of 1.92 years (Ravid, et al. 1998 [531]).

One cohort study evaluated the relation between HbA1 and microalbuminuria. This study showed a much higher cumulative incidence rate among individuals with a HbA1>9.5 percent (58.3 percent over 5 years of followup) compared to those with a HbA1c below this cut-point (18.2 percent) (Haneda, et al. 1992 [1172]). The mean age of this population was approximately 57.2 years and the average diabetes duration was approximately 10 years.

In two cohort studies, the glycated hemoglobin exposure variable was total GHb. Among individuals using insulin and those not using insulin in both studies, there was an increase in cumulative incidence of microalbuminuria with increasing GHb quartiles (Klein, et al. 1995 [853]; Klein et al. 1993 [1103]). Among insulin users, there was a non-significant 33 percent to 43 percent increased risk of microalbuminuria in individuals in the highest quartile of GHb (≥11.6 percent) compared to those in the lowest quartile GHb (≤8.8 percent) (RR=1.43; 95 percent CI: 0.85 to 2.42) (Klein, et al. 1995 [853]) and (RR=1.33; 95 percent CI: 0.7 to 2.52) for individuals with GHB>13.5 percent vs. individuals with GH<10.1 percent (Klein et al. 1993 [1103]). Similarly, among non-insulin users, there was an 83 percent to 87 percent increased risk of microalbuminuria in individuals in the highest quartile of GHb (≥10.1 percent) compared to those in the lowest quartile (≤7.6 percent)(RR=1.87; 95 percent CI: 1.12 to 3.13) (Klein, et al. 1995 [853]) and (RR=1.83; 95 percent CI: 0.87 to 3.85) for individuals with GHB>11.7 percent vs. individuals with GHB<8.5 percent (Klein et al. 1993 [1103]).

##### Incidence of Macroalbuminuria

[underlined: Type 1 diabetes] (Table 26)

Seven cohort studies examined the relation between glycosylated hemoglobin and risk of macroalbuminuria among individuals with type 1 diabetes. In two studies, the glycated hemoglobin exposure variable was HbA1c (Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]; The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial 1996 [718]). These studies included 1208 to 1273 individuals followed for 4 to 6.5 years. In one study, there was a significant risk reduction in macroalbuminuria in individuals with a mean HbA1 of 7.3 percent compared to those with a mean HbA1 of 9.8 percent in a population with a mean age of 27 years and an average diabetes duration of approximately 12 years (RRR=86 percent; 95 percent CI: 60 to 95 percent) (Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group 2000 [292]). In the other study, the RRR for macroalbuminuria for a 10 percent change in HbA1c was 36 percent (95 percent CI: 26 to 45 percent) for the whole study population, as well as the conventional and intensive therapy groups (The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial 1996 [718]).

In four studies, the glycated hemoglobin exposure variable was HbA1. These studies included 148 to 340 individuals followed for 2 to 8 years (Warram, et al. 2000 [304]; Predictors of the development of microalbuminuria in patients with Type 1 diabetes mellitus: a seven-year prospective study. The Microalbuminuria Collaborative Study Group 1999 [310]; Villar, et al. 1999 [325]; Jones, et al. 1998 [482]). In one study, the incidence and RR of macroalbuminuria increased with increasing quartiles of HbA1, such that individuals in the higher quartile (HbA1≥10 percent) were over 5-times more likely to develop macroalbuminuria compared to individuals with HbA1<7.9 in a population with a mean age of 30 years and an average diabetes duration of approximately 17.5 years (RR=5.5; 95 percent CI: 1.6 to 18.8) (Warram, et al. 2000 [304]). In the other study, the risk of macroalbuminuria increased by 32 percent for each 1 percent increase in HbA1 in a population with a mean HbA1 of approximately 9.2 percent, mean age of approximately 29 years, and average diabetes duration of approximately 15 years (Predictors of the development of microalbuminuria in patients with Type 1 diabetes mellitus: a seven-year prospective study. The Microalbuminuria Collaborative Study Group 1999 [310]).

In one cohort study, glycated hemoglobin exposure was assessed by measuring total GHb. The risk of macroalbuminuria over 4 years of followup was threefold greater in individuals with GHb≥11 percent compared to individuals below this cut-point (Lloyd, et al. 1996 [777]).

[underlined: Type 2 diabetes] (Table 27)

Four cohort studies examined the relation between glycated hemoglobin and incident macroalbuminuria in individuals with type 2 diabetes (Villar, et al. 1999 [325]; Gall, et al. 1997 [654]; Park, et al. 1998 [534]; Klein, et al. 1996 [809]). In one study, in which HbA1c was used to measure glycated hemoglobin exposure, the adjusted RR of developing macroalbuminuria over 6 years of followup was 20 percent for each 1 percent increase in HbA1c for a population with an average HbA1c of 7.79 percent, a mean age of approximately 55 years, and an average diabetes duration of approximately 5.5 years (RR=1.2; 95 percent CI: 1.0 to 1.4) (Gall, et al. 1997 [654]).

In two studies the measure of glycated hemoglobin exposure was HbA1. In one study, the risk of developing macroalbuminuria over 5.5 years of followup was 13 percent for each 1 percent increase in HbA1 for a population with an average HbA1 of 11.25 percent, a mean age of approximately 62 years, and an average diabetes duration of approximately 14 years (RH=1.13; 95 percent CI: 1.05 to 1.21) (Park, et al. 1998 [534]). In the other study, there was no relation between HbA1 and the risk of macroalbuminuria in insulin users (mean age 65.2 years; average diabetes duration 15 years) or in non-users (mean age 68 years; average diabetes duration 8.8 years) (Klein, et al. 1996 [809]).

##### Progression of Nephropathy

[underlined: Type 1 diabetes] (Table 28)

Only two cohort studies examined the progression of nephropathy in individuals with type 1 diabetes. In one study, the glycated hemoglobin exposure variable was HbA1c (Villar, et al. 1999 [325]). In this study, the risk of progression was twofold higher for each 1 percent increase in HbA1c in a population with a mean age of 35 years and average diabetes duration of 19 years (OR=2.08; 95 percent CI: 1.34 to 3.21) (Villar, et al. 1999 [325]). In the other study, in which the glycated hemoglobin exposure variable was HbA1, the risk of nephropathy progression increased by 65 percent for each 1 percent increase in HbA1 over 6 years of followup in a population with a mean HbA1 of 7.8 percent, a mean age of 26.4 years, and an average diabetes duration of 8.4 years (Sawicki, et al. 2000 [289]).

[underlined: Type 2 diabetes] (Table 29)

Three cohort studies examined the progression of nephropathy in individuals with type 2 diabetes and all studies used HbA1c as a measure of glycated hemoglobin exposure. These studies included 67 and 258 individuals followed for 2 and 10 years, respectively (Nosadini, et al. 2000 [245]; Oue, et al. 1999 [315]; Villar, et al. 1999 [325]). In one study the risk of nephropathy progression was 3-times greater in individuals with the higher HbA1c (>9.01 percent) compared to those with the lowest HbA1c (<6.7 percent) in a population with a mean age of approximately 58 years, and an average diabetes duration of approximately 12 years (Nosadini, et al. 2000 [245]). In another study, the risk of nephropathy progression increased 7-fold for each 1 percent increase in HbA1c over 10 years of followup in individuals with a mean HbA1c of approximately 8.2 percent, mean age of approximately 56 years, and an average diabetes duration of 11 years (OR=7.30; 95 percent CI: 1.29 to 41.4); however, this relation was attenuated following multivariate adjustment (OR=1.65; 95 percent CI: 1.09 to 2.50) (Oue, et al. 1999 [315]). The risk of nephropathy progression increased 77 percent for each 1 percent increase in HbA1c in a population with an average HbA1c of 7.5 percent, a mean age of 60 years, and an average diabetes duration of 14 years (Villar, et al. 1999 [325]).

##### Change in GFR/Creatinine Clearance (Table 30)

There were 5 studies that evaluated the relation between glycated hemoglobin and change in GFR or creatinine clearance. All of these studies were performed on individuals with type 1 diabetes. In one study, glycated hemoglobin exposure was reported as HbA1c and was associated with a significant rate of decline in GFR (Hovind, et al. 2001 [154]). Four studies examined this relation using HbA1 as the exposure variable and also found that HbA1 was positively associated with a significant decline in GFR over 3 to 8.4 years (Klein, et al. 1999 [387]; Mulec, et al. 1998 [540]; Earle, et al. 1997 [566]; Alaveras, et al. 1997 [681]). These studies included 54 to 301 individuals followed for 3 to 8.4 years. The mean ages of participants in these studies were 36 years (Hovind, et al. 2001 [154]), 31.3 years (Klein, et al. 1999 [387]), 35.5 years (Mulec, et al. 1998 [540]), and approximately 35 year (Earle, et al. 1997 [566]) and the average diabetes durations were 22 years (Hovind, et al. 2001 [154]), 17.1 years (Klein, et al. 1999 [387]), 21.8 years (Mulec, et al. 1998 [540]), approximately 18 years (Earle, et al. 1997 [566]), and 13 years (Alaveras, et al. 1997 [681]) (see Table 2).

##### End-stage Renal Disease (ESRD)

[underlined: Type 1 diabetes] (Table 31)

Three cohort studies examined the relation between glycated hemoglobin and the risk of ESRD in individuals with type 1 diabetes. In one study, in which the glycated hemoglobin exposure variable was HbA1c, the incidence of ESRD increased from 0.5 percent among normoalbuminuric individuals with a mean HbA1c of 8.1 percent, mean age of 26.1 years, and average diabetes duration of 8.4 years to 37.2 percent in macroalbuminuric individuals with a mean HbA1c of 8.4 percent, mean age of 33.5 years, and average diabetes duration of 19.7 years during 10 years of followup (Muhlhauser, et al. 2000 [185]). In two studies, the glycated hemoglobin exposure variable was HbA1 (Muhlhauser, et al. 2000 [178]; Alaveras, et al. 1997 [681]). In one study, the incidence of ESRD increased from 2.4 percent among individuals with a HbA1<7 percent to 5.9 percent among individuals with HbA1c>9 percent in a population with a mean age of 27.5 years and an average diabetes duration of 10.5 years (Muhlhauser, et al. 2000 [178]).

[underlined: Type 2 diabetes] (Table 32)

Only one cohort study examined the relation between glycated hemoglobin and ESRD among individuals with type 2 diabetes and found that there was no relation between HbA1c level and development of ESRD over 8 years of followup in a population with a mean age of 57 years (Yokoyama, et al. 1997 [653]).

#### Randomized clinical trials evaluating nephropathy outcomes

##### Incidence of Microalbuminuria

[underlined: Type 1 diabetes] (Table 33)

Two clinical trials examined the association between HbA1c and incidence of microalbuminuria in individuals randomized to intensive vs. conventional glycemic control. These studies included 89 to 1441 individuals over approximately 7 years of followup (Reichard, et al. 1993 [1069]); The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group 1993 [4638]). In one study, the RRR was 34 percent in for intensive insulin therapy vs. conventional insulin therapy in the primary prevention cohort with a mean age of 26.5 years and was 43 percent for the secondary prevention cohort with a mean age of 27 years (The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group 1993 [4638]). In another study, for the whole study population, the odds of microalbuminuria was 6-fold for each 1 percent increase in HbA1c (OR=5.9; 95 percent CI: 1.9 to 16.8) (Reichard, et al. 1993 [1069]). The population had a mean age of approximately 32 years for those with standard treatment and 30 years for those with intensive treatment and average diabetes duration of 16 years for those with standard treatment and 18 years for those with intensive treatment (Reichard, et al. 1993 [1069]).

[underlined: Type 2 diabetes] (Table 34)

There were three clinical trials that examined the association between intensive vs. conventional glycemic control and the risk of microalbuminuria. These studies include 102 to 4209 individuals over 6 to 10 years of followup (Shichiri, et al. 2000 [247]; Ohkubo, et al. 1995 [888]; Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]). The incidence rates of microalbuminuria over 6 to 8 years of followup were much lower in the intensive therapy groups (7.7 to 16 percent) where the mean HbA1c over followup was approximately 7.1 compared to the conventional therapy groups (28 to 43.5 percent), where the mean HbA1c over followup was approximately 9.4 (Shichiri, et al. 2000 [247]; Ohkubo, et al. 1995 [888]). The mean ages in the conventional therapy groups were approximately 51 years (Shichiri, et al. 2000 [247]) and 48 years (Ohkubo, et al. 1995 [888]) and the mean ages in the intensive therapy groups were 48 years (Shichiri, et al. 2000 [247]) and 50.5 years (Ohkubo, et al. 1995 [888]) (see Table 3). For both studies the average diabetes duration for the primary prevention cohorts was approximately 6 years and for the secondary prevention cohorts was approximately 10 years (see Table 3). The RRRs in the incidence of microalbuminuria in these studies ranged from 30 to 74 percent for the intensive therapy groups compared to the conventional therapy groups (Shichiri, et al. 2000 [247]; Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]).

##### Incidence of macroalbuminuria

[underlined: Type 1 diabetes] (Table 35)

One clinical trial examined the relation between intensive glycemic control and the incidence of macroalbuminuria in individuals with type 1 diabetes. This study included 1441 individuals followed for 6.5 years. The study reported a RRR for macroalbuminuria for the intensive vs. conventional glycemic control was 44 percent (95 percent CI: -124 to 86 percent) for the primary prevention cohort and 56 percent (95 percent CI: 18 to 76 percent) for the secondary prevention cohort (The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group 1993 [4638]).

[underlined: Type 2 diabetes] (Table 36)

Three clinical trials examined the association between intensive glycemic control and incidence of macroalbuminuria in individuals with type 2 diabetes. These studies included 110 to 4209 individuals followed for 6 to 10 years. The incidence rates of macroalbuminuria were lower in the intensive compared to the conventional therapy groups (Shichiri, et al. 2000 [247]; Ohkubo, et al. 1995 [888]). The RRR ranged from 44 to 100 percent (Shichiri, et al. 2000 [247]; Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]), although in one study, the event rates were very low (Shichiri, et al. 2000 [247]).

##### Progression of nephropathy

[underlined: Type 1 diabetes] (Table 37)

There was one clinical trial examining the association between intensive glycemic control and the risk of nephropathy progression. For the whole study population, the odds of nephropathy progression was 2-fold for each 1 percent increase in HbA1c in a population with a mean age of approximately 30 years and average diabetes duration of 17.1 years (OR=2.3; 95 percent CI: 1.3 to 3.4) (Reichard, et al. 1991 [1266]).

[underlined: Type 2 diabetes] (Table 38)

Similarly, there was only one clinical trial examining the association between intensive glycemic control and the risk of nephropathy progression in individuals with type 2 diabetes. This study showed a lower incidence of nephropathy progression in individuals randomized to intensive glycemic control (9.6 percent per 100 person years), where the HbA1c at the end of followup was 7.1 percent, compared to those randomized the conventional glycemic control (30 percent per 100 person years), where the HbA1c at the end of followup was 9.4 percent (Ohkubo, et al. 1995 [888]).

#### Cohort studies reporting neuropathy outcomes

##### Peripheral Neuropathy

[underlined: Type 1 diabetes] (Table 39)

There were five cohort studies that reported peripheral neuropathy outcomes in individuals with type 1 diabetes. In three of these studies, where HbA1c was the exposure variable, there were 4 to 6.5 years of followup in 96 to 1273 individuals. In one study, there was a threefold increased risk of developing distal symmetric polyneuropathy in individuals with HbA1c>11 percent compared to individuals below this cut-point (Lloyd, et al. 1996 [777]). In another study, there was an 85 percent lower odds of developing neuropathy in individuals with HbA1c<8.9 percent compared to individuals with HbA1c>9 percent in a population with a mean age of 30.1 years and an average diabetes duration of 17 years (Reichard, 1992 [1188]). Another study found no threshold effect for the relation between HbA1c and clinical neuropathy and demonstrated similar RRR for each 10 percent change in HbA1c in a followup study of individuals previously randomized to either intensive or conventional treatment (The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial 1996 [718]). The mean age of this population was 27 years and the average diabetes duration in the primary prevention cohort was 2.6 years and in the secondary prevention cohort was approximately 8.8 years (see Table 2).There was one study that examined symptoms of neuropathy in relation to baseline HbA1 level. The cumulative incidences of sensory loss and diminished temperature sensation were 18.6 percent and 10.6 percent, respectively, over 10 years of followup in 1298 individuals with a mean age of 29.3 years and an average diabetes duration of 14.7 years (Klein, et al. 1996 [809]).

One study examined the relation between total glycated hemoglobin and the risk of neuropathy progression. During 3 years of followup in 407 individuals with a mean age of 31.4 years and an average diabetes duration of 6.5 years, the risk of progression to definite distal symmetric polyneuropathy was six fold greater in individuals with GHb>13.5 percent compared to those with GHb<10.1 percent (RR=6.4; 95 percent CI: 2.4 to 16.8), and the risk of progression of neuropathy was nearly threefold greater in those with GHb>13.5 percent compared to those with GHb<10.1 percent (RR=2.8; 95 percent CI: 1.6 to 4.8) (Christen, et al. 1999 [1999]). In multivariate analyses, there was a 25 percent increased risk of progression to definite distal symmetric polyneuropathy (RR=1.25; 95 percent CI: 1.12 to 1.39) and a 17 percent increased risk of progression of neuropathy (RR=1.17; 95 percent CI: 1.08 to 1.26) for each 1 percent increase in total GHb.

[underlined: Type 2 diabetes] (Table 40)

There were only three cohort studies that examined the relation between glycated hemoglobin and neuropathy outcomes in individuals with type 2 diabetes. These two studies, in which the glycated hemoglobin exposure variable was HbA1, included 231 and 1298 individuals over 5 and 10 years of followup, respectively (Sands, et al. 1997 [2275]; Klein, et al. 1996 [809]). In one study, there was no difference in the risk of definite distal symmetric neuropathy or development of an abnormal neurological exam based on HbA1 level (Sands, et al. 1997 [2275]). In another study, the incidence rates of sensory loss and diminished temperature sensation were similar in older onset diabetic individuals who were taking insulin (mean age 65.2 years; average diabetes duration 15 years) and in those who were not taking insulin (mean age 68 years; average diabetes duration 8.8 years) (Klein, et al. 1996 [809]).

One study examined the relation between total GHb and the risk of neuropathy. This study included 149 individuals followed for 6 years and in multivariate analyses, showed a significant positive association between GHb and neuropathy impairment score in a population with an average diabetes duration of 17.1 years (Dyck, et al. 1999 [2022]).

##### Autonomic Neuropathy

[underlined: Type 1 diabetes] (Table 41)

The two cohort studies identified by our search examining the relation between glycated hemoglobin and autonomic neuropathy have been conducted in individuals with type 1 diabetes. These two studies included 83 and 373 individuals over 10 and 5 years of followup, respectively (Makimattila, et al. 2000 [184]; Stella, et al. 2000 [224]). One study showed an inverse association between HbA1 and total power, a measure of heart rate variability, in a population with a mean HbA1 of 9.3 percent, a mean age of 22 years, and an average diabetes duration of 11 years (Makimattila, et al. 2000 [184]). In another study, there was a positive association between HbA1 and the incidence of cardiac autonomic neuropathy in a population with a mean age of 28.7 years and an average diabetes duration of 20.2 years (Stella, et al. 2000 [224]). There was a 67 percent increased risk of cardiac autonomic neuropathy in individuals with HbA1>10 percent compared to those with a HbA1 below this cut-point (RR=1.67; 95 percent CI: 1.16 to 2.41) (Stella, et al. 2000 [224]). In multivariate analyses, there was a 50 percent increased risk of cardiac autonomic neuropathy for each 1 percent increase in HbA1 (RR=1.50; 95 percent CI: 1.21 to 1.86) (Stella, et al. 2000 [224]). We found no studies examining the relation between glycated hemoglobin and autonomic neuropathy in individuals with type 2 diabetes using our search strategy.

#### Randomized clinical trials examining neuropathy outcomes

##### Peripheral Neuropathy

[underlined: Type 1 diabetes] (Table 42)

There were 4 clinical trials that reported the relation between HbA1c and neuropathy outcomes. These studies included 5 to 8 years of followup in 89 to 1441 individuals (Gaede, et al. 1999 [416]; Reichard 1995 [921]; Reichard, et al. 1991 [1266]; The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group 1993 [4638]). The cumulative incidence rates of neuropathy and neuropathy progression were lower in individuals randomized to the intensively treated groups (3.1 percent), where the average HbA1c was approximately 7 percent, than in those randomized to the standard groups (9.8 percent) where the average HbA1c was approximately 9 percent (The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group 1993 [4638]). The mean ages of participants in the standard therapy group was 26.5 years (The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group 1993 [4638]) and in the intensive therapy group was 27 years (The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group 1993 [4638]) (see Table 3). In another study, the cumulative incidence rates of neuropathy, defined by subjective symptoms and abnormal nerve conduction study, were higher in individuals with HbA1c>9 percent compared to those with HbA1c<7 percent (43 percent vs. 10 percent), irrespective of randomization status in a population with a mean age of 31 years and an average diabetes duration of 17 years (Reichard 1995 [921])

One study showed a threefold increased risk of neuropathy in individuals randomized to conventional therapy, where the average HbA1c over followup was 8.7 percent (mean age 31.6 years; average diabetes duration 16.1 years), compared to those randomized to intensive therapy, where the average HbA1c was 7.2 percent (mean age 29.5 years; average diabetes duration 18.1 years) (Reichard, et al. 1991 [1266]). Another study showed a significant RRR in clinical neuropathy in individuals randomized to intensive therapy, where the average HbA1c was approximately 7 percent, compared to those randomized to conventional therapy, where the average HbA1c was approximately 9 percent, in both the primary prevention (RRR=69 percent; 95 percent CI: 24 percent to 87 percent) and secondary prevention (RRR=57 percent; 95 percent CI: 29 percent to 73 percent) cohorts (The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group 1993 [4638]). The average age of participants in this study was 27 years (see Table 3).

[underlined: Type 2 diabetes] (Table 43)

Two clinical trials in individuals with type 2 diabetes has risk data on the relation between HbA1c and peripheral neuropathy. These studies included 160 and 4209 individuals followed for 4 and 10 years, respectively (Gaede, et al. 1999 [416]; Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]). While one study did not demonstrate a significant reduction in the odds of peripheral neuropathy progression in individuals randomized to intensive therapy (OR=0.89; 95 percent CI: 0.43 to 1.85) (Gaede, et al. 1999 [416]), the other study showed that individuals randomized to the intensive therapy group, where the median HbA1c was 7 percent and the mean age was 53.2 years, had a 30 percent reduction in the risk of neuropathy compared to individuals randomized to the conventional therapy group, where the median HbA1c was 7.9 percent and the mean age was 53.4 years (RR=0.60; 95 percent CI: 0.39 to 0.94) (Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]).

##### Autonomic Neuropathy (Table 44)

Only one clinical trial reported data on autonomic neuropathy and this study, conducted in individuals with type 2 diabetes, demonstrated a significant reduction in the risk of autonomic neuropathy progression (OR=0.31; 95 percent CI: 0.12 to 0.78) (Gaede, et al. 1999 [416]). There are no clinical trial data on autonomic neuropathy outcomes in individuals with type 1 diabetes identified by our search strategy.

#### Cohort studies examining macrovascular outcomes

##### Cause specific Cardiovascular Morbidity

[underlined: Coronary artery disease: Non-fatal MI, Angina] (Table 45)

There were no studies identified by our search strategy in individuals with type 1 diabetes that examined the relation between glycated hemoglobin and coronary artery disease morbidity. There were 2 cohort studies that examined the association between glycated hemoglobin and risk of CAD morbidity in individuals with type 2 diabetes. These studies included 5063 and 1059 individuals followed for 10 and 7 years, respectively (Adler, et al. 1999 [4124]; Lehto, et al. 1997 [4240]). In one study of newly diagnosed diabetics in which the mean age of the participants was 53 years, there was a 60 to 70 percent increased risk of angina among individuals with HbA1c>7.7 percent compared to their counterparts with HbA1c<6.3 percent, following multivariate adjustment, including cardiovascular risk factors such as age, blood pressure, smoking and lipids. (Adler, et al. 1999 [4124]). In another study, in which the mean age of the population was approximately 58 years and the average diabetes duration was approximately 8 years, there was a 30 percent increased risk developing non-fatal MI over 7 years of followup in individuals with HbA1c>10.7 percent compared to individuals with HbA1c below this cut-point (RH=1.3; 95 percent CI: 1.0 to 1.7) (Lehto, et al. 1997 [4240]). Following multivariate adjustment, which included cardiovascular risk factors such as age, prevalent MI, and lipids, this association was no longer significant (Lehto, et al. 1997 [4240]).

[underlined: Cerebrovascular disease: Non-fatal stroke] (Table 46)

One cohort study examined the association between glycemic control and non-fatal stroke in individuals with type 2 diabetes. This study, in which the mean age of the participants was 61.2 years, showed an inconsistent association between the incidence of stroke and quartiles of HbA1c over 4 years of followup (Fu, et al. 1993 [4403]). This relation has not been examined in individuals with type 1 diabetes.

[underlined: Peripheral arterial disease (PAD): Limb amputation, ulcer formation]

[underlined: Type 1 diabetes] (Table 47)

There were 7 cohort studies that evaluated the association between non-fatal PAD and glycohemoglobin (Muhlhauser, et al. 2000 [185]; Olson, et al. 2002 [7]; Muhlhauser, et al. 2000 [178]; Lloyd, et al. 1996 [777]; Moss, et al. 1999 [2047]; Moss, et al. 1996 [2326]; Moss, et al. 1992 [2636]). In one study, in which the glycated hemoglobin exposure variable was HbA1c, there was a positive association between HbA1c and the risk of limb amputations in which the mean age of the population ranged from 26.1 to 33.5 years and the average diabetes duration ranged from 8.4 years to 19.7 years (Muhlhauser, et al. 2000 [185]). In two studies, the glycated hemoglobin exposure variable was HbA1 (Olson, et al. 2002 [7]; Muhlhauser, et al. 2000 [178]). Both demonstrated a positive association between HbA1 and the risk of PAD over 10 years of followup. In one study, there was a 53 percent increased risk of PAD for each 1.84 unit change in HbA1 in a population with an average HbA1 of approximately 10.6 percent, a mean age of approximately 28 years, and an average diabetes duration of approximately 20 years, following adjustment for diabetes duration, hypertension, log AER, and heart rate (Olson, et al. 2002 [7]). In another study, the cumulative incidence of limb amputation over 10 years of followup was 1.1 percent for individuals with HbA1<7 percent compared to 2.7 percent for individuals with HbA1>9 percent in a population with a mean age of 27.5 years and an average diabetes duration of 10.5 years (Muhlhauser, et al. 2000 [178]).

In 4 cohort studies, the glycated hemoglobin exposure variable was total GHb. These studies included 658 to 996 individuals following for 4 to 14 years (Lloyd, et al. 1996 [777]; Moss, et al. 1999 [2047]; Moss, et al. 1996 [2326]; Moss, et al. 1992 [2636]). One study found no association between total GHb and risk of PAD over 4 years of followup (Lloyd, et al. 1996 [777]). Most studies found a positive association. In one study, the cumulative incidence of limb amputation over 10 years was higher in individuals with total GHb>14.2 percent compared to those with total GHb<10.8 percent (3.0 percent vs. 0.9 percent) (Moss, et al. 1992 [2636]). A stronger association was found for patient self-report of sores or foot ulcers, with a cumulative incidence of 17.2 percent for individuals with a total GHb>14.2 percent vs. 5.2 percent for individuals with a total GHb<10.8 percent (Moss, et al. 1992 [2636]). In two studies, the risk of PAD was approximately 6-fold greater in individuals in the highest quartile of total GHb (12.1 to 19.5 percent) compared to those in the lowest quartile (5.6 to 9.4 percent) (Moss, et al. 1999 [2047]; Moss, et al. 1996 [2326]). In multivariate analysis in one of these studies, which included adjustment for gender, diabetes duration, blood pressure, history of ulcers, and retinopathy , the risk of PAD was increased 39 percent for each 1 percent increased in total GHb (OR=1.39; 95 percent CI: 1.19 to 1.62) (Moss, et al. 1996 [2326]). In one study, the mean age of the participants was 27.9 years and the average diabetes duration was 13.5 years (Moss, et al. 1999 [2047])(see Table 2).

[underlined: Type 2 diabetes] (Table 48)

Four cohort studies examined the association between glycated hemoglobin and the risk of non-fatal PAD in individuals with type 2 diabetes (Lehto, et al. 1996 [2330]; Moss, et al. 1992 [2636]; Moss, et al. 1999 [2047]; Moss, et al. 1996 [2326]). In the one study that used HbA1 as the exposure variable, individuals with HbA1>10.8 percent were over 2-times as likely to have a limb amputation over 7 years of followup compared to individuals with a HbA1 below that cut-point (Lehto, et al. 1996 [2330]).

In three studies, the glycated hemoglobin variable was total GHb and these studies included 956 to 996 individuals over 4 to 14 years of followup (Moss, et al. 1992 [2636]; Moss, et al. 1999 [2047]; Moss, et al. 1996 [2326]). The cumulative incidence of limb amputations and patient self-report of sores or foot ulcers increased with increasing quartiles of total GHb (Moss, et al. 1992 [2636]; Moss, et al. 1996 [2326]). In one of these studies, the mean age of the participants was 64.5 years and the average diabetes duration was 11 years (Moss, et al. 1996 [2326]) (see Table 2). In two other studies, there was nearly a fourfold increased risk of lower extremity amputation in individuals in the highest quartile of total GHb (10.9 to 20.8 percent) compared to the lowest quartile (5.4 to 8.1 percent) (Moss, et al. 1999 [2047]; Moss, et al. 1996 [2326]). In multivariate analyses adjusted for cardiovascular risk factors, including age and blood pressure, the risk of amputation increased by 25 to 28 percent for each 1 percent increased in total GHb in a population with an average total GHb of 9.6 percent, a mean age of approximately 64 years, and an average diabetes duration of approximately 11 years (Moss, et al. 1999 [2047]; Moss, et al. 1996 [2326]).

[underlined: Congestive heart failure (CHF)] (Table 49)

We found two studies examining the association between glycated hemoglobin the risk of congestive heart failure (CHF) in individuals with type 2 diabetes. While one study, in which the mean age was 53 years, showed a significant RRR in the incidence of CHF for each 1 percent decline in HbA1c during 10 years of followup following adjustment for gender, race, blood pressure, smoking, age at diabetes diagnosis, lipids, and albuminuria (Stratton, et al. 2000 [4087]), the other study, in which the mean age was 63 years and the average diabetes duration was 4.5 years, demonstrated no relation between HbA1c and risk of CHF over 2.5 years of followup in population with a mean HbA1c of 7.7 percent (Nichols, et al. 2001 [4025]). There are no cohort study data identified by our search strategy on the relation between glycated hemoglobin and the risk of CHF among individuals with type 1 diabetes.

[underlined: Carotid intimal-medial thickness (IMT)]

[underlined: Type 1 diabetes] (Table 50)

One study examined the association between HbA1c and change in carotid IMT, a measure of subclinical atherosclerosis, in individuals with type 1 diabetes and did not find a significant relationship after adjusting for age, diabetes duration, weight, blood pressure, smoking, height, GFR, and diabetes treatment (Effect of intensive diabetes treatment on carotid artery wall thickness in the epidemiology of diabetes interventions and complications. Epidemiology of Diabetes Interventions and Complications (EDIC) Research Group 1999 [4147]). This study population had a mean age of approximately 35 years and an average diabetes duration of approximately 14 years (see Table 2).

[underlined: Type 2 diabetes] (Table 51)

One cohort study examined the association between HbA1c and change in carotid IMT over 3.1 years of followup in individuals with type 2 diabetes. This study demonstrated a significant, positive association between HbA1c and increase in common carotid IMT in a population with a mean HbA1c of 8.66 percent following adjustment for age, gender, diabetes duration, baseline IMT, weight, blood pressure, smoking, lipids, creatinine, BUN and uric acid (Yamasaki, et al. 2000 [4081]). This study population had a mean age of 61.7 years and an average diabetes duration of 15.6 years (see Table 2).

##### Cause-specific Cardiovascular Mortality

[underlined: Fatal Coronary Artery Disease (CAD): Fatal MI]

[underlined: Type 1 diabetes] (Table 52)

There was only one cohort study that examined the risk of CAD mortality in relation to glycated hemoglobin in individuals with type 1 diabetes (Lehto, et al. 1999 [397]). In this study in which the mean age of the population was approximately 56 years and the average diabetes duration ranged from 13 to 22 years, individuals with an HbA1≥10.4 percent were over 6-times as likely to suffer a fatal CAD event compared to individuals with an HbA1 below this cut-point (RH=6.8; 95 percent CI: 2.5 to 19) (Lehto, et al. 1999 [397]). This relation persisted following multivariate adjustment for cardiovascular risk factors, including age, prevalent MI, weight, blood pressure, smoking, alcohol, and HDL (RH=5.4; 95 percent CI: 1.4 to 20.4) (Lehto, et al. 1999 [397]).

[underlined: Type 2 diabetes] (Table 53)

Four studies in individuals with type 2 diabetes examined this relationship. In three studies, which included 121 to 2693 individuals followed for 7 to 10 years, the glycated hemoglobin exposure variable was HbA1c (Toyry, et al. 1996 [3527]; Turner, et al. 1998 [4217]; Lehto, et al. 1997 [4240]). In one study, in which the mean age of the population was 55.7 years, the risk of fatal MI increased 50 percent for each 1 percent increase in HbA1c in multivariate analysis in a population with a mean HbA1c of 9.0 percent (OR=1.5; 95 percent CI: 1.1 to 2.1), following adjustment for age, gender, weight, blood pressure, smoking, autonomic dysfunction, ischemic ECG, and diuretics (Toyry, et al. 1996 [3527]). In another study, in which the mean age of the study population was approximately 52.5 years, the risk of a fatal MI was increased by 72 percent in individuals with a HbA1c>7.5 percent compared to those with a HbA1c<6.1 percent following adjustment for age, gender, blood pressure, smoking, and lipids (RH=1.72; 95 percent CI: 1.06 to 2.77) (Turner, et al. 1998 [4217]). Similarly, there was an increased risk of fatal MI in individuals with a HbA1c>10.7 percent compared to individuals with a HbA1c below this cut-point (Crude RH=1.5; 95 percent CI: 1.1 to 2.1; Adjusted RH=1.4; 95 percent CI: 1.0 to 1.9, adjusted for age, gender, diabetes duration, baseline MI, lipids, AUC glucose) (Lehto, et al. 1997 [4240]). The mean age of this study population was approximately 59 years and the average diabetes duration was approximately 8 years (see Table 2).

In one study, the glycated hemoglobin exposure variable was total GHb (Florkowski, et al. 1998 [519]). In this study, which included 6 years of followup in a population with a mean age of 62 years and an average diabetes duration of approximately 10 year, the risk of fatal CAD was increased by 90 percent in individuals free of CAD at baseline following multivariate adjustment for multiple cardiovascular risk factors including smoking, lipids, hypertension, CAD, and albuminuria (RH=1.90; 95 percent CI: 1.04 to 3.47); however, in this same study, there was not a significant relation between total GHb and fatal CAD in individuals who had a prior history of CAD (RH=0.81; 95 percent CI: 0.42 to 1.58) (Florkowski, et al. 1998 [519]).

[underlined: Fatal cerebrovascular disease: Fatal stroke] (Table 54)

One study in individuals with type 2 diabetes examined the relation between total GHb and the risk of fatal stroke during 10 years of followup in a population with a mean age of 66.6 years and an average diabetes duration of 11.6 year and showed a 17 percent increased risk of stroke for each 1 percent increase in total GHb (RH=1.17; 95 percent CI: 1.05 to 1.30) (Moss, et al. 1994 [4338]).

##### Composite Cardiovascular Mortality

[underlined: Fatal MI or Fatal stroke]

[underlined: Type 2 diabetes] (Table 55)

Three cohort studies evaluated the relation between HbA1c and the risk of fatal MI or stroke in individuals with type 2 diabetes. These studies included 133 to 328 individuals followed for 5.3 to 15 years (Niskanen, et al. 1998 [457]; Gall, et al. 1995 [827]; Standl, et al. 1996 [4276]). In two studies, there was a 52 percent increased risk and a 30 percent increased risk for each 1 percent increase in HbA1c in populations with a mean HbA1c of 9 percent and approximately 8 percent, respectively, following multivariate adjustment (Niskanen, et al. 1998 [457]; Gall, et al. 1995 [827]). The mean age of the participants in these studies were 55.7 years (Niskanen, et al. 1998 [457]) and 56 years (Gall, et al. 1995 [827]) and the average diabetes duration in one study was approximately 7 years (Gall, et al. 1995 [827]) (see Table 2). The risk of fatal MI or stroke was not evaluated in relation to HbA1c in individuals with type 1 diabetes.

##### Composite Cardiovascular Morbidity and Mortality

[underlined: Coronary artery disease: Fatal and non-fatal MI]

[underlined: Type 1 diabetes] (Table 56)

Two cohort studies examined the association between glycated hemoglobin and fatal and non-fatal CAD in individuals with type 1 diabetes. One study, in which the mean age was approximately 56 years and the average diabetes duration ranged from approximately 13 to 22 years, found a nearly 3-fold increase in risk of fatal and non-fatal MI in individuals with a HbA1≥10.4 percent compared to individuals below this cut-point (RH=3.4; 95 percent CI: 1.6 to 7.4), which persisted following multivariate adjustment for age, gender, diabetes duration, baseline CVD, weight, blood pressure, smoking, alcohol, and HDL (RH=2.8; 95 percent CI: 1.2 to 6.9) (Lehto, et al. 1999 [397]). In contrast, the other study found no significant relation between total GHb and risk of fatal and non-fatal CAD (Lloyd, et al. 1996 [777]).

[underlined: Type 2 diabetes] (Table 57)

Three cohort studies have examined the relation between HbA1c and risk of fatal and non-fatal MI in individuals with type 2 diabetes. These studies included 2693 to 5063 individuals followed for 10 years (Stratton, et al. 2000 [4087]; Adler, et al. 1999 [4124]; Turner, et al. 1998 [4217]). In one study, in which the mean age of the study population was 53 years, there was a 14 percent risk reduction in fatal or non-fatal MI for each 1 percent reduction in HbA1c, following multivariate adjustment for gender, race, blood pressure, smoking, age at diagnosis, lipids, and albuminuria (RRR=14; 95 percent CI: 8 to 21) (Stratton, et al. 2000 [4087]). In two other studies, there was an approximately 50 percent increased risk of fatal and non-fatal MI in individuals with a HbA1c>7.5–7.7 percent compared to those with HbA1c<6.1–6.3 percent following multivariate adjustment for multiple cardiovascular risk factors (Adler, et al. 1999 [4124]; Turner, et al. 1998 [4217]).

[underlined: Composite cerebrovascular disease: Fatal and non-fatal stroke]

[underlined: Type 1 diabetes] (Table 58)

One cohort study has examined the association between total GHb and the risk of fatal and non-fatal stroke in individuals with type 1 diabetes. This study showed an 18 percent increased risk of stroke over 10 years for each 1 percent increase in total GHb in a population with a mean total GHb of 12.6 percent, a mean age of 29.1 years, and an average diabetes duration of 14.6 years (Moss, et al. 1994 [4338]).

[underlined: Type 2 diabetes] (Table 59)

Three cohort studies have examined the association between glycated hemoglobin and fatal and non-fatal stroke. In two of these studies, which included 3642 and 5063 individuals followed for 10 years, the glycated hemoglobin exposure variable was HbA1c (Stratton, et al. 2000 [4087]; Adler, et al. 1999 [4124]). In one study, there was a 12 percent increased risk of stroke for each 1 percent increase in HbA1c in a population with a mean HbA1c of 7.1 percent and a mean age of 53 years, following adjustment for gender, race, blood pressure, smoking, age at diagnosis, lipids, and albuminuria (Stratton, et al. 2000 [4087]); however, the other study, in which the mean age of the participants was also 53 years, found no relation between HbA1c and the risk of stroke following multivariate analyses (Adler, et al. 1999 [4124]). In the third study, in which the glycated hemoglobin exposure variable was HbA1, there was a 60 percent increased risk of stroke in individuals with a HbA1>10.8 percent compared to those with a HbA1 below this cut-point in individuals with a mean age of approximately 59 years and an average diabetes duration of approximately 8 years (OR=1.6; 95 percent CI: 1.1 to 2.4) (Lehto, et al. 1996 [4313]).

#### Randomized Clinical trials examining macrovascular outcomes

There is only one clinical trial examining the association between intensive glycemic control and the risk of macrovascular complications in individuals with type 2 diabetes (Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]). The mean age of the 4209 participants in this clinical trial who were all newly diagnosed diabetics was approximately 53 years (see Table 3). There are no trials specifically examining this outcome in individuals with type 1 diabetes.

##### Coronary artery disease: Fatal and non -fatal CAD (Table 60)

Compared to individuals randomized to conventional glycemic control, where the median HbA1c over 10 years of followup was 7.9 percent, those randomized to intensive glycemic control, where the median HbA1c was 7.0 percent, had non-significant risk reductions in non-fatal MI (RR=0.79; 95 percent CI: 0.58 to 1.09), fatal MI (RR=0.94; 95 percent CI: 0.68 to 1.30), and sudden cardiac death (RR=0.54; 95 percent CI: 0.24 to 1.21) (Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]).

##### Cerebrovascular disease: Fatal and non-fatal Stroke (Table 61)

There was no relation between randomization to intensive vs. conventional glycemic control and the risk of non-fatal stroke (RR=1.07; 95 percent CI: 0.68 to 1.69) and fatal stroke (RR=1.17; 95 percent CI: 0.54 to 2.54) (Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]).

##### Peripheral vascular disease (Table 62))

There was a non-significant reduction in the incidence of limb amputation in the intensive therapy group compared to the conventional therapy group (RR=0.61; 95 percent CI=0.28 to 1.33) (Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]).

##### Congestive heart failure (Table 63))

Similarly, there was a non-significant reduction in the incidence of CHF in the intensive therapy group compared to the conventional therapy group (RR=0.91; 95 percent CI: 0.54 to 1.52) (Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group 1998 [2113]).

#### Studies examining threshold effects between glycosylated hemoglobin and diabetic complications

Fifteen studies specifically addressed the issue of a threshold effect between glycosylated hemoglobin and microvascular complications. Eight studies examined retinopathy outcomes (see Table 64). In 6 studies, there was no threshold effect for the relation between glycated hemoglobin and risk of retinopathy (Molyneaux, et al. 1998 [424]; Klein, et al. 1994 [2458]; Porta, et al. 2001 [1769]; Chaturvedi, et al. 2001 [140]; The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial 1996 [718]; Stratton, et al. 2000 [4087]). Two studies suggested a threshold effect for glycated hemoglobin on the risk of retinopathy, one at 9 percent (Danne, et al. 1994 [934]) and the other at 6.5 percent (Ohkubo, et al. 1995 [888]). Eight studies examined the presence of a threshold effect between glycosylated hemoglobin and nephropathy outcomes and 5 of these found not threshold effect (see Table 65). In three studies, however, threshold effects for incident nephropathy were identified at 8 percent (Scott, et al. 2001 [25]), 7.5 to 8.5 percent (Warram, et al. 2000 [304]), and 6.5 percent (Ohkubo, et al. 1995 [888]). Only one study each examined the presence of a threshold effect for neuropathy (The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial 1996 [718]) and macrovascular outcomes (Stratton, et al. 2000 [4087]) and neither study found an effect for either of these outcomes. (See Tables 66 and 67, respectively.)

## Urine Albumin

Of 4383 potentially relevant abstracts and articles identified through our search, articles were eliminated for the following reasons: 1) no information relevant to the questions asked (n=3613), 2) under 100 persons enrolled (n=276), 3) no prospective data included (n=183), 4) no original data (i.e. editorials, reviews) (n=117), 5) albumin exposure not defined adequately or studies not reporting outcomes relative to the presence or absence of study participants at baseline (n=75), 6) no study participants with diabetes or study did not analyze outcomes for study participants with diabetes (n=33), 7) no populations of interest studied (i.e. pregnant women, transplant studies, persons already on dialysis, persons with pre-existing CVD, persons with pre-existing amputations) (n=31), 8) data not extractable (i.e. presented only in graphical form) (n=9), 9) no human data (i.e. in vitro studies, animal studies) (n=7), and 10) less than 3 months total followup (n=3). To help ensure that important eligible articles were not overlooked, we scanned bibliographies and relevant reviews. This process did not uncover additional references not already identified using the above strategy.

### Characteristics of Reviewed Studies-Study Population, Design, Location, Recruitment, Outcomes, and Quality

Of the remaining 36 articles, 4 reported on randomized controlled trials (RCTs), 31 reported on prospective cohort studies, and one reported on a post-hoc cohort analysis of a study initially designed as a RCT (from this point on, referred to as “RCT analyzed as a cohort study.” Most articles reported on studies including persons with only type 2 diabetes (n=25), while 8 articles reported on studies which included persons with only type 2 diabetes, 2 articles reported on studies including persons with both type 1 and type 2 diabetes, and 1 article did not specify study participants' type of diabetes. Reported study locations were varied, with the majority (21) of studies performed in Europe and most studies (23) being performed in a single city or country.

Articles reported on a variety of outcomes: 11 reported on renal outcomes, 24 reported on total mortality, and 19 reported on cardiovascular morbidity and mortality. Among articles reporting renal outcomes, 7 were cohort studies, and 4 were RCTs. Among articles reporting on cardiovascular outcomes, 17 were cohort studies, one was a RCT, and one was a cohort analysis of a RCT. Among studies reporting on all cause death, 22 were cohort studies, four were RCT, and one was a cohort analysis of a RCT. The mean quality score for observational studies was 51.0 (standard deviation (SD) 12.3, median 49.8) and for RCTs was 52.8, (SD=15.4, median 50.7). (Table 68)

#### Reported Baseline Data for Study Participants

Articles varied in terms of their reporting of many baseline characteristics, and reported participant characteristics were diverse. Nearly all articles reported on study participant age, with reported means ranging from 27.5 years to 67.9 years. Most articles reported on study participant gender as well, with most reporting enrolling a majority of male participants. Most articles did not report on race/ethnicity of study participants. Most articles reported on the duration of diabetes for study enrollees, and reported means ranged from 5 years to 20 years. Over half of the articles reported smoking status of study enrollees, with most studies reporting enrolling current and/or past smokers. Over half of articles reported on glycemic control (either hemoglobin A1c (HbA1c) or fasting glucose) of study participants. Reported means for HbA1c ranged from 6.3 percent to 11.9 percent, and reported means for fasting glucose ranged from 8.3mmol/L to 12.0mmol/L. Over half of the articles reported on study participants' prior history of cardiovascular, peripheral vascular or cerebrovascular disease. In articles reporting on this information, the percent study participants with a prior history of cardiovascular disease ranged from 3.4 percent to 60 percent while the percent study participants with a prior history of peripheral vascular disease ranged from 1.5 percent to 27.5 percent, and the percent study participants with a prior history of cerebrovascular disease ranged from 0 percent to 20 percent. (Tables 69 and 70)

#### Diagnosis of Diabetes

Reporting of the method of ascertaining the diagnosis of diabetes for study participants varied. Among reports on cohort studies, 8 articles did not report method of diagnosis of diabetes, and among reports on RCTs, two articles did not report the method of diagnosis of diabetes for study participants. In other articles, verification of diabetes diagnosis ranged from presence of insulin therapy, self report of previous physician diagnosis, previous physician diagnosis, and a prior history of ketoacidosis. Several articles also referenced study participant fulfillment of World Health Organization (WHO) requirements in establishing the diagnosis of types 1 and 2 diabetes. (Tables 71 and 72).

### Mesures of Microalbuminuria

Of three methods of reported urine collection, 15 studies articles collection of random urine specimens, 12 reported collection of 24 hour urine specimens, and 9 reported collection of timed or ‘overnight’ specimens (referred to as ‘timed’ in tables and report). Articles also varied in their reporting of the types of measurement used in assessing microalbuminuria; 30 studies reported albumin excretion rates, 5 reported albumin to creatinine ratios, and one reported dipstick positive results.

### Definition of Microalbuminuria

Quantification and definitions of microalbuminuria varied among reported studies. In studies reporting albumin excretion rates from 24-hour urine specimens (n=12), the lower and upper values for defining microalbuminuria ranged from 10.1–50.5 mg/24hrs and 35 to 300mg/24hrs, respectively. (Stehouwer, et al. 2002 [6834]; Niskanen, et al. 1993 [1452]; Lebovitz, et al. 1994 [1366]; Gall, et al. 1995 [1146]; Deckert, et al. 1996 [1074]; Rossing, et al. 1996 [991]; Araki, et al. 1997 [930]; Gaede, et al. 1999 [613]; Nosadini, et al. 2000 [376]; Rachmani, et al. 2000 [336]; Muhlhauser, et al. 2000 [293]; Muhlhauser, et al. 2000 [283]) One study of this group gave no upper limit in defining microalbuminuria. (Niskanen, et al. 1993 [1452]) In studies reporting albumin excretion obtained from timed urine collections (n=9), the lower and upper values for defining microalbuminuria ranged from 15.0 to 30 μg/min and 149.9 to 499 μg/min, respectively. (Damsgaard, et al. 1992 [1622]; Mattock, et al. 1992 [1603]; Damsgaard, et al. 1993 [1429]; MacLeod, et al. 1995 [1218]; Crepaldi, et al. 1995 [1158]; Captopril reduces the risk of nephropathy in IDDM patients with microalbuminuria. The Microalbuminuria Captopril Study Group1996 [1061]; Mattock, et al. 1998 [659]; Hanninen, et al. 1999 [580]) One study reporting albumin excretion obtained from timed urine collection reported the lower value for microalbuminuria as 30mg/24 hrs; this study gave no upper value for defining microalbuminuria. (Niskanen, et al. 1996 [1067]) In studies reporting albumin excretion obtained from random urine specimens (n= 9), the lower and upper values for defining microalbuminuria ranged from 20 to 150 mg/l and 200 to 300mg/l, respectively. (Torffvit, et al. 1993 [1508]; Neil, et al. 1993 [1454]; Agardh, et al. 1996 [1075]; Beilin, et al. 1996 [1009]; Miettinen, et al. 1996 [977]; Valmadrid, et al. 2000 [411]; Biderman, et al. 2000 [392]; de Grauw, et al. 2001 [216]) One study of this group gave no upper value for defining microalbuminuria. (Biderman, et al. 2000 [392])

Among studies reporting microalbuminuria as albumin to creatinine ratio (ACR) (n=5), ACR was quantified in different ways; one study quantified ACR in grams albumin per gram creatinine (g/g), three studies quantified ACR in milligrams albumin per millimol creatinine (mg/mmol), and one quantified ACR in grams albumin per mol creatinine (g/mol). (Hoy, et al. 2001 [160]; Mlacak, et al. 1999 [465]; Nelson, et al. 1996 [967]; Chan, et al. 1995 [1195]; Gerstein, et al. 2001 [136]) (See Acronyms for abbreviations).

### Study Outcomes

#### Cohort Studies Reporting on Renal Outcomes

Among cohort studies, the following renal outcomes (number of articles reporting outcome) were reported: 1) change in GFR at study followup (n=1), 2) rate of change of GFR during study (n=2), 3) rate of change in 1/serum creatinine during study (n=1), 4) change in creatinine clearance at study followup (n=1), and 5) incidence of ESRD, need for renal replacement therapy, or kidney transplantation (n=3).

1. Change in GFR at Study Followup
  [underlined: Type 2 diabetes]
  In the one article reporting on a prospective cohort study assessing change in GFR, the magnitude of change in GFR observed at study followup was greater among persons with greater levels of urine albumin excretion (UAE) at baseline. In this study of 143 persons with mean (SD) age of 44.5 (1.2) years and type 2 diabetes, change in GFR was reported as percentage change in GFR from baseline over 4 years of followup. At followup, persons with normoalbuminuria (albumin to creatinine ratio (ACR) <30mg/g in a random urine specimen) were reported to have a two percent increase in GFR over study followup, while persons with microalbuminuria (ACR 20–299mg/g) were reported to have a 3 percent decrease in GFR over study followup, and persons with macroalbuminuria (ACR ≥ 300mg/g) were reported to have a 35 percent decrease in GFR over study followup. (Nelson, et al. 1996 [967]) (Tables 69, 73)
2. Rate of Change in GFR During Study
  [underlined: Type 2 diabetes]
  In two articles reporting on prospective cohort studies assessing rate of change in GFR during study followup, the rate of decline in GFR during the study period was observed to increase with greater magnitude among persons with greater levels of UAE at baseline. (Rachmani, et al. 2000 [336]; Nosadini, et al. 2000 [376]) These studies of a combined 724 persons with mean ages of 47.9 and 56.0 years, respectively and with type 2 diabetes were run for 8 and 4 years, respectively. In one study, the mean (SD) rate of change in GFR among persons with normoalbuminuria (albumin excretion rate (AER) 0–10mg/24hrs in a 24 hour specimen) was reported as a decline of 1.19 (0.36) ml/min/year, while the mean (SD) rate of change in GFR among persons with microalbuminuria (AER 10.1–20mg/24hrs) was reported as a decline of 1.64(0.58) ml/min/year, while persons with macroalbuminuria (AER 20.1–30mg/24hrs) had reported mean rate of change (SD) in GFR of 2.52 (0.96) ml/min/year. (Rachmani, et al. 2000 [336]) (Tables 69, 74)
  In the second study, persons with microalbuminuria and who were found to have a progression in kidney disease (AER 20–199μg/min in a 24 hour urine specimen) had a mean (SD) decline in GFR of 5.54 (6.74) ml/min/1.73m^2^/year, while persons with macroalbuminuria (AER>199μg/min) had a mean (SD) decline in GFR of 10.92 (9.99) ml/min/1.73m^2^/year. This was compared with persons with microalbuminuria who did not have a progression in kidney disease during the study, who had a mean (SD) increase in GFR of 3.96 (5.84) ml/min/1.73m^2^/year, while persons with macroalbuminuria had a mean (SD) increase in GFR of 4.08 (11.0) ml/min/1.73m^2^/year. (Nosadini, et al. 2000 [376]) (Tables 69, 74)
3. Rate of Change in 1/Serum Creatinine During Study
  [underlined: Type 2 diabetes]
  In one article reporting on a two year prospective cohort study assessing the rate of decline in kidney function (reported as 1/serum creatinine) among persons with mean (SD) age of 54.2 (12.5), the rate of decline in kidney function was greater among persons with greater UAE at baseline. Persons with normoalbuminuria (ACR < 5.6mg/mmol in a random urine specimen) had a mean (SD) decline in 1/serum creatinine of 27.3 (62.5) L/μmol/month, while persons with microalbuminuria (ACR 5.6–38 mg/mmol) had a mean (SD) decline in 1/serum creatinine of 43.4 (68.6) L/μmol/month, and persons with macroalbuminuria (ACR >38mg/mmol) had a mean decline in 1/serum creatinine of 108.8 (98.8) L/μmol/month. (Chan, et al. 1995 [1195]) (Tables 69, 75)
4. Rate of Change in Creatinine Clearance During Study
  [underlined: Type 1 diabetes]
  In one article reporting on a prospective cohort study assessing the risk of a clinically meaningful decline in creatinine clearance (defined as a decline >3ml/min/1.73m^2^/year) among persons with mean age of 31.3 years, greater risk of a clinically meaningful decline in creatinine clearance was observed among persons with greater UAE at baseline. In this 10 year study, persons with microalbuminuria at baseline (urine albumin concentration (UAC) 30–299mg/L) had 45 percent increased risk of a clinically meaningful decline in creatinine clearance when compared to their counterparts with normoalbuminuria (UAC of 0–30mg/L). Persons with baseline UAC ≥ 500mg/L had a greater than twofold increased risk of a clinically meaningful decline in creatinine clearance when compared to persons with baseline UAC of 0–30mg/L. (Klein, et al. 1999 [3379]) (Tables 69, 76)
5. Incidence of ESRD, Need for Renal Replacement Therapy, or Kidney Transplantation
  [underlined: Type 1 diabetes]
  Articles reporting on two prospective cohort studies demonstrate a greater risk of of ESRD, need for renal replacement therapy, or kidney transplantation among persons with greater levels of baseline UAE.
  Two articles reported on a single prospective cohort study of 3674 persons with type 1 diabetes. (Muhlhauser, et al. 2000 [293]; Muhlhauser, et al. 2000 [283]) In this 10 year study of persons with mean (SD) age of 27.5 (9.5) years, persons with normoalbuminuria (<20mg/24 hrs obtained from 24 hour urine specimen) had a 0.5 percent cumulative incidence of need for renal replacement therapy, while persons with microalbuminuria (UAC 41–499mg/L) had a 1.5 percent cumulative incidence of this outcome, and persons with macroalbuminuria (UAC ≥ 500mg/L) had a 34.8 percent cumulative incidence of this outcome. (Muhlhauser, et al. 2000 [293]; Muhlhauser, et al. 2000 [283]) In a second prospective 10-year cohort study of persons with mean age of 31.3 years and type 1 diabetes, persons with microalbuminuria (defined as UAC 30–299mg/L in a random urine specimen) were observed to have a greater than eightfold increased risk of need for renal replacement therapy period when compared to their counterparts with normoalbuminuria (UAC of 0–30mg/L), and persons with macroalbuminuria (UAC ≥ 300mg/L) were observed to have a greater than twofold increased risk of need for renal replacement therapy when compared to persons with normoalbuminuria. (Klein, et al. 1999 [3379]) (Table 77)

#### Randomized Controlled Trials Reporting on Renal Outcomes

Among articles reporting on RCTs, the following renal outcomes (number of studies reporting outcome) were reported: 1) change in GFR at study followup (n=1), 2) rate of change of GFR during study (n=1), 3) change in creatinine clearance at study followup (n=1), and 4) rate of change in creatinine clearance during study.

1. Change in GFR at Study Followup
  [underlined: Type 2 diabetes]
  One article reporting on an RCT studying an ‘intensive’ multifactorial diabetes intervention versus ‘standard’ diabetes care assessed the magnitude of decline in GFR at study followup. Persons with mean ages ranging from 54.9 to 55.2 years and with microalbuminuria (UAE 30–300mg/24hrs, obtained from 24 hour urine specimen) receiving ‘standard’ diabetes care were reported to have a decrease in GFR of 13 ml/min/1.73m^2^ over a 3.8 year study followup period when compared to persons receiving the ‘intensive’ intervention, who were reported to have a decrease in GFR of 11 ml/min/1.73m^2^ over the same period. No data on persons with other levels of UAE was reported in this study. (Gaede, et al. 1999 [613]) (Tables 70, 78)
2. Rate of Change in GFR During Study
  [underlined: Type 2 diabetes]
  One article reporting on an RCT studying the Angiotensin Converting Enzyme (ACE) inhibitor Enalapril versus conventional (“control”) blood pressure therapy assessed the rate of change in GFR during study followup among 121 persons with type 2 diabetes over a three year study period. In this study, persons with greater UAE at baseline had a greater rate of decline in GFR within both the Enalapril and the control groups. Among persons receiving Enalapril, those with normoalbuminuria (AER <30mg/24hrs in a 24 hour urine specimen) had a mean (SE) decline in GFR of 0.386 (0.178) ml/min/1.73m^2^/month, while persons with microalbuminuria (AER 30–300mg/24 hours) experienced a mean (SE) decline in GFR of 0.003 (0.178) ml/min/1.73m^2^/month, and persons with baseline AER >300mg/24hrs experienced a mean (SE) decline in GFR of 0.533 (0.158) ml/min/1.73m^2^/month. Among persons receiving conventional therapy, those with normoalbuminuria had a mean (SE) decline in GFR of 0.235 (0.15) ml/min/1.73m^2^/month, while persons with microalbuminuria had a mean (SE) decline in GFR of 0.416 (0.192) ml/min/1.73m^2^/month, and persons with baseline macroalbuminuria experienced a mean (SE) decline in GFR of 0.785 (0.253) ml/min/1.73m^2^/month. Overall, the reported magnitude of GFR decline was greater among groups receiving conventional therapy when compared with persons receiving Enalapril. (Lebovitz, et al. 1994 [1366]) (Table 79)
3. Change in Creatinine Clearance at Study Followup
  [underlined: Type 2 diabetes]
  In one article reporting on an RCT studying the ACE inhibitor Lisinopril versus Nifedipine anti-hypertension therapy, the magnitude of decline in creatinine clearance at study population was assessed in 162 persons with Type 2 diabetes. Persons with microalbuminuria (AER 20–200 μg/min in a timed urine specimen) receiving Lisinopril therapy were reported to have a decrease in creatinine clearance of 1 ml/min/1.73m^2^ over a 24 week treatment period when compared to persons receiving Nifedipine therapy, who were reported to have a decrease in creatinine clearance of 2 ml/min/1.73m^2^. No data on persons with other levels of UAE was reported in this study. (Crepaldi, et al. 1995 [1158]) (Table 80)
4. Rate of Change in Creatinine Clearance During Study
  [underlined: Type 1 diabetes]
  One article reporting on a RCT studying the ACE inhibitor Captopril versus conventional blood pressure therapy assessed the magnitude of rate of decline in creatinine clearance among 235 persons with mean ages ranging from 31.8 to 32.5 years and type 1 diabetes over a two year study period. Persons with microalbuminuria (AER 20–200μg/min in a timed urine specimen) receiving conventional therapy were reported to have a mean (range) decrease in creatinine clearance of 6.4 (2.5–10.5) ml/min/1.73m^2^/year compared with persons receiving Captopril therapy who were reported to have a mean (range) decrease in creatinine clearance of 1.4 (2.6–5.3) ml/min/1.73m^2^/year. No data on persons with other levels of UAE was reported in this study. (Captopril reduces the risk of nephropathy in IDDM patients with microalbuminuria. The Microalbuminuria Captopril Study Group1996 [1061]) (Tables 70, 81)

#### Cohort Studies Reporting on All-Cause Mortality

Among all articles reporting on cohort studies in which total mortality was assessed (n=22), four reported on persons with type 1 diabetes, 16 reported on persons with type 2 diabetes, one reported on persons with both types 1 and 2 diabetes, and one article did not specify the type of diabetes.

[underlined: Type 1 diabetes]

In four articles reporting on all-cause mortality in persons with type 1 diabetes, greater UAE at baseline as associated with a greater cumulative incidence and risk of all-cause mortality at followup. In one study of persons with a mean (SD) age of 27.5 (9.5) years, persons with normoalbuminuria (UAC <50mg/L in a 24 hour urine specimen) had a 3.2 percent cumulative incidence of all-cause mortality over 10 years of followup, while persons with microalbuminuria (UAC 51–499mg/L) had a 5.3 percent cumulative incidence of all-cause mortality, and persons with macroalbuminuria (UAC ≥ 500mg/L) had a 31.1 percent cumulative incidence of all-cause mortality during the study period. In this same study, persons with UAC ≥50mg/L had a greater than threefold increased risk of all-cause mortality when compared to persons with microalbuminuria after adjustment for age, gender, duration of diabetes, smoking, total cholesterol, and social status. (Muhlhauser, et al. 2000 [283]) (Tables 69, 82) (Muhlhauser, et al. 2000 [293])

In a second study, persons with mean (SD) age of 39.6 (12.6) years and normoalbuminuria (AER <31mg/24hrs in a 24 hour urine specimen) had a 15 percent cumulative incidence of all-cause mortality over 10 years, while persons with microalbuminuria (AER 31–299mg/24hrs) had a 25 percent cumulative incidence of all-cause mortality, and persons with macroalbuminuria (AER ≥300mg/24hrs) had a 44 percent cumulative incidence of all cause mortality during this time period. No risk estimates adjusted for potential confounders were reported. (Rossing, et al. 1996 [991])(Tables 69, 82)

In a third study, persons of mean (SD) age of 35 (11) years with normoalbuminuria (UAC <12.5 mg/L in a random urine sample) had a 1.6 percent cumulative incidence of all-cause mortality over 5 years, while persons with UAC 12.5–30mg/L had a 2.9 percent cumulative incidence of all-cause mortality, persons with microalbuminuria (UAC 31–299mg/L) had a 4.5 percent cumulative incidence of all-cause mortality, and persons with macroalbuminuria (UAC ≥ 300mg/L) had a 12 percent cumulative incidence of all-cause mortality during study followup. No risk estimates adjusted for potential confounders were reported. (Torffvit, et al. 1993 [1508]) (Tables 69, 82)

[underlined: Type 2 diabetes]

In 14 articles reporting on persons with type 2 diabetes and all-cause mortality, greater UAE at baseline was associated with greater cumulative incidence and risk of all-cause mortality at followup. In these studies of persons with mean and median ages ranging from 53.8 to 67.2 and 58 to 68.2 years, respectively, cumulative incidence of all-cause mortality ranged from 3.8 percent to 58.1 percent among persons with normoalbuminuria (less than microalbuminuria as defined for each study), from 13.2 percent to 63.9 percent in groups with microalbuminuria (with varying definitions among random, timed, and 24 hour specimens), and from 12 percent to 75 percent for persons with macroalbuminuria (greater than microalbuminuria as defined for each study) over study periods ranging from 2 to 10 years followup. For studies estimating incremental risk of all-cause mortality compared to persons with normoalbuminuria, microalbuminuria and macroalbuminuria were found to be associated with a 20 percent to fourfold increase in risk of all-cause death in both crude and adjusted analyses. (de Grauw, et al. 2001 [216]; Biderman, et al. 2000 [392]; Hanninen, et al. 1999 [580]; Mattock, et al. 1998 [659]; Araki, et al. 1997 [930]; Beilin, et al. 1996 [1009]; Gall, et al. 1995 [1146]; Chan, et al. 1995 [1195]; MacLeod, et al. 1995 [1218]; Neil, et al. 1993 [1454]; Mattock, et al. 1992 [1603]; Damsgaard, et al. 1992 [1622]; Schmitz, et al. 1988 [1986]; Stehouwer, et al. 2002 [6834]) (Tables 69, 83)

[underlined: Types 1 and 2 Diabetes, or diabetes type not specified]

In three cohort studies reporting on types 1 and 2 diabetes and in one study where the type of diabetes studied was not reported, greater UAE at baseline was associated with greater incidence of all-cause mortality among persons of mean age ranging from 56.2 to 66 years. In studies reporting incidence rates, the cumulative incidence of all-cause mortality over 5–11 years ranged from 3.7 percent to 49.9 percent among persons with normoalbuminuria and ranged from 10 percent to 63.9 percent among persons with microalbuminuria. In a single study reporting incidence rates per person year, the incidence rate ranged from 3.2 events per 100 person years in persons with normoalbuminuria to 3.6 events per 100 persons years in persons with macroalbuminuria. No risk estimates adjusted for potential confounders were reported. (Hoy, et al. 2001 [160]; Mlacak, et al. 1999 [465]; Damsgaard, et al. 1993 [1429]; Niskanen, et al. 1993 [1452])(Tables 69, 84)

#### Clinical Trials Analyzed as Cohort Studies, Reporting on All-Cause Mortality

[underlined: Types 1 and 2 diabetes]

In one article reporting on a RCT analyzed as a cohort study in post-hoc analysis, greater UAE at baseline was associated with greater risk of all-cause mortality. In this study of persons with both types 1 and 2 diabetes and mean (SD) age of 65.4(6.5) years, the cumulative incidence of all-cause mortality for persons with normoalbuminuria was reported as 9.3 percent over a 4.5 year followup, compared with a cumulative incidence of 18.6 percent over followup for persons with microalbuminuria (ACR ≥ 2mg/mmol in a random urine specimen). Persons randomized to Ramipril had lower cumulative incidence rates than persons randomized to placebo, and this remained true for strata of UAE within randomized groups. For persons with levels of ACR below 1.62mg/mmol, the crude risk of these outcomes appeared to increase with increasing quartiles of ACR exposure. After adjustment for randomization to Ramipril, all persons with microalbuminuria were reported to have a two-fold increased risk of all-cause mortality at study followup when compared to persons with ACR below 2mg/mmol. In subgroup analyses, persons randomized to placebo and Ramipril with microalbuminuria were found to have respective 85 percent and 64 percent increased risks of all-cause mortality when compared to their counterparts with normoalbuminuria after adjustment for age, gender, duration of diabetes, weight, blood pressure, insulin therapy, smoking, glycemic control, cholesterol, serum creatinine, and use of oral hypoglycemic agents. (Gerstein, et al. 2001 [136]) (Tables 69, 85)

#### Randomized Controlled Trials Reporting on All Cause Mortality

[underlined: Type 2 diabetes]

One article reporting on a RCT assessed all cause mortality. In this study, 160 persons with type 2 diabetes and mean ages ranging from 54.9 to 55.2 were randomized to an ‘intensive’ multi-factorial diabetes intervention or ‘standard’ diabetes care for 4 years. Albumin excretion rates were obtained from 24-hour urine specimens. Microalbuminuria was defined as 30–300 mg/24 hrs. The incidence of all cause mortality in person with microalbuminuria ranged from 3 percent in persons receiving the ‘standard’ intervention to 5.19 percent in persons receiving the ‘intensive’ intervention. Persons with normoalbuminuria were not studied, and no risk estimates adjusted for potential confounders were reported. (Gaede, et al. 1999 [613]) (Tables 70, 86)

#### Cohort Studies Reporting on Composite CVD Mortality

[underlined: Type 1 diabetes]

Among all articles reporting on cohort studies featuring composite CVD mortality, one studied persons with type 1 diabetes. In this study, of 3674 persons with mean (SD) age of 27.5 (9.5), greater UAE at baseline was associated with greater incidence of composite CVD mortality at followup. Persons with normoalbuminuria (AER ≤ 50mg/24hrs in a 24 hour urine specimen) had a 10-year cumulative incidence of 1.03 percent, while persons with microalbuminuria (AER 51–499 mg/24hrs) had a cumulative incidence of 1.91 percent, and persons with macroalbuminuria (AER ≥ 500mg/24hrs) had a cumulative incidence of 13.9 percent at followup. No risk estimates adjusted for potential confounders were reported. (Muhlhauser, et al. 2000 [293]) (Tables 69, 87)

[underlined: Type 2 diabetes]

Among 10 articles reporting on cohort studies of persons with type 2 diabetes that assessed composite CVD mortality, greater baseline UAE was associated with greater incidence and risk of composite CVD mortality. Among persons with mean and ages ranging from 54 and 67.9 years, respectively, the incidence of composite CVD mortality ranged from 0 percent to 39 percent among persons with normoalbuminuria, from 11.62 percent to 72 percent among persons with microalbuminuria, and from 19 percent to 32 percent for persons with macroalbuminuria over 2 to 12 years followup. For studies reporting incidence in person years, the incidence of composite CVD mortality ranged from 0.33 events per 100 person years to 3.69 events per 100 person years for persons with normoalbuminuria, from 0.34 events per 100 person years to 11.3 per100 persons years for persons, and in a single study persons with macroalbuminuria were reported to have an incidence rate of 12.3 events per 100 person years. Among studies reporting adjusted estimates of relative risk, persons with microalbuminuria were reported to have 83 percent to greater than threefold increased risk of composite CVD mortality when compared to their counterparts with normoalbuminuria in fully-adjusted regression models. Persons with macroalbuminuria were reported to have greater than twofold to greater than threefold increased risk of composite CVD mortality when compared to their counterparts with normoalbuminuria in fully adjusted regression models. (de Grauw, et al. 2001 [216]; Valmadrid, et al. 2000 [411]; Mattock, et al. 1998 [659]; Araki, et al. 1997 [930]; Beilin, et al. 1996 [1009]; Niskanen, et al. 1996 [1067]; Gall, et al. 1995 [1146]; MacLeod, et al. 1995 [1218]; Neil, et al. 1993 [1454]; Mattock, et al. 1992 [1603]) (Tables 69, 88)

#### Randomized Controlled Trials Reporting on Composite CVD Mortality

[underlined: Type 2 diabetes]

One article reported on a RCT which assessed the magnitude of composite CVD mortality in 160 persons with mean age ranging from 54.9 to 55.2 and type 2 diabetes. In this study of an ‘intensive’ multi-factorial diabetes intervention versus ‘standard’ diabetes care, participants were followed for 3.8 years. The cumulative incidence of composite CVD mortality among persons with microalbuminuria (AER 30–300mg/24 hrs obtained from 24 hour urine specimens) ranged from 2.56 percent to 3.9 percent. Persons with normoalbuminuria were not studied, and no risk estimates adjusted for potential confounders were reported. (Gaede, et al. 1999 [613]) (Tables 7, 89)

#### Cohort Studies Reporting on Cause Specific CVD Mortality: Death from Myocardial Infarction

[underlined: Type 1 diabetes]

In one article reporting on a cohort study of persons with mean (SD) age of 39.6 (12.6) and type 1 diabetes, greater levels of UAE at baseline were associated with greater cumulative incidence of death due to myocardial infarction over 10 years of followup. While persons with normoalbuminuria (AER ≤ 31mg/24hrs in a 24 hour urine specimen) had a cumulative incidence of 2.87 percent, persons with microalbuminuria (AER 31–299mg/24 hrs) and macroalbuminuria (AER ≥300mg/24hrs) had cumulative incidence rates of 7.18 percent and 5.45 percent, respectively. No risk estimates adjusted for potential confounders were reported. (Rossing, et al. 1996 [991]) (Tables 69, 90)

[underlined: Type 2 diabetes]

In one article reporting on a cohort study of persons with mean (SD) age 54 (9) and type 2 diabetes, greater levels of UAE at baseline were associated with greater cumulative incidence of death due to myocardial infarction over 5 years followup. While persons with normoalbuminuria (AER < 30mg/24hrs in a 24 hour urine specimen) had a cumulative incidence of 1.57 percent, persons with microalbuminuria (AER 30–200mg/24hrs) had a cumulative incidence of 8.14 percent, and persons with macroalbuminuria (AER >300mg/24hrs) had a cumulative incidence of 11.8 percent. No risk estimates adjusted for potential confounders were reported. (Gall, et al. 1995 [1146]) (Tables 69, 91)

#### Cohort Studies Reporting on Cause Specific CVD Mortality: Death from Cerebrovascular Accident (CVA)

[underlined: Type 1 diabetes]

Of two articles of cohort studies of persons with type 1 diabetes, greater baseline UAE was associated with greater incidence of death secondary to a cerebrovascular accident. In one study, persons with mean (SD) age 27.5 (9.5) years and normoalbuminuria (AER ≤50mg/24hrs in a 24 hour urine specimen) had a cumulative incidence of 0.11 percent over 10 years, while persons with microalbuminuria (AER 41–400mg/24hrs) had a cumulative incidence of 0.08 percent, and persons with macroalbuminuria (AER ≥500mg/24hrs) had a cumulative incidence of 4.63 percent. (Muhlhauser, et al. 2000 [293]) In the other study, persons with mean (SD) age of 36 (12.6) years and normoalbuminuria (AER <31mg/24hrs in a 24 hour urine specimen) had a cumulative incidence of death secondary to cerebrovascular accident of 0.67 percent over 10 years, while persons with microalbuminuria (AER 31–299mg/24hrs) had a cumulative incidence of 0.55 percent, and persons with macroalbuminuria (AER ≥300mg/24hrs) had a cumulative incidence of 3.05 percent. No risk estimates adjusted for potential confounders were reported. (Rossing, et al. 1996 [991]) (Tables 69, 92)

[underlined: Type 2 diabetes]

In one article reporting on a cohort study of persons with mean (SD) age 54 (9) years and type 2 diabetes, greater baseline UAE was associated with greater cumulative incidence of death secondary to cerebrovascular accident. Persons with normoalbuminuria (AER ≤30mg/24 hrs in a 24 hour urine specimen) had a cumulative incidence of 0.52 percent over 5 years, while persons with microalbuminuria (AER 30–299mg/24hrs) had a cumulative incidence of 2.32 percent, and persons with macroalbuminuria (AER ≥300mg/24hrs) had a cumulative incidence of 3.92 percent over followup. No risk estimates adjusted for potential confounders were reported. (Gall, et al. 1995 [1146]) (Tables 69, 93)

#### Cohort Studies Reporting on CVD Morbidity

[underlined: Type 1 diabetes]

In two articles reporting on cohort studies of persons with type 1 diabetes, greater baseline UAE was associated with greater incidence and risk of assorted CVD morbidity events. In one study, the cumulative incidences of amputation and blindness among persons with mean (SD) age of 27.5 (9.5) years were reported as 0.5 percent and 0.4 percent respectively for persons with normoalbuminuria (AER ≤50mg/24 hours in a 24 hour urine specimen), 1.7 percent and 1.2 percent respectively for persons with microalbuminuria (AER 51–499mg/24hrs), and 10.5 percent and 5.8 percent respectively for persons with macroalbuminuria (AER ≥500mg/24hrs) over a 10 year period of followup. No risk estimates adjusted for potential confounders were reported. (Muhlhauser, et al. 2000 [283]) In the other study, persons with mean age 34.7 years and microalbuminuria (AER 30–300mg/24hrs in a 24 hour urine specimen) had greater than twofold increased risk of atherosclerotic vascular disease over a 7 year period when compared to their counterparts with normoalbuminuria (AER <30mg/24hrs) after adjustment f or age, gender, diabetes duration, blood pressure, insulin therapy, smoking, glycemic control, total cholesterol, sialic acid, and Von Willebrand factor levels. (Deckert, et al. 1996 [1074]) (Tables 69, 94)

[underlined: Type 2 diabetes]

In one article reporting on a cohort study of persons with mean (SD) age of 58 (0.2) years and type II diabetes, greater baseline UAE was associated with greater cumulative incidence and risk of stroke and amputation over 7 years followup. Persons with normoalbuminuria (UAC <150mg/L in a random urine specimen) had cumulative incidence rates for stroke and amputation of 7.2 percent and 3.9 percent respectively, while persons with microalbuminuria (UAC 150–299mg/L) had cumulative incidence rates of 11.1 percent and 5.7 percent, respectively, and persons with macroalbuminuria (UAC ≥ 300mg/L) had cumulative incidence rates of 23 percent and 12.2 percent respectively. In this same study, persons with microalbuminuria had 13 percent to 36 percent increased risk of stroke and amputation at followup when compared to their counterparts with normoalbuminuria in fully-adjusted multivariate regression models, while persons with macroalbuminuria had greater than two-fold increased risks of these outcomes when compared to their counterparts with normoalbuminuria in fully-adjusted multivariate regression models. (Miettinen, et al. 1996 [977]) (Tables 69, 95)

#### Cohort Analyses of Randomized Controlled Trials Reporting on CVD Morbidity

[underlined: Types 1 and 2 diabetes]

One article reporting on a cohort analysis of an RCT assessing hospitalization for congestive heart failure, and this article reported greater risk of hospitalization for congestive heart failure among persons with greater baseline UAE over 4.5 years of followup. Persons with mean (SD) age of 65 (6.5) years and normoalbuminuria (ACR <2mg/mmol assessed in a random urine specimen) had a cumulative incidence of hospitalization for congestive heart failure of 9.3 percent, while persons with microalbuminuria (ACR≥2mg/mmol) had a cumulative incidence of 18.6 percent. Among persons randomized to the ace inhibitor Ramipril versus placebo, those randomized to Ramipril had lower cumulative incidence of events than those randomized to placebo, and this remained true for strata of UAE within randomized groups. Greater than threefold increased risk of hospitalization for congestive heart failure was observed among persons with microalbuminuria when compared to their counterparts with normoalbuminuria in crude and adjusted multivariate regression models (adjusted for randomization to Ramipril). In subgroup analyses, greater than four-fold and two-fold increased risk in hospitalization for congestive heart failure were observed among persons with microalbuminuria who were randomized to placebo and Ramipril, respectively after adjustment for age, gender, duration of diabetes, weight, blood pressure, insulin therapy, smoking, glycemic control, cholesterol, serum creatinine, and use of oral hypoglycemic agents. For persons with levels of ACR below 1.62 mg/mmol, the crude risk of this outcome appeared to increase with increasing quartiles of ACR exposure. (Gerstein, et al. 2001 [136]) (Tables 69, 96)

#### Randomized Controlled Trials Reporting on CVD Morbidity

[underlined: Type 2 diabetes]

One article reported on a RCT assessing the magnitude of CVD morbidity among persons with microalbuminuria (AER 30–300mg/24hrs in a 24 hour urine sample) who were randomized to an “intensive” multifactorial diabetes intervention or “conventional” diabetes care. Events included non-fatal myocardial infarction, coronary artery bypass grafting, cerebrovascular accident, and amputation. Among persons with mean age ranging from 55.2 to 54.9 years, over 4 years of followup, cumulative incidence rates for non-fatal myocardial infarction ranged from 5.13 percent to 5.19 percent, cumulative incidence rates for coronary artery bypass grafting ranged from 2.15 percent to 5.13 percent, cumulative incidence rates for cerebrovascular accident ranged from 1.3 percent to 10.3 percent, and cumulative incidence rates for amputation ranged from 5.13 percent to 5.19 percent. Persons with normoalbuminuria or macroalbuminuria were not studied, and no risk estimates adjusted for potential confounders were reported. (Gaede, et al. 1999 [613]) (Tables 70, 97)

#### Cohort Studies Reporting on Composite CVD Morbidity and Mortality

[underlined: Type 2 diabetes]

Three articles reporting on cohort studies which assessed composite CVD morbidity and mortality demonstrated that greater risk of these outcomes were associated with greater baseline UAE. In one study of persons with a mean age of 47.9 years, persons with microalbuminuria (defined as AER 10.1–20 obtained from a 24 hour urine specimen) had 90 percent greater risk of non-fatal myocardial infarction, angina, congestive heart failure, peripheral vascular disease, or all cause death when compared to their counterparts with normoalbuminuria (AER ≤10mg/24hrs) after 8 years of followup. Persons with macroalbuminuria (AER 20.1–30mg/24hrs) experienced greater than nine-fold increased risk of these outcomes when compared to their counterparts with normoalbuminuria after age-adjustment. (Rachmani, et al. 2000 [336]) (Tables 69, 98)

In a second study of persons with mean (SD) age 58.1 (0.2), persons with normoalbuminuria (UAC <150mg/L in a random urine specimen) had cumulative incidence rates of atherosclerotic vascular diseases (including congestive heart disease death or non-fatal myocardial infarction, stroke, or amputation) and congestive heart disease or non-fatal myocardial infarction alone of 26 percent and 18.4 percent respectively, while persons with microalbuminuria (UAC 150–299mg/L) had cumulative incidence rates of 35.7 percent and 25.7 percent, respectively, and persons with macroalbuminuria (UAC ≥300mg/l) had cumulative incidence rates of 52.5 percent and 34.5 percent, respectively over 7 years of followup. In this same study, persons with microalbuminuria had 30–38 percent increased risk of developing these outcomes when compared to their counterparts with normoalbuminuria after adjustment in multivariate regression models (controlling for age, gender, study area, previous amputation, smoking, total cholesterol, HDL or LDL cholesterol, glycemic control, and duration of diabetes), and persons with macroalbuminuria had greater than one to twofold increased risk in developing these outcomes when compared to their counterparts with normoalbuminuria after adjustment. (Miettinen, et al. 1996 [977]) (Tables 69, 98)

In the third study, persons with mean (SD) age of 54.5 (10.2) years and microalbuminuria (UAC 31–299 mg/L in a random urine specimen) had 50 percent increased risk of developing vascular morbidity (myocardial infarction, cerebrovascular disease, amputation) or death when compared to their counterparts with normoalbuminuria (UAC <12.5mg/L) (result not statistically significant), while persons with macroalbuminuria (UAC ≥300mg/L) had greater than threefold increased risk of developing these outcomes (after adjustment for age, diabetes duration, blood pressure, age at diagnosis, glycemic control, and serum creatinine) when compared to their counterparts with normoalbuminuria (result statistically significant) over 5 years followup. In this same study, persons with an intermediate level of urine protein (UAC 12.5–30mg/L) also had a 37 percent increased risk of developing these outcomes, although this adjusted risk was not statistically significantly different from the reference group. (Agardh, et al. 1996 [1075]) (Tables 69, 98)

#### Cohort Analyses from Randomized Controlled Trials Reporting on Composite CVD Morbidity and Mortality

[underlined: Types 1 and 2 diabetes]

In one article reporting on a cohort analysis of an RCT of persons with mean (SD) age of 65.4 (6.5) years, those with greater baseline UAE were observed to have greater risk of developing myocardial infarction, stroke, or cardiovascular death over 4.5 years of followup. Persons with normoalbuminuria (ACR <2mg/mmol in a random urine specimen) were found to have a cumulative incidence of these outcomes of 13.9 percent while persons with microalbuminuria (ACR≥2mg/mmol) had a 25 percent incidence of these outcomes at followup. Persons with microalbuminuria also had 97 percent increased risk of developing these outcomes when compared to their counterparts with normoalbuminuria after adjustment for randomization to Ramipril. In subgroup analyses, among persons randomized to placebo and Ramipril, persons with microalbuminuria had 84 percent and 44 percent increased risks of developing these outcomes when compared to their counterparts with normoalbuminuria, respectively (after adjustment for age, gender, duration of diabetes, weight, blood pressure, insulin therapy, smoking, glycemic control, cholesterol, serum creatinine, and use of oral hypoglycemic agents). For persons with levels of ACR below 1.62 mg/mmol, the crude risk of these outcomes appeared to increase with increasing quartiles of ACR exposure. (Gerstein, et al. 2001 [136]) (Tables 69, 99)