# Methodology

## Recruitment of Technical Experts and Peer Reviewers

The Evidence-based Practice Center (EPC) recruited six technical and community experts to provide input into the definition of the key questions and to review a draft of the report. The EPC also recruited representatives from a range of other stakeholder organizations to serve as peer reviewers of the draft Evidence Report. These stakeholder organizations included organizations of physicians, allied health professionals, and third party health care payers in addition to consumer organizations.

## Process of Systematic Review

Because of the divergent content of questions related to glycemic control and urine albumin, two separate teams of investigators systematically reviewed literature in these two areas. Investigators from each team executed systematic search strategies pertinent to each set of questions. Thus, search strategies and studies identified were different for questions on glycemic control and urine albumin. This chapter details methodology used to systematically review literature pertaining to each set of questions.

## Glycemic Control

### Identification of Studies and Data Abstraction

#### Data Sources

Articles published in English language from 1966 to April 2002 were identified by searching MEDLINE^®^ accessed through PubMed^®^ using MESH and text words for glycohemoglobin, diabetes, and individuals diabetic complications, including retinopathy, nephropathy, neuropathy, and cardiovascular disease. To identify studies that measured glycated hemoglobin exposure, the MESH terms “hemoglobin A, glycosylated” and “hyperglycemia” and the following text terms were used: “A1c,” “HbA1c,” “HbA1,” “GHb,” “glycohemoglobin,” “glycohaemoglobin,” “glycosylated,” “hemoglobin,” “glycosylaed,” “haemoglobin,” “glycemia,” “glycaemia,” “hyperglycemia,” “hyperglycaemia.” The MeSH term “diabetes mellitus” and the text term “diabetes” were used to identify studies of persons with diabetes mellitus. To identify studies focusing on diabetic retinopathy, we used the MESH term “diabetic retinopathy” and the text terms “retinopathy,” “eye-disease,” “retinal-disease,” “eye,” and “eyes.” To identify studies reporting nephropathy outcomes, we used the MESH terms “diabetic nephropathies,” “albuminuria,” “glomerular filtration rate,” “kidney disease,” and “kidney failure” and the text words “nephropathy” and “albuminuria.” To identify studies reporting neuropathy outcomes, we used the MESH term “diabetic neuropathies” and the text terms “neuropathy” and “neurological.” To identify studies reporting cardiovascular outcomes, we used the MESH term “cardiovascular diseases” and the following text terms: “angina,” “cardiovascular artery disease,” “cardiovascular disease,” “cardiovascular heart disease,” “congestive heart disease,” “ischemic heart disease,” “ischaemic heart disease,” “myocardial infarction,” “peripheral artery disease,” “stroke,” and “transient ischemic attack.” To obtain additional references not otherwise identified through the electronic search, we searched bibliographies of relevant primary and review articles from our electronic search.

### Study Selection

We restricted our review to prospective longitudinal cohort studies, non-concurrent prospective cohort studies, and clinical trials that had data on glycated hemoglobin exposure and outcome data on individual microvascular and macrovascular complications during at least 1 year of follow-up in at least 50 participants with type 1 or type 2 diabetes. Because we were interested in determining the risk relationship between glycated hemoglobin exposure and microvascular and macrovascular complications and in re-examining whether a threshold exists for this relation, we only included studies that reported prospective, quantitative risk data (i.e. incidence rates (IR), regression coefficients with standard errors reported separately; relative hazards (RH), relative odds (OR), relative risk (RR)). Retrospective case-control studies that reported and compared previous glycated hemoglobin values in individuals with a given outcome versus those without a given outcome were excluded. Articles that reported data in graphical form in which specific quantitative values could not be determined were also excluded. If outcome risks were reported by glycated hemoglobin level, the levels had to be quantitatively defined for a study to be included. Similarly, if the outcome risk was reported for each unit change in glycated hemoglobin, the mean glycated hemoglobin of the study population had to be reported for a study to be included so that there was adequate exposure summary data.

Other exclusion criteria included review articles, animal or in vitro studies, non-English language, and studies in which the design was unclear.

### Exposure Variables

[underlined: Glycosylated hemoglobin:] Data were abstracted on the biochemical method of measurement, whether the method was traceable to the DCCT standard and/or whether the lab was certified by the NGSP, and how glycosylated hemoglobin was reported (i.e. HbA1c, HbA1, total GHB)(See Appendix C). Summary data on glycated hemoglobin exposure was recorded as reported in each study—mean or median overall glycated hemoglobin and/or categories of glycated hemoglobin exposure.

[underlined: Diabetes mellitus:] Data were extracted on the type of diabetes that study participants had and the method of diagnosis/confirmation.

### Outcome Variables

#### Microvascular Outcomes

[underlined: Retinopathy]: Incident retinopathy was defined as new onset retinopathy, progression of pre-existing retinopathy, cataract extraction, incident macular edema, need for focal or scatter photocoagulation, blindness, or change in visual acuity. When reported, the method of assessment of retinopathy was recorded (i.e. fundus photography, direct ophthalmoscopy) as well as the grading scale for retinopathy (i.e. Early Treatment of Diabetic Retinopathy Study [ETDRS] scale; see Appendix C).

[underlined: Nephropathy]: Incident nephropathy was defined as development of microalbuminuria and progression of nephropathy as progression from micro- to macroalbuminuria or progression to end-stage renal disease requiring renal replacement therapy. Other nephropathy outcomes included change in glomerular filtration rate/creatinine clearance. Data were recorded on how albumin excretion was defined (i.e. albumin excretion rate, albumin:creatinine ratio, dipstick) and the biochemical methods of measuring urinary albumin and creatinine.

[underlined: Neuropathy]: Data on peripheral and autonomic neuropathy were recorded. Peripheral neuropathy was defined as an abnormal neurological exam, subjective symptoms, abnormal biothesiometry, or abnormal nerve conduction study. Autonomic neuropathy was defined as abnormal R-R interval, orthostatic hypotension, or resting tachycardia.

#### Macrovascular Outcomes

[underlined: Coronary Artery Disease] (CAD): CAD morbidity was defined as non-fatal myocardial infarction, angina, ischemic heart disease, congestive heart failure secondary to ischemic heart disease, coronary artery bypass surgery, and angioplasty. When reported, confirmatory ICD 9 codes were recorded. CAD mortality was defined as fatal myocardial infarction (ICD 9 code recorded if reported) and sudden cardiac death. If the death was confirmed by national or state death certificate registry, these data were recorded.

[underlined: Cerebrovascular Disease]: Cerebrovascular morbidity was defined as non-fatal stroke, transient ischemic attack, or need for carotid endarterectomy. Cerebrovascular mortality was defined as fatal stroke. If the death was confirmed by national or state death certificate registry, these data were recorded.

[underlined: Peripheral Arterial Disease] (PAD): PAD was defined as claudication, peripheral revascularization procedure (angioplasty, bypass surgery, stenting), gangrene, limb amputation, decreased ankle-brachial index, and decreased arm-toe gradient.

[underlined: Others]: Outcome data were collected on congestive heart failure (CHF) not related to ischemic heart disease and presence of atherosclerosis (i.e. carotid intimal-medial thickness (IMT), abdominal aortic aneurysm).

### Other Variables

Data were recorded on other variables including treatment (if indicated), demographic characteristics, metabolic characteristics, study design, study location, source of study participants, and exclusion criteria.

### Data Abstraction

Two investigators reviewed titles and abstracts of identified articles and appropriate studies were selected for data abstraction. Three investigators extracted data from each article onto standardized data collection forms. Each abstracted article was reviewed by a second reviewer to ensure that all relevant data had been obtained and was correct. All three reviewers are board-certified internists and one reviewer is an endocrinologist cross-trained in epidemiology and specializing in diabetology.

## Urine Albumin

### Identification of Studies and Data Abstraction

#### Data Sources

Articles published in English language from 1966 to April 2002 were identified by searching MEDLINE^®^ accessed through PubMed^®^ using MESH and text words for diabetes, proteinuria, and cardiovascular or renal outcomes. The MESH term “diabetes mellitus” and the text term “diabetes” was used to identify studies of persons with diabetes mellitus. To identify studies focusing on urine albumin, we used the MESH terms “proteinuria,” “kidney diseases,” and “albuminuria,” and the following text terms: “albumin excretion”, “albuminuria,” “microalbuminuria,” “nephropathy,” and “proteinuria.” To identify studies reporting on renal, cardiovascular outcomes, and death, we used the MESH terms “glomerular filtration rate,” “kidney failure,” and “peripheral vascular diseases” and the following text words: “angina,” coronary artery disease,” “cardiovascular disease,” “cardiovascular heart disease,” “congestive heart disease,” “death,” “ischemic heart disease,” “mortality,” “myocardial infarction,” “peripheral artery disease,” “stroke,” and “transient ischemic attack”. To obtain additional references not otherwise identified through the electronic search, we searched bibliographies of relevant primary and review articles from our electronic search.

### Study Selection

After identification of citations through PubMed^®^, all abstracts were reviewed for relevance by a single abstractor. All articles to be potentially included in the final review underwent double review by study authors for data abstraction. Differences in opinion were resolved through consensus adjudication. Data abstracted included 1) study design, 2) study location, 3) numbers of study subjects enrolled, 4) study exclusion criteria, 5) type of diabetes studied and numbers of persons with each type of diabetes included in study, 6) measurement and definitions of levels of urine albumin exposure, 7) descriptive information about study participants (including age, gender, race, duration of diabetes, glycemic control, baseline diastolic and systolic blood pressure), 8) baseline and followup measures of urinary albumin excretion, and 9) baseline and followup measures of kidney function (e.g. serum creatinine, creatinine clearance, or direct measurement of glomerular filtration rates). For randomized controlled trials featuring medication interventions (e.g. ACE inhibitors vs. other anti-hypertension agents) the type of medication, dose and frequency were also recorded.

### Exposure Variables

[underlined: Urine albumin:] Data were abstracted on the biochemical method of measurement of urine measurement, including the timing of urine specimens and the cutoffs used to define different levels of urine albumin exposure at baseline. Unless otherwise specified by study authors, we considered ‘microalbuminuria’ to be present among study subjects if urine albumin excretion was classified as being in the range of 30–200 mg/24 hours in 24 hour urine specimens, 20–199μg/min in 24 hour and other timed urine specimens, or 30–299μg albumin per mg creatinine in random or spot urine specimens. For studies assessing multiple cutoff levels for urine albumin exposure, persons with the least level of exposure (less than microalbuminuria) were considered to have ‘normoalbuminuria’, while persons with greatest level of exposure were considered to have ‘macroalbuminuria’. In cases where additional cutoffs for urine albumin level were made between non-detectable levels of urine albumin (or no albuminuria) and levels considered to be consistent with ‘microalbuminuria’ such cutoffs were deemed to represent ‘intermediate’ levels of exposure to urine albumin. Use of dipstick methods for ascertainment of microalbuminuria was also recorded. Studies reporting only on persons with macroalbuminuria (levels greater than those defined above, unless authors defined microalbuminuria in some other fashion) were excluded from our analysis.

[underlined: Diabetes mellitus:] Data were extracted on study participants' type of diabetes and the reported method of diagnosis/confirmation of diabetes within each study. To help organize this diverse literature, persons reported as having type 1, insulin dependent, or younger onset diabetes were classified as having type 1 diabetes in our analysis. Persons reported as having type 2, non-insulin dependent or, older onset diabetes were classified as having type 2 diabetes in our analysis.

### Outcome Variables

#### Renal Outcomes

We divided outcomes reflecting decline in renal function over time into eight categories: 1) change in glomerular filtration rate (GFR) at end of study, 2) rate of change in GFR, 3) change in creatinine clearance at end of study, 4) rate of change in creatinine clearance, 5) change in 1/serum creatinine at end of study, 6) rate of change in 1/serum creatinine), 7) doubling of serum creatinine, or 8) need for renal replacement therapy, including dialysis and transplantation.

#### Cardiovascular Outcomes

We defined cardiovascular outcomes as the: 1) incidence of all cause death, 2) incidence of composite CVD deaths, 3) incidence of death due to myocardial infarction, 4) incidence of death due to cerebrovascular accident, 5) incidence of CVD morbidity, and 6) incidence of composite CVD morbidity and mortality.

CAD morbidity was defined as non-fatal myocardial infarction, angina, ischemic heart disease, congestive heart failure secondary to ischemic heart disease, coronary artery bypass surgery, and angioplasty. When reported, confirmatory ICD 9 codes were recorded. CAD mortality was defined as fatal myocardial infarction (ICD 9 code recorded if reported) and sudden cardiac death. If the death was confirmed by national or state death certificate registry, that data was recorded. Cerebrovascular morbidity was defined as non-fatal stroke, transient ischemic attack, or need for carotid endarterectomy. Cerebrovascular morbidity was defined as fatal stroke. If the death was confirmed by national or state death certificate registry, that data was recorded. PAD was defined as claudication, peripheral revascularization procedure (angioplasty, bypass surgery, stenting), gangrene, limb amputation, decreased ankle-brachial index, and decreased arm-toe gradient. Outcome data were also collected on congestive heart failure not related to ischemic heart disease and presence of atherosclerosis (i.e. carotid intimal-medial thickness, abdominal aortic aneurysm).

### Data Abstraction and Analysis

Two investigators reviewed titles and abstracts of identified articles and appropriate studies were selected for data abstraction. Articles chosen for abstraction were reviewed by two reviewers to ensure that all relevant data had been obtained and was correct.

## Assessment of Study Quality

All reviewed articles for both questions were rated for the quality of reporting on several aspects of study external and internal validity, including 1)description of inclusion and exclusion criteria for study subjects, 2) description of study subjects' baseline characteristics, 3) description of study non-enrollees, 4)description of the study intervention, 5) length of study followup, 6)study subject attrition, 7)statistical analysis, and (for RCTs) 8) quality of randomization and 9) blinding. Based on work by Chalmers, et al, a quality score ranging from 0–100 was developed, in which ratings of reporting of external and internal validity received 70 percent of the total quality score, and aspects of statistical analysis of data received 30 percent of the total quality score. (Chalmers, et al. 1981 [565].

## Calculation of weighted averages

For studies in which the exposure data for glycated hemoglobin and microalbuminuria and baseline characteristics were given by the clinical outcomes but the risk analyses were conducted on the entire cohort, a weighted average for the whole group was calculated according to the following formulae:

Weighted mean calculations: