# Introduction

## Background

Clinical testing to assess levels of disease control and progression among persons with types 1and 2 diabetes mellitus is widely recommended to clinicians to improve patients' clinical outcomes. (American Diabetes Association: Clinical Practice Recommendations 2002 [92176]) Two important foci of recommendations for the follow-up care of individuals with diabetes include monitoring of glycemic status by measurement of glycated hemoglobin and screening for kidney disease with urine microalbumin to assess overall disease progression and to detect potential progression toward end-organ damage. According to the American Diabetes Association Clinical Practice Recommendations, monitoring of glycemic status is considered a cornerstone of diabetes care and affects how physicians and patients adjust medical therapy as well as behavioral therapy, such as diet and exercise. Screening for urine albumin among persons with diabetes is also widely recommended for the detection and treatment of incipient diabetic nephropathy, which is currently defined as the excretion of small amounts of albumin in the urine (30–200mg albumin per 24 hours) and affects physician's implementation of therapy to slow progression of kidney disease.

Despite widespread recommendations for screening of persons with diabetes for both glycemic control and urine albumin, there has not been a systematic assembly of the literature to assess the risk relation between tests assessing long-term glycemic control or tests assessing the presence of microalbuminuria with cardiovascular, peripheral vascular, renal, and neurological outcomes (all of which represent end-organ effects of long-term diabetes). This report, commissioned by the American Association of Clinical Chemistry, systematically reviews the literature identifying the risk relation between testing for glycemic control or urine albumin with these important clinical outcomes.

### Glycemic Control

#### Tests of Glycemic Control in Diabetes

Prior to implementation of patient self-monitoring of blood glucose (SMBG), patients tested their glycemic status using urine glucose testing; however, this provided only a rough estimate of glycemic control and provided no information regarding the level of glycemia below the renal threshold of 180 mg/dL (American Diabetes Association: Clinical Practice Recommendations 2002 [92176]). The advent of SMBG has allowed patients to attain glycemic goals more quickly and has revolutionized the care of individuals with diabetes mellitus; however, it does not provide information regarding glycemic control over an extended period of time (American Diabetes Association: Clinical Practice Recommendations 2002 [92176]). Measurement of glycated hemoglobin, which first began in the 1970's, has become the preferred method of assessing long-term glycemic control. Glycated hemoglobin describes a series of stable minor hemoglobin components formed by a post-translational modification in HbA1 in which glucose is nonenzymatically bound to the alpha chain of hemoglobin (Goldstein, et al.1995 [4644]). Rahbar et al. first showed that these minor HbA1 fractions were elevated in individuals with diabetes (Rahbar, et al. 1969; [92177]; Rahbar, et al. 1986 [92178]). HbA1 can be separated into three minor components, HbA1a, HbA1b, and HbA1c (see Appendix C). HbA1c was found to be the specific glycated hemoglobin resulting from post-translational modification of HbA1 by glucose and correlated with various measures of glucose (Goldstein, et al. 1995 [4644]).

Of the various glycated hemoglobin fractions, HbA1c is the preferred gold standard for assessing glycemic control over the previous 2–3 months. Glycated hemoglobin results should be expressed as percent HbA1c or percent HbA1c equivalents (if total GHB is actually measured). The American Diabetes Association began to make treatment recommendations based on HbA1c following publication of the results of the Diabetes Control and Complications Trial in the 1990's; however, at that time, there was a lack of standardization of measurement methodologies, which hindered implementation of the guidelines (American Diabetes Association: Clinical Practice Recommendations 2002 [92176]). As a result, the National Glycohemoglobin Standardization Program (NGSP), partly sponsored by the American Diabetes Association, was started in 1996 http://web.missouri.edu/~diabetes/ngsp.html (American Diabetes Association: Clinical Practice Recommendations 2002 [92176]). A follow-up study of the program reported that in 2000, 90 percent of surveyed laboratories reported glycated hemoglobin results as HbA1c or equivalent and that 78 percent of these used a NGSP-certified method (Little, et al. 2001 [4643]). The current ADA recommendations related to the use of glycated hemoglobin are that (1) all labs use only HbA1c assay methods that have been certified, (2) all labs participate in the College of American Pathologists proficiency testing survey, (3) all results be reported as “percent HbA1c” or “percent HbA1c equivalent” and (4) the goal HbA1c should be <7 percent with a therapeutic action target of >8 percent, using a DCCT traceable method (American Diabetes Association: Clinical Practice Recommendations 2002 [92176]). The HbA1c has become the gold standard for the therapeutic management of diabetes mellitus in research and in the clinical setting. The test results, however, are affected by diseases that shorten the lifespan of the red blood cells (i.e. hemolytic anemias) or diseases that are associated with hemoglobin variants (i.e hemoglobins S, C, and F), resulting in HbA1c values that may not accurately reflect long-term glycemic control (Bry, et al. 2001 [92179]).

#### Prognostic Significance of Glycated Hemoglobin Testing

While glycated hemoglobin testing gives an assessment of long-term glycemic control, what other prognostic information does it provide in the management of individuals with diabetes mellitus? Pirart first recognized the importance of poor glycemic control in the development of diabetic complications, as evidenced in his 1984 quotation: “The catastrophic loss of the macula will sometimes be prevented by a further destruction by laser of the already dying retina. Haemo- and peritoneal dialysis are a pitiful way leading to kidney transplantation with its disappointing surgical, infectious, and immunological failures. All that could have been avoided or at least much delayed, had hyperglycaemia be better mitigated in the long run and from the very beginning of a diabetic's career.”

Pirart and Lauvaux conducted the first prospective cohort study of the relation between hyperglycemia and microvascular complications in individuals with diabetes mellitus (Pirart 1995 [4642]). The study of 4,400 individuals with diabetes followed for 25 years from the onset of their disease or from a later time demonstrated that retinopathy and nephropathy were significantly related to the duration of diabetes and to sustained hyperglycemia, independent of age, gender, body weight, family history of diabetes, and severity of diabetes (Pirart 1995 [4642]). In this early study, glycemic control was assessed based on multiple daily urine tests to detect glucosuria and blood analyses obtained during clinic visits (Pirart 1995 [4642]).

Since that time, other cohort studies have confirmed Pirart's observations and several large, randomized clinical trials have demonstrated that intensive glycemic control prevents the development and progression of long-term diabetic microvascular complications. In these studies, glycemic goals were assessed using glycated hemoglobin as the measure of long-term control.

Long-term hyperglycemia, as measured by glycated hemoglobin, is clearly related to the development of diabetic microvascular complications; however, its relation to the development of macrovascular complications is less clear. A meta regression analysis performed by Coutinho et al. demonstrated a significant association between fasting, 1-hour, and 2-hour glucose and cardiovascular events and mortality in individuals without diabetes (Coutinho et al. 1999 [4645]). The relation of glycemic control and cardiovascular disease in individuals with diabetes remains controversial, with some studies demonstrating a positive association and others showing no association. Impaired glucose homeostasis may be causal in its relationship to cardiovascular disease or alternatively, both diabetes and cardiovascular disease may arise from a “common soil” of insulin resistance, resulting in the observed association (Donahue, et al. 1992 [4649]). Pooled analyses of glucose intervention trials aimed at improving glycemic control have shown insignificant reductions in cardiovascular mortality (Lawson, et al. 1999 [4646]; Huang, et al. 2001 [4647]).

Another important issue that is still an area of active investigation in the management of diabetes relates to whether there is a threshold effect of glycated hemoglobin for microvascular and/or macrovascular complications—that is, is there a glycated hemoglobin level above which the risk of complications rises exponentially. While the majority of studies have not found a threshold effect, a few studies suggest a threshold level between 8 percent and 9 percent for retinopathy (Klein, et al. 1988 [92172]; Janka, et al. 1989 [92173]; Danne, et al. 1994 [92174]) and nephropathy (Krolewski, et al. 1995 [92175]). The issue of a threshold effect of glycated hemoglobin has important implications for where the HbA1c treatment targets are set to prevent diabetic complications. At present, the ADA recommends an HbA1c target of ≤7 percent for the prevention of complications; however, the American College of Endocrinology (ACE) recently altered its recommendations such that a HbA1c target of ≤6.5 percent is recommended for prevention of diabetic complications (ACE Consensus Development Conference on Guidelines for Glycemic Control ACE, 2001 [92180]) and this new target has been adopted by the American Association of Clinical Endocrinologists (American Association of Clinical Endocrinologists Medical Guidelines for Management of Diabetes Mellitus (ACCE), 2002 [92181]). Also, if there is a threshold effect of HbA1c for complications, it is important to determine whether it is the same for both microvascular and macrovascular complications.

### Urine Albumin

#### Screening for microalbuminuria

Great interest in screening and monitoring urinary albumin excretion in patients with diabetes lies not only in the fact that diabetes mellitus is the most common cause of incident ESRD (resulting in annual costs to Medicare of over $15 billion) but also in the fact that microalbuminuria is associated with increased cardiovascular morbidity, cardiovascular mortality, and total mortality in patients with diabetes mellitus in select studies. (Dinneen, et al. 1997 [6]; Borch-Johnsen, et al. 1987 [5]; U.S. Renal Data System 2002 [20]; Donahue, et al. 1992 [4])

Screening tests for microalbuminuria are recommended annually for patients with type 1 diabetes of greater than 5 years duration and for all patients with type 2 diabetes from the time of diagnosis. (American Diabetes Association 2002 [2]) Twenty-four hour collection of urine for quantitative assessment of urinary albumin excretion rate is currently considered the gold standard measurement of microalbuminuria. However, this method is frequently considered to be cumbersome and difficult to carry out in the outpatient clinical setting, and it is subject to timing and collection inaccuracies. (American Diabetes Association 2002 [2]; Remuzzi, et al. 2002 [7]; Bakker 1999 [8]) Several other methods of testing, which are considered less difficult to perform in outpatient settings, have been studied and have been demonstrated to have varying degrees of correlation with 24-hour urine collection for the detection of urinary albumin. These include random or ‘spot’ testing of a morning urine specimen for urine albumin concentration or albumin to creatinine ratio, overnight or ‘timed’ urine collections for estimation of albumin excretion rates, and dipstick testing. (American Diabetes Association 2002 [2]; Leong, et al. 1998 [16]; Mogensen, et al. 1997 [15]; Piehlmeier, et al. 1998 [14]; Tiu, et al. 1993 [13]; Eshoj, et al. 1987 [12]; Nathan, et al. 1987 [11]; Schwab, et al. 1992 [10]; Assadi 2002 [9]) While many experts now support the use of random or first morning tests for urinary albumin to creatinine ratio as a convenient and accurate approach to screening patients, there is currently no clear consensus on standardized testing methods. (American Diabetes Association 2002 [2]; Nathan, et al. 1987 [11])

#### Prognostic significance of microalbuminuria in persons with diabetes

In a variety of prospective studies, elevated urinary albumin excretion has been shown to be associated with increased risk of progression of kidney disease toward ESRD as well as increased cardiovascular morbidity, cardiovascular mortality, and total mortality. Results of a recent systematic review of the association of microalbuminuria with subsequent cardiovascular morbidity and mortality among persons with non-insulin dependent diabetes mellitus demonstrate a 2–3 fold increase in risk of these outcomes associated with the presence of microalbuminuria at baseline. (Dinneen, et al. 1997 [6]) However, few studies have systematically ascertained the magnitude of increase in both renal and cardiovascular risk associated with microalbuminuria among both persons with both type 1 and type 2 diabetes.

Moreover, although observations of renal and cardiovascular outcomes among persons classified as having microalbuminuria by currently accepted standards have been reported, it remains unclear whether current definitions of microalbuminuria are optimal in terms of predicting renal and cardiovascular outcomes and if there is a dose-relationship or threshold effect in prediction of outcomes associated with urinary albumin excretion. Knowledge of the pooled magnitude of risk associated with current definitions of microalbuminuria in addition to an improved understanding of the risk relationship of varying levels of baseline microalbuminuria with cardiovascular and renal outcomes could have important implications in screening and treatment recommendations for persons with diabetes.

## Key Questions

With these issues taken into account, we asked the following key questions concerning both testing for glycemic control and urine albumin for persons with both type 1 and type 2 diabetes mellitus:

### Glycemic Control

1. What is the risk relationship between glycated hemoglobin and the subsequent risk of microvascular diabetic complications (retinopathy, nephropathy, neuropathy) in individuals with type 1 and type 2 diabetes?
2. What is the risk relationship between glycated hemoglobin and the subsequent risk of macrovascular diabetic complications (coronary heart disease, cerebrovascular disease, peripheral vascular disease) in individuals with type 1 and type 2 diabetes?

### Urine Albumin

1. What is the risk relationship between microalbuminuria and renal function?
2. What is the risk relationship between microalbuminuria, cardiovascular disease, and death?