# Appendix I. Research Team

The team was lead by endocrinologist/epidemiologist Sherita Golden and internist/epidemiologist Ebony Boulware.Further information about the Johns Hopkins Evidence-Based Practice Center can be found at:

http://www.hopkinsmedicine.org/epc/default.htm

Gail Berkenblit, MD, PhD (Research Associate)

L. Ebony Boulware, MD, MPH (Project Co-Director)

Frederick L. Brancati, MD, MHS (Co-Investigator)

Geetanjali Chander, MD, MPH (Research Associate)

Sherita Hill Golden, MD, MHS (Project Co-Director)

Spyridon S. Marinopoulos, MD, MBA (Research Associate)

Michael Paasche-Orlow, MD, MPH (Research Associate)

Neil Powe, MD, MPH, MBA (Task Leader/Co-Investigator)

Tejal Rami, MPH (Project Coordinator/Search Director)