# Appendix D. EDTRS Criteria

For each eye, the maximum grade in any of the seven standard photographic fields was determined for each of the lesions and used in defining the “retinopathy levels” as follows:

(From: Klein et al, Ophthalmology, 1998 [2108])

Level 10: | No retinopathy
Level 21: | Microaneurysms (MAs) only or retinal hemorrhages (H) or soft exudates in the absence of MAs.
Level 31: | Microaneurysms and one or more of the following: venous loops 31 μm or greater; questionable soft exudate, intraretinal microvascular abnormalities (IRMA), or venous beading; and retinal H.
Level 37: | Microaneurysms and one or more of the following: hard exudate and soft exudate.
Level 43: | Microaneurysms and one or more of the following: H/MAs equaling or exceeding those in Standard Photo (SP) I in four or five fields; H/MAs equaling or exceeding those in SP 2A in one field; and IRMA in one to three fields.
Level 47: | Microaneurysms and one or more of the following: both IRMA and H/MA characteristics from level 43; IRMA in four or five fields; H/MAs equaling or exceeding those in SP 2A in two or three fields; and venous beading in one field.
Level 53: | Microaneurysms and one or more of the following: any two or three characteristics from level 47; H/Mas equaling or exceeding those in SP 2A in four or five fields; IRMA equaling or exceeding those in SP 8A; venous beading in two or more fields.
Level 60: | Fibrous proliferations only.
Level 61: | No evidence of level 60 or 65 but scars of photocoagulation either in “scatter” or confluent patches, presumably directed at new vessels.
Level 65: | Proliferative diabetic retinopathy (PDR) less than Diabetic Retinopathy Study high-risk characteristics (DRS-HRC). Lesions as follows: new vessels elsewhere (NVE): new vessels on or within 1 disc diameter (NVD) of the disc graded less than SP 10A: or preretinal (PRH) or vitreous hemorrhage (VH) less than 1 disc area (DA).
Level 71: | Diabetic Retinopathy Study high-risk characteristics (DRS-HRC). Lesions as follows: VH and/or PRH equaling or exceeding 1 DA: NVE equaling or exceeding half DA with VH and/or PRH: NVD less than SP 10A with VH or PRH or both: and NVD equaling or exceeding SP 10A.
Level 75: | Advanced PDR, lesions as follows: NVD equaling or exceeding SP 10A with VH or PRH or both.
Level 85: | End-stage PDR, lesions as follows: macula obscured by VH or PRH or both; retinal detachment at center of macula: phthisis bulbi; and enucleation secondary to complications of diabetic retinopathy.