# Appendix C. Glycohemoglobin (GHb) Testing

GHb (glycated hemoglobin, HbA1c, HbA1) describes a series of stable minor hemoglobin components formed slowly and nonenzymatically from hemoglobin and glucose. This alteration in HbA is a post-translational modification [4644].

Rahbar et al. demonstrated elevation in the minor HbA fractions in patients with diabetes using gel electrophoresis (Rahbar, et al. 1969; [92177]; Rahbar, et al. 1986 [92178]).

[underlined: Historical perspective:]

HbA1 can be separated into three minor components that have a more negative charge:

1. HbA1a
2. HbA1b
3. HbA1c

HbA1c was the component resulting from post-translational modification of HbA by glucose at the N-terminus of the β chain. HbA1c has been correlated with:

1. fasting plasma glucose
2. glucose peak during glucose tolerance test
3. area under the curve of glucose tolerance test
4. mean glucose levels over preceding few weeks

[4644].

[underlined: Glycohemoglobin nomenclature:]

Terminology
HbA | The major form of hemoglobin; a native, unmodified tetramer consisting of two α- and β-chains
GHb | General term for glucose bound nonenzymatically to hemoglobin with a ketoamine structure
HbA1 | GHb species that are more negatively charged forms of HbA detected by cation-exchange chromatographic and electrophoretic methods, which include HbA1a, HbA1b, and HbA1c, “fast” hemoglobins
HbA1c | Specific GHb that is an adduct of glucose attached to the β-chain terminal valine residue
Total GHb | Term used to describe all GHb species as measured by affinity chromatographic methods

From Goldstein D et al. Tests of glycemia in diabetes. Diabetes Care 1995;18(6):896–909.

[underlined: Glycated hemoglobin measurement methods available in US as of 2002]

| | | Common interferences
| Glycated Hb Measured | NGSP Certified | HbS | HbC | Elevated HbF | HbE
Ion Exchange Chromatography
Bio-Rad DiaStat | HbA1c
Bio-Rad Variant | HbA1c | Yes | Yes | No | - | No
| Total GHb | | No | No | - | -
Bio-Rad Variant II | HbA1c | Yes | No | No | No (HbF≤24%) | Yes
Tosoh A1c 2.2 Plus | HbA1c | Yes | No | No | - | Yes
Tosoh G7 Auto | HbA1c | Yes
Other: Minicolumns | | No
Boronate Affinity
Abbott IMx | HbA1c | | No | Yes | - | -
| Total GHb
Abbott Vision | Total GHb
Primus HPLC | HbA1c | Yes | No | No | - | No
Axis Shield | | Yes | No | No | - | -
NycoCard (Primus)
Provalis Glycosal | | Yes
Bio-Rad MicroMat II | | | No | Yes | - | -
Cholestech
Other: Minicolumns
Electrophoresis
Beckman Diatrac | HbA1c
Immunoassay
Bayer DCA 2000 | HbA1c | Yes | No | No | - | No
Beckman Synchron | HbA1c | Yes | No | No | - | -
Dade Behring Dimension | HbA1c | Yes
Roche Cobas Integra | HbA1c | Yes | Yes | Yes | - | -
Roche Unimate | | Yes | Yes | Yes | - | -
Roche Tina-quant II | | Yes | No | No | No (HbF≤30%) | No
Metrika A1c Now | | Yes

Adapted from National Glycohemoglobin Standardization Program Website(www.ngsp.org) (http://www.ngsp.org).

[underlined: College of American Pathologists (CAP) Survey Data (updated 5/02)]

The American Diabetes Association (ADA) recommends that laboratories use only GHB assay methods that have been NGSP certified and report results as “%HbA1c” or “%HbA1c equivalents”. The ADA also recommends that all laboratories performing GHB testing participate in the College of American Pathologists (CAP) fresh sample proficiency testing survey (see ADA Recommendations section on this website for more details). The following methods were included in the recent 2002 CAP GH2 survey:

[underlined: Methods reporting HbA1c or equivalent:]

Bayer DCA 2000

Beckman Synchron Syst

Bio-Rad Diastat

Bio-Rad Variant A1c

Bio-Rad Variant II A1c

Dade Behring Dimension

Primus (affinity)

Roche Cobas Integra

Roche/Hitachi (Tina Quant II)

Tosoh A1c 2.2 Plus

Tosoh G7 Auto HPLC

Abbott IMX

Beckman Diatrac

[underlined: Methods reporting total GHb:]

Abbott IMX

Bio-Rad Variant

Helena Glyco-Tek

Primus

Adapted from NGSP Website (www.ngsp.org) (http://www.ngsp.org).