# Appendix A. Acknowledgments

## Peer Reviewers

At-large reviewers with content expertise

Thomas Kickler, MD*

Professor of Oncology, Pathology, and Medicine

Director, Hematology Lab, Pathology

Randie R. Little, Ph.D., Network Coordinator

National Glycohemoglobin Standardization Program (NGSP)

Katherine R. Tuttle, MD

Clinical Associate Professor of Medicine

University of Washington School of Medicine

The Heart Institute of Spokane

## Nominated Reviewers

[underlined: NIDDK Organizations]

NIDDK—National Kidney Disease Education Program

Thomas H. Hostetter, MD

Director, National Kidney Disease Education Program

Senior Scientific Advisor

National Institutes of Health

NIDDK—National Diabetes Education Program

Saul N. Malozowski

Senior Advisor for Clinical Trials and Diabetes Translation

Division of Diabetes, Endocrinology, and Metabolic Diseases

[underlined: Diabetes Organizations]

American Association of Diabetes Educators

Gary Arsham, MD, PhD

Arsham Consultants, Inc.

[underlined: Pathology/Laboratory Organizations]

American Association of Clinical Chemistry

William E. Winter, MD

Professor of Pathology and Pediatrics

University of Florida

[underlined: Organizations representing minority interests]

Indian Health Service

Charlton Wilson, MD

IHS National Diabetes Program

[underlined: Private third-party payer or public payer representative]

Blue Cross Blue Shield (BC/BS) Association

Timothy Ranney, MD

Blue Cross & Blue Shield of Nebraska

Veterans Administration Health Care System

Leonard M. Pogach, MD

National Diabetes Director

New Jersey Veterans Administration Health Care System

## Data Abstractors

[underlined: Glycohemoglobin]

Sherita Hill Golden, MD, MHS

Spyridon S. Marinopoulos, MD, MBA

Gail Berkenblit, MD, PhD

[underlined: Microalbuminuria]

Ebony Boulware, MD, MPH

Geetangali Chander, MD, MPH

Michael Paasche-Orlow, MD