# Appendixes

Appendix A. Acknowledgments

Appendix B. Study Questions: Refinement by Experts

Appendix C. Glycohemoglobin (GHb) Testing

Appendix D. EDTRS Criteria

Appendix E. Glycohemoglobin Abstract Review Form

Appendix F. Glycohemoglobin and Diabetic Complications: Data Abstraction Tool

Appendix G. Microalbuminuria Abstract Review Form

Appendix H. Microalbuminuria and Diabetic Complications: Data Abstraction Tool

Appendix I. Research Team