# Evidence Tables

Evidence Table. Antioxidants for Cardiovascular Prevention and Treatment

| Trial name
| Study Design and Quality
1^st^ Author | Population | | | Interventions
Year | Type of Disease | | Arm | Dose Data | Sample Size | | Summary of Results
Anderson | Named trial: | Other | 1 | Placebo | N entered: | 24 | Excluded from statistical analysis because no outcomes of interest were reported. No significant effect of vitamin E on angina symptoms.
1974a | | | | Placebo for 9 Weeks | N analyzed: | 18
Study 1 | Design: | RCT | 2 | Vitamin E | N entered: | 24
| | | | 3200 IU orally for 9 Weeks | N analyzed: | 15
| Jadad: | 5
| Population: | Unspecified
| Condition: | Angina
Anderson | Named trial: | Other | 1 | Placebo | N entered: | 10 | Excluded from statistical analysis because no outcomes of interest were reported. No significant effect of vitamin E on angina symptoms.
1974a | | | | Placebo for 9 Weeks | N analyzed: | 4
Study 2 | Design: | RCT | 2 | Vitamin E | N entered: | 10
| Jadad: | 5 | | Dose N/A orally for 9 weeks | N analyzed: | 6
| Population: | Unspecified
| Condition: | Angina
Anderson | Named trial: | Other | 1 | Placebo | N entered: | 18 | Excluded from statistical analysis because no outcomes of interest were reported. No significant effect of vitamin E on angina symptoms.
1974b | | | | Placebo for 9 Weeks | N analyzed: | N/A
| Design: | RCT | 2 | Vitamin E | N entered: | 18
| | | | 3200 IU orally for 9 Weeks | N analyzed: | N/A
| Jadad: | 5
| Population: | Unspecified
| Condition: | CAD, angina
Anderson 1999 | Named trial: | Other | 1 | Placebo | N entered: | 20 | Excluded from meta-analysis of lipids due to study design. Antioxidant combination group showed significant reduction in LDL oxidation as compared to placebo.
| | | | Placebo for 8 Weeks | N analyzed: | 16
| Design: | CCT | 2 | Vitamin C | N entered: | 20
| | | | 1000 mg orally for 12 Weeks | N analyzed: | 18
| Jadad: | 0 | | Vitamin E
| | | | 800 IU orally for 12 Weeks
| Population: | Unspecified | | Beta-carotene
| Condition: | CAD | | 24 mg orally for 12 Weeks
Boaz | Named trial: | SPACE | 1 | Placebo | N entered: | 99 | Included in meta-analysis of death and MI.
2000 | | | | Placebo for 26 Months | N analyzed: | 99
| Design: | RCT
| | | 2 | Vitamin E | N entered: | 97
| Jadad: | 4 | | 800 IU orally for 26 Months | N analyzed: | 97
| Population: | Unspecified
| Condition: | CAD,CVA/TIA,PVD, angina
Brown | Named trial: | Other | 1 | Placebo | N entered: | N/A | Included in meta-analysis of lipids.
1994 | | | | Placebo for 10 Weeks | N analyzed: | N/A
| Design: | CCT | 2 | Vitamin E | N entered: | N/A
| | | | 280 mg orally for 10 Weeks | N analyzed: | N/A
| Jadad: | 2
| Population: | Unspecified
| Condition: | CAD, LDL oxidation
Brown | Named trial: | HATS | 1 | Placebo | N entered: | N/A | Included in meta-analysis of death and MI.
2001 | | | | Placebo for 3 Years | N analyzed: | 34 | Excluded from meta-analysis of lipids due to insufficient followup time.
| Design: | RCT | 2 | Niacin | N entered: | N/A
| | | | Dose N/A orally for 3 years | N analyzed: | 33
| Jadad: | 4 | | Statin drug
| | | | Dose N/A orally for 3 years
| Population: | Unspecified | 3 | Vitamin E | N entered: | N/A
| | | | 800 IU orally for 3 Years | N analyzed: | 39
| Condition: | CAD, CVA/TIA, angina | | Vitamin C
| | | | 1000 mg orally for 3 Years
| | | | Beta-carotene
| | | | 25 mg orally for 3 Years
| | | | Selenium
| | | | 100 μg orally for 3 Years
| | | 4 | Selenium | N entered: | N/A
| | | | 100 μg orally for 3 Years | N analyzed: | 40
| | | | Beta-carotene
| | | | 25 mg orally for 3 Years
| | | | Vitamin E
| | | | 800 IU orally for 3 Years
| | | | Vitamin C
| | | | 1000 mg orally for 3 Years
| | | | Niacin
| | | | Dose N/A orally for 3 years
| | | | Statin drug
| | | | Dose N/A orally for 3 years
Chamiec 1996 | Named trial: | Other | 1 | Control or Usual care | N entered: | N/A | Excluded from statistical analysis because no outcomes of interest were reported. Significant decrease in measures of myocardial free radical injury among group treated with vitamins E and C.
| | | | No dosage data reported | N analyzed: | 28
| Design: | RCT | 2 | Vitamin C | N entered: | N/A
| | | | 600 mg orally for 14 Days | N analyzed: | 33
| Jadad: | 2 | | Vitamin E
| | | | 600 mg orally for 14 Days
| Population: | Unspecified
| Condition: | CAD
Chello | Named trial: | Other | 1 | Control or Usual care | N entered: | 20 | Excluded from statistical analysis because no outcomes of interest were reported. Significant decrease in rate of arrhythmias and improvement in some measures of hemodynamics in Co-Q10 group following bypass surgery.
1994 | | | | No dosage data reported | N analyzed: | 20
| Design: | RCT | 2 | Co-Q10 | N entered: | 20
| | | | 150 mg orally for 7 Days | N analyzed: | 20
| Jadad: | 2
| Population: | Unspecified
| Condition: | CAD
Chello | Named trial: | Other | 1 | Placebo | N entered: | 15 | Excluded from statistical analysis because no outcomes of interest were reported. Statistically significant decrease in muscle reperfusion injury measures after cross-clamping of abdominal aortae intraoperatively in subjects pre-treated with Co-Q10.
1996 | | | | Placebo for 7 Days | N analyzed: | 15
| Design: | RCT | 2 | Co-Q10 | N entered: | 15
| | | | 150 mg orally for 7 Days | N analyzed: | 15
| Jadad: | 3
| Population: | Unspecified
| Condition: | Reperfusion injury
Chen | Named trial: | Other | 1 | Placebo | N entered: | 11 | Excluded from statistical analysis because no outcomes of interest were reported. Significant improvement in some, but not all, measures of hemodynamics in Co-Q10 group following cardiovascular surgery.
1994 | | | | Placebo for 6 Days | N analyzed: | 11
| Design: | RCT | 2 | Co-Q10 | N entered: | 11
| | | | 150–200 mg orally for 6 Days | N analyzed: | 11
| Jadad: | 2
| Population: | Unspecified
| Condition: | CAD
de Lorgeril | Named trial: | Other | 1 | Control or Usual care | N entered: | 10 | Included in meta-analysis of lipids.
1994 | | | | Control or Usual care for 2 Months | N analyzed: | 10
| Design: | RCT
| | | 2 | Vitamin E | N entered: | 10
| Jadad: | 1 | | 500 IU orally for 2 Months | N analyzed: | 10
| Population: | Unspecified
| Condition: | CAD
De Waart 1997 | Named trial: | Other | 1 | Placebo | N entered: | 41 | Included in meta-analysis of lipids.
| | | | Placebo for 3 Months | N analyzed: | 41
| Design: | RCT | 2 | Vitamin E | N entered: | 42
| | | | 100 IU orally for 3 Months | N analyzed: | 41
| Jadad: | 3
| Population: | Elderly (over 65)
| Condition: | CAD
DeMaio 1992 | Named trial: | Other | 1 | Placebo | N entered: | N/A | Included in meta-analysis of lipids.
| | | | Placebo for 4 Months | N analyzed: | 48
| Design: | RCT | 2 | Vitamin E | N entered: | N/A
| | | | 1200 IU orally for 4 Months | N analyzed: | 52
| Jadad: | 2
| Population: | Unspecified
| Condition: | CAD, reperfusion injury
Di Somma | Named trial: | Other | 1 | Control or Usual care | N entered: | 318 | Excluded from meta-analysis of death due to insufficient statistics. Excluded from meta-analysis of lipids as not relevant intervention.
1991 | | | | No dosage data reported | N analyzed: | 306
| Design: | RCT | 2 | Co-Q10 | N entered: | 488
| | | | 100 mg orally for 24 Weeks | N analyzed: | 466 | Significant improvement in heart failure and angina was found from Co-Q10.
| Jadad: | 2
| Population: | Unspecified
| Condition: | CAD, CHF
Dieber- | Named trial: | Other | 1 | Placebo | N entered: | 4 | Excluded from meta-analysis of lipids due to insufficient statistics. Vitamin E group showed significant reduction in LDL oxidation as compared to placebo.
Rotheneder | | | | Placebo for 21 Days | N analyzed: | 4
1991 | Design: | CCT | 2 | Vitamin E | N entered: | 2
| | | | 150 IU orally for 21 Days | N analyzed: | 2
| Jadad: | 0 | 3 | Vitamin E | N entered: | 2
| | | | 225 IU orally for 21 Days | N analyzed: | 2
| Population: | Unspecified | 4 | Vitamin E | N entered: | 2
| | | | 800 IU orally for 21 Days | N analyzed: | 2
| Condition: | CAD, LDL oxidation | 5 | Vitamin E | N entered: | 2
| | | | 1200 IU orally for 21 Days | N analyzed: | 2
Digiesi 1990 | Named trial: | Other | 1 | Placebo | N entered: | 18 | Excluded from statistical analysis because no outcomes of interest were reported. Statistically significant decrease in blood pressure in Co-Q10 group.
| | | | Placebo for 10 Weeks | N analyzed: | 18
| Design: | RCT | 2 | Co-Q10 | N entered: | 18
| | | | 100 mg orally for 10 Weeks | N analyzed: | 18
| Jadad: | 1
| Population: | Unspecified
| Condition: | HTN
Duffy | Named trial: | Other | 1 | Placebo | N entered: | 23 | Excluded from statistical analysis because no outcomes of interest were reported. Significant decrease in systolic blood pressure in vitamin C group.
1999 | | | | Placebo for 1 Day | N analyzed: | 20
| Design: | RCT | | Placebo
| | | | Placebo for 30 Days
| Jadad: | 3 | 2 | Vitamin C | N entered: | 22
| | | | 2 gm orally for 1 Day | N analyzed: | 19
| Population: | Unspecified | | Vitamin C
| | | | 500 mg orally for 30 Days
| Condition: | CAD, HTN
Duffy | Named trial: | Other | 1 | Placebo | N entered: | 20 | Excluded from statistical analysis because no outcomes of interest were reported. Chronic vitamin C therapy group exhibited significantly lowered systolic and mean blood pressure.
2001 | | | | Placebo for 1 Day | N analyzed: | 20
| Design: | RCT | | Placebo
| | | | Placebo for 1 Month
| Jadad: | 2 | 2 | Vitamin C | N entered: | 19
| | | | 2 gm orally for 1 Day | N analyzed: | 19
| Population: | Unspecified | | Vitamin C
| | | | 500 mg orally for 1 Month
| Condition: | HTN
Duthie 1991 | Named trial: | Other | 1 | Placebo | N entered: | 10 | Excluded from meta-analysis of lipids due to insufficient statistics. Vitamin E group showed no significant difference in total cholesterol among male smokers.
| | | | Placebo for 14 Days | N analyzed: | 10
| Design: | CCT | 2 | Vitamin E | N entered: | 10
| | | | 1000 mg orally for 14 Days | N analyzed: | 10
| Jadad:0 | 0
| Population: | Unspecified
| Condition: | N/A
Fuller | Named trial: | Other | 1 | Placebo | N entered: | 9 | Excluded from statistical analysis because no outcomes of interest were reported. Significant reduction in LDL oxidation among vitamin C group.
1996a | | | | Placebo for 4 Weeks | N analyzed: | 9
| Design: | RCT | 2 | Vitamin C | N entered: | 10
| | | | 1000 mg orally for 4 Weeks | N analyzed: | 10
| Jadad: | 1
| Population: | Smokers
| Condition: | CAD
Fuller | Named trial: | Other | 1 | Placebo | N entered: | 13 | Included in meta-analysis of lipids.
1996b | | | | Placebo for 8 Weeks | N analyzed: | 13
| Design: | RCT | 2 | Vitamin E | N entered: | 15
| | | | 1200 IU orally for 8 Weeks | N analyzed: | 15
| Jadad: | 1
| Population: | Unspecified
| Condition: | CAD, LDL oxidation
Galley | Named trial: | Other | 1 | Placebo | N entered: | 40 | Excluded from statistical analysis because no outcomes of interest were reported. Significantly reduced blood pressure levels among those in group receiving high-dose combinations of antioxidants including vitamins C and E.
1997 | | | | Placebo for 8 Weeks | N analyzed: | 38
| Design: | RCT | 2 | Vitamin C | N entered: | 40
| | | | 500 mg orally for 8 Weeks | N analyzed: | 38
| Jadad: | 5 | | Vitamin E
| | | | 600 mg orally for 8 Weeks
| Population: | Unspecified | | Beta-carotene
| | | | 30 mg orally for 8 Weeks
| Condition: | HTN | | Multi-vitamin
| | | | Multi-vitamin orally for 8 Weeks
Gatto | Named trial: | Other | 1 | Placebo | N entered: | 10 | Excluded from meta-analysis of lipids as not relevant intervention. Vitamin C group showed significant improvements in lipid profiles after 4 weeks of therapy.
1996 | | | | Placebo for 4 Weeks | N analyzed: | 10
| Design: | RCT | 2 | Vitamin C | N entered: | 10
| | | | 1000 mg orally for 4 Weeks | N analyzed: | 10
| Jadad: | 2
| Population: | Female
| Condition: | CAD
Ghatak 1996 | Named trial: | Other | 1 | Placebo | N entered: | 7 | Excluded from statistical analysis because no outcomes of interest were reported. Significant reduction in measures of antioxidant stress among vitamin E group.
| | | | Placebo for 4 Weeks | N analyzed: | 7
| Design: | RCT | 2 | Vitamin E | N entered: | 5
| | | | 400 mg orally for 4 Weeks | N analyzed: | 5
| Jadad: | 1
| Population: | Unspecified
| Condition: | CHF
Gillilan 1977 | Named trial: | Other | 1 | Placebo | N entered: | 52 | Excluded from meta-analysis of death due to insufficient followup time. No change in exercise capacity, angina or cardiac function were found with the use of vitamin E.
| | | | Placebo for 6 Months | N analyzed: | 48
| Design: | RCT | 2 | Vitamin E | N entered: | 52
| | | | 1600 IU orally for 6 Months | N analyzed: | 48
| Jadad: | 3
| Population: | Unspecified
| Condition: | CAD
GISSI | Named trial: | GISSI/GIZZI | 1 | Placebo | N entered: | 2828 | Included in meta-analysis of death and MI. Excluded from meta-analysis of lipids due to heterogeneous sample-size.
1999 | | | | Placebo for 3.5 Years | N analyzed: | 2809
| Design: | RCT | 2 | n3 PUFA | N entered: | 2836
| | | | 1 gm orally for 3.5 Years | N analyzed: | 2065
| Jadad: | 3 | 3 | Vitamin E | N entered: | 2830
| | | | 300 mg orally for 3.5 Years | N analyzed: | 2128
| Population: | Unspecified | 4 | Vitamin E | N entered: | 2830
| | | | 300 mg orally for 3.5 Years | N analyzed: | 1170
| Condition: | CAD, CVA/TIA | | n3 PUFA
| | | | 1 gm orally for 3.5 Years
Guetta 1995 | Named trial: | Other | 1 | 17 beta estradiol | N entered: | 9 | Excluded from meta-analysis of lipids due to no placebo arm. Both vitamin E and hormonal therapy groups showed significant reductions in LDL oxidation.
| | | | 0.1 mg 3 for 3 Weeks | N analyzed: | 9
| Design: | RCT | 2 | Vitamin E | N entered: | 10
| | | | 800 IU orally for 6 Weeks | N analyzed: | 10
| Jadad: | 1 | 3 | Vitamin E | N entered: | 19
| | | | 800 IU orally for 6 Weeks | N analyzed: | 19
| Population: | Female | | 17 beta estradiol
| | | | 0.1 mg 3 for 3 Weeks
| Condition: | CAD
Haeger 1968 | Named trial: | Other | 1 | Vasodilators | N entered: | 37 | Included in meta-analysis of death.
| | | | Dose N/A orally for 7 years | N analyzed: | N/A
| Design: | CCT | 2 | Coumadin | N entered: | 44
| | | | Dose N/A orally for 7 years | N analyzed: | N/A
| Jadad: | 0 | 3 | Multi-vitamin | N entered: | 42
| | | | Multi-vitamin orally for 7 Years | N analyzed: | N/A
| Population: | Unspecified | 4 | Vitamin E | N entered: | 104
| | | | 300 mg orally for 7 Years | N analyzed: | N/A
| Condition: | PVD
Haeger 1973 | Named trial: | Other | 1 | Control or Usual care | N entered: | N/A | Excluded from statistical analysis because no outcomes of interest were reported. Significant improvement in walking distance with vitamin E among subjects with intermittent claudication.
| | | | No dosage data reported | N analyzed: | 14
| Design: | CCT | 2 | Vitamin E | N entered: | N/A
| | | | 300 mg orally for 5 Years | N analyzed: | 33
| Jadad: | 0
| Population: | Unspecified
| Condition: | PVD
Haeger 1974 | Named trial: | Other | 1 | Control or Usual care | N entered: | N/A | Excluded from statistical analysis because no outcomes of interest were reported. Significant improvement in claudication symptoms among vitamin E group.
| | | | No dosage data reported | N analyzed: | N/A
| Design: | CCT | 2 | Vitamin E | N entered: | N/A
| | | | 300 mg orally for 3.5 Years | N analyzed: | N/A
| Jadad: | 0
| Population: | Unspecified
| Condition: | CAD, PVD
Hamabe 2001 | Named trial: | Other | 1 | Placebo | N entered: | 17 | Excluded from statistical analysis because no outcomes of interest were reported. No effect of vitamin C on blood pressure.
| | | | Placebo for 0.33 Hours | N analyzed: | 17
| Design: | RCT | 2 | Vitamin C | N entered: | 17
| | | | 1000 mg intravenously for 0.33 Hours | N analyzed: | 17
| Jadad: | 1
| Population: | Unspecified
| Condition: | CAD, angina
Harats 1990 | Named trial: | Other | 1 | Control or Usual care | N entered: | 3 | Excluded from meta-analysis of lipids due to insufficient statistics. Both vitamin E and hormonal therapy groups showed significant reductions in LDL oxidation.
| | | | Control or Usual care for 4 Weeks | N analyzed: | 3
| Design: | CCT
| | | 2 | Vitamin C | N entered: | 3
| Jadad: | 0 | | 1.5 gm orally for 4 Weeks | N analyzed: | 3
| | | 3 | Vitamin E | N entered: | 4
| Population: | Smokers | | 600 mg orally for 4 Weeks | N analyzed: | 4
| Condition: | CAD
Herbaczynska-Cedro 1995 | Named trial: | Other | 1 | Control or Usual care | N entered: | 22 | Excluded from statistical analysis because no outcomes of interest were reported. Vitamin C and E group showed significantly lower measures of lipid oxidation and free radical production.
| | | | Control or Usual care for 14 Days | N analyzed: | 22
| Design: | RCT
| | | 2 | Vitamin C | N entered: | 23
| Jadad: | 1 | | 600 mg orally for 14 Days | N analyzed: | 23
| | | | Vitamin E
| Population: | Unspecified | | 600 mg orally for 14 Days
| Condition: | CAD
Hiasa | Named trial: | Other | 1 | Placebo | N entered: | 6 | Excluded from statistical analysis because no outcomes of interest were reported. Improvement in exercise tolerance with Co-Q10 among subjects with stable angina.
1984 | | | | Placebo for 7 Days | N analyzed: | 6
| Design: | CCT | 2 | Co-Q10 | N entered: | 12
| | | | 1.5 mg/kg intravenously for 7 Days | N analyzed: | 12
| Jadad: | 2
| Population: | Unspecified
| Condition: | CAD, angina
Hoffman 1999 | Named trial: | Other | 1 | Placebo | N entered: | 12 | Included in meta-analysis of lipids.
| | | | Placebo for 6 Months | N analyzed: | 11
| Design: | RCT | 2 | Vitamin E | N entered: | 27
| | | | 400 mg orally for 6 Months | N analyzed: | 22
| Jadad: | 2
| Population: | Unspecified
| Condition: | CAD, LDL oxidation
| Trial name
| Study Design and Quality
1st Author | Population | | | Interventions
Year | Type of Disease | | Arm | Dose Data | Sample Size | | Summary of Results
Hofman-Bang | Named trial: | Other | 1 | Placebo | N entered: | 7 | Excluded from statistical analysis because no outcomes of interest were reported. Co-Q10 group showed significant improvements in some, not all, measures of exercise hemodynamics with no change in hemodynamics at rest among heart failure subjects.
1992 | | | | Placebo for 3 Months | N analyzed: | N/A
| Design: | RCT | 2 | Co-Q10 | N entered: | 11
| | | | 100 mg orally for 3 Months | N analyzed: | N/A
| Jadad: | 2
| Population: | Unspecified
| Condition: | CHF
Hofman-Bang | Named trial: | Other | 1 | Placebo | N entered: | 79 | Excluded from meta-analysis of death due to insufficient statistics. Significant improvements in some, but not all, measures of hemodynamics and significant improvements in quality of life in the Co-Q10 group among subjects with heart failure.
1995 | | | | Placebo for 3 Months | N analyzed: | 69
| Design: | RCT | 2 | Co-Q10 | N entered: | 79
| | | | 100 mg orally for 3 Months | N analyzed: | 69
| Jadad: | 3
| Population: | Unspecified
| Condition: | CHF
(HPSCG, Heart Protection Study Collaborative Group, 2002) | Named trial: | MRC/BHF | 1 | Placebo | N entered: | 10267 | Included in meta-analysis of death and MI. Excluded from meta-analysis of lipids due to heterogeneous sample-size.
| | | | Placebo for 5 Years | N analyzed: | 10228
| Design: | RCT | 2 | Vitamin E | N entered: | 10269
| | | | 600 mg orally for 5 Years | N analyzed: | 10241
| Jadad: | 5 | | Vitamin C
| | | | 250 mg orally for 5 Years
| Population: | Unspecified | | Beta-carotene
| | | | 020 mg orally for 5 Years
| Condition: | CAD
Iarussi 1994 | Named trial: | Other | 1 | Control or Usual care | N entered: | 10 | Excluded from statistical analysis because no outcomes of interest were reported. Statistically significant reduction in cardiotoxicity from anthracycline hemotherapy among Co-Q10 group.
| | | | No dosage data reported | N analyzed: | 10
| Design: | RCT | 2 | Co-Q10 | N entered: | 10
| | | | 200 mg orally duration N/A | N analyzed: | 10
| Jadad: | 2 | | | N entered:
| Population: | Children (under 18)
| Condition: | Cardiotoxicity
Iino | Named trial: | Other | 1 | Placebo | N entered: | 48 | Excluded from meta-analysis of lipids as not relevant outcome. Symptoms of cerebrovascular disease and hypertension were decreased in vitamin E group as compared to placebo.
1977 | | | | Placebo for 4 Weeks | N analyzed: | 45
| Design: | CCT | 2 | Vitamin E | N entered: | 46
| | | | 600 mg orally for 4 Weeks | N analyzed: | 44
| Jadad: | 2
| Population: | Unspecified
| Condition: | CVA/TIA, HTN
Inagaki | Named trial: | Other | 1 | Placebo | | 37 | Excluded from statistical analysis because no outcomes of interest were reported. Significant effect of vitamin E on several measures of cardiac symptoms and function including hypertension.
1978 | | | | Placebo for 5 Weeks | N analyzed: | 37
| Design: | CCT | 2 | Vitamin E | N entered: | 40
| | | | 600 mg orally for 5 Weeks | N analyzed: | 38
| Jadad: | 2
| Population: | Unspecified
| Condition: | CAD, CVA/TIA, PVD, HTN
Inal | Named trial: | Other | 1 | 17 beta estradiol | N entered: | 22 | Excluded from meta-analysis of lipids due to no placebo arm. All groups showed significant reductions in lipid levels.
1997 | | | | 0.05 gm 3 for 6 Months | N analyzed: | 22
| Design: | RCT | 2 | 17 beta estradiol | N entered: | 22
| | | | 0.05 gm 3 for 6 Months | N analyzed: | 22
| Jadad: | 1 | | Progesterone
| | | | 10 mg orally for 10 Days
| Population: | Female | 3 | Vitamin E | N entered: | 22
| | | | 600 mg orally for 6 Months | N analyzed: | 22
| Condition: | CAD | | 17 beta estradiol
| | | | 0.05 gm 3 for 6 Months
| | | | Progesterone
| | | | 10 mg orally for 10 Days
Jain | Named trial: | Other | 1 | Placebo | N entered: | N/A | Included in meta-analysis of lipids.
1996 | | | | Placebo for 3 Months | N analyzed: | 16
| Design: | CCT | 2 | Vitamin E | N entered: | N/A
| | | | 100 IU orally for 3 Months | N analyzed: | 13
| Jadad: | 2
| Population: | Unspecified
| Condition: | CAD
Jialal | Named trial: | Other | 1 | Placebo | N entered: | 12 | Included in meta-analysis of lipids.
1992 | | | | Placebo for 12 Weeks | N analyzed: | 12
| Design: | RCT | 2 | Vitamin E | N entered: | 12
| | | | 800 IU orally for 12 Weeks | N analyzed: | 12
| Jadad: | 1
| Population: | Unspecified
| Condition: | CAD
Jialal | Named trial: | Other | 1 | Placebo | N entered: | 12 | Included in meta-analysis of lipids.
1993 | | | | Placebo for 12 Weeks | N analyzed: | 12
| Design: | RCT | 2 | Vitamin E | N entered: | 12
| | | | 800 IU orally for 12 Weeks | N analyzed: | 12
| Jadad: | 1 | | Vitamin C
| | | | 1 gm orally for 12 Weeks
| Population: | Unspecified | | Beta-carotene
| | | | 30 mg orally for 12 Weeks
| Condition: | CAD
Jialal | Named trial: | Other | 1 | Placebo | N entered: | 8 | Included in meta-analysis of lipids.
1995 | | | | Placebo for 8 Weeks | N analyzed: | 8
| Design: | RCT | 2 | Vitamin E | N entered: | 8
| | | | 60 IU orally for 8 Weeks | N analyzed: | 8
| Jadad: | 1
| | | 3 | Vitamin E | N entered: | 8
| Population: | Unspecified | | 200 IU orally for 8 Weeks | N analyzed: | 8
| | | 4 | Vitamin E | N entered: | 8
| Condition: | CAD, LDL oxidation | | 400 IU orally for 8 Weeks | N analyzed: | 8
| | | 5 | Vitamin E | N entered: | 8
| | | | 800 IU orally for 8 Weeks | N analyzed: | 8
| | | 6 | Vitamin E | N entered: | 8
| | | | 1200 IU orally for 8 Weeks | N analyzed: | 8
Judy | Named trial: | Other | 1 | Control or Usual care | N entered: | 55 | Excluded from meta-analysis of death as not relevant intervention. Co-Q10 significantly improved measures of cardiac function and survival among heart failure subjects.
1986a | | | | Control or Usual care for 3 Years | N analyzed: | N/A
| Design: | CCT
| | | 2 | Co-Q10 | N entered: | 55
| Jadad: | 0 | | 100 mg orally for 3 Years | N analyzed: | N/A
| Population: | Unspecified
| Condition: | CHF
Judy | Named trial: | Other | 1 | Placebo | N entered: | 14 | Excluded from meta-analysis of death as not relevant intervention. Co-Q10 significantly improved measures of cardiac function among heart failure subjects.
1986b | | | | Placebo for 90 Days | N analyzed: | 10
| Design: | RCT | 2 | Co-Q10 | N entered: | 14
| | | | 100 mg orally for 90 Days | N analyzed: | 10
| Jadad: | 4
| Population: | Unspecified
| Condition: | CHF
Judy | Named trial: | Other | 1 | Control or Usual care | N entered: | 90 | Excluded from meta-analysis of death as not relevant intervention. Co-Q10 significantly improved measures of cardiac function and survival among heart failure subjects.
1991 | | | | Control or Usual care for 8 Years | N analyzed: | N/A
| Design: | CCT
| | | 2 | Co-Q10 | N entered: | 90
| Jadad: | 0 | | 100 mg orally for 8 Years | N analyzed: | N/A
| Population: | Unspecified
| Condition: | CHF
Judy | Named trial: | Other | 1 | Placebo | N entered: | 10 | Excluded from statistical analysis because no outcomes of interest were reported. Significant improvement in some, but not all, hemodynamic measures among Co-Q10 group following cardiovascular surgery.
1993 | | | | Placebo for 44 Days | N analyzed: | 10
| Design: | RCT | 2 | Co-Q10 | N entered: | 10
| | | | 100 mg orally for 44 Days | N analyzed: | 10
| Jadad: | 2
| Population: | Unspecified
| Condition: | CAD, reperfusion injury
Kaikkonen | Named trial: | MASIT | 1 | Placebo | N entered: | 20 | Excluded from statistical analysis because no outcomes of interest were reported. No significant impact of Co-Q10 on LDL oxidation.
1997 | | | | Placebo for 2 Months | N analyzed: | N/A
| Design: | RCT | 2 | Co-Q10 | N entered: | 20
| | | | 90 mg orally for 2 Months | N analyzed: | N/A
| Jadad: | 3 | 3 | Co-Q10 | N entered: | 20
| | | | 90 mg orally for 2 Months | N analyzed: | N/A
| Population: | Smokers
| Condition: | CAD
Kaikkonen | Named trial: | Other | 1 | Placebo | N entered: | 19 | Excluded from meta-analysis of lipids as not relevant outcome. The combination of Co-Q10 and vitamin E significantly decreased LDL oxidation at rest, but had no effect on lipid oxidation after vigorous exercise.
1998 | | | | Placebo for 3 Weeks | N analyzed: | 18
| Design: | RCT | 2 | Co-Q10 | N entered: | 18
| | | | 90 mg orally for 3 Weeks | N analyzed: | 18
| Jadad: | 3 | | Vitamin E
| Population: | Unspecified | | 13.5 mg orally for 3 Weeks
| Condition: | CAD, LDL oxidation
Kaikkonen | Named trial: | Other | 1 | Placebo | N entered: | 10 | Included in meta-analysis of lipids.
2000 | | | | Placebo for 3 Months | N analyzed: | 10
Study 1 | Design: | RCT | 2 | Vitamin E | N entered: | 10
| | | | 700 mg orally for 3 Months | N analyzed: | 10
| Jadad: | 2 | | Co-Q10
| | | | 200 mg orally for 3 Months
| Population: | Unspecified | 3 | Co-Q10 | N entered: | 10
| | | | 200 mg orally for 3 Months | N analyzed: | 10
| Condition: | CAD | 4 | Vitamin E | N entered: | 10
| | | | 700 mg orally for 3 Months | N analyzed: | 10
Kaikkonen | Named trial: | Other | 1 | Placebo | N entered: | 10 | Excluded from meta-analysis of lipids as not relevant intervention. There was no significant change in lipid levels among any of the treatment groups.
2000 | | | | Placebo for 7 Days | N analyzed: | 10
Study 2 | Design: | RCT | 2 | Co-Q10 | N entered: | 10
| | | | 90 mg orally for 7 Days | N analyzed: | 10
| Jadad: | 1
| Population: | Unspecified
| Condition: | CAD
Kamikawa | Named trial: | Other | 1 | Placebo | N entered: | 12 | Excluded from statistical analysis because no outcomes of interest were reported. Statistically significant increased exercise tolerance found among subjects in Co-Q10 group.
1985 | | | | Placebo for 4 Weeks | N analyzed: | 12
| Design: | RCT | 2 | Co-Q10 | N entered: | 12
| | | | 150 mg orally for 4 Weeks | N analyzed: | 12
| Jadad: | 2
| Population: | Unspecified
| Condition: | CAD, angina
Keith | Named trial: | Other | 1 | Placebo | N entered: | N/A | Excluded from statistical analysis because no outcomes of interest were reported. No effect of vitamin E on quality of life or measures of oxidative stress among subjects with heart failure.
2000 | | | | Placebo for 12 Weeks | N analyzed: | N/A
| Design: | RCT | 2 | Vitamin E | N entered: | N/A
| | | | 1000 IU orally for 12 Weeks | N analyzed: | N/A
| Jadad: | 1
| Population: | Unspecified
| Condition: | CHF
Keith | Named trial: | Other | 1 | Placebo | N entered: | 30 | Excluded from statistical analysis because no outcomes of interest were reported. No statistically significant effects of vitamin E on cardiac function and quality of life among heart failure subjects.
2001 | | | | Placebo for 12 Weeks | N analyzed: | 30
| Design: | RCT | 2 | Vitamin E | N entered: | 26
| | | | 500 IU orally for 12 Weeks | N analyzed: | 26
| Jadad: | 4
| Population: | Unspecified
| Condition: | CHF
Khatta | Named trial: | Other | 1 | Placebo | N entered: | 27 | Excluded from meta-analysis of death due to insufficient statistics. No improvement with Co-Q10 over standard treatment in subjects with heart failure.
2000 | | | | Placebo for 6 Months | N analyzed: | 23
| Design: | RCT | 2 | Co-Q10 | N entered: | 28
| | | | 200 mg orally for 6 Months | N analyzed: | 23
| Jadad: | 4
| Population: | Unspecified
| Condition: | CHF
Kuklinski 1994 | Named trial: | Other | 1 | Placebo | N entered: | 29 | Excluded from meta-analysis of death as not relevant intervention. Excluded from meta-analysis of MI due to insufficient statistics. Antioxidant group showed no significant difference in post-MI complications, and fewer deaths at long term followup.
| | | | Placebo for 1 Year | N analyzed: | 29
| Design: | RCT | 2 | Co-Q10 | N entered: | 32
| | | | 100 mg orally for 1 Year | N analyzed: | 32
| Jadad: 2 | 2 | | Selenium
| Population: | Unspecified | | 100 μg orally for 1 Year
| Condition: | CAD
Langsjoen | Named trial: | Other | 1 | Placebo | N entered: | N/A | Excluded from statistical analysis because no outcomes of interest were reported. Statistically significant improvement in hemodynamics with Co-Q10 among heart failure subjects.
1985a | | | | Placebo for 12 Weeks | N analyzed: | 19
| Design: | RCT | 2 | Co-Q10 | N entered: | N/A
| | | | 99 mg orally for 12 Weeks | N analyzed: | 19
| Jadad: 3 | 3
| Population: | Unspecified
| Condition: | CHF
Langsjoen | Named trial: | Other | 1 | Placebo | N entered: | 19 | Excluded from statistical analysis because no outcomes of interest were reported. Statistically significant improvement in cardiac function with Co-Q10 among heart failure subjects.
1985b | | | | Placebo for 12 Weeks | N analyzed:
| Design: | RCT | 2 | Co-Q10 | N entered: | 19
| | | | 100 mg orally for 12 Weeks | N analyzed: | 19
| Jadad: 2 | 2
| Population: | Unspecified
| Condition: | CHF
Lankin 2000 | Named trial: | Other | 1 | Statin drug | N entered: | N/A | Excluded from meta-analysis of lipids as not relevant intervention. Co-Q10 prevented statin-induced increase in LDL oxidation as compared to placebo.
| | | | 40 mg orally for 6 Months | N analyzed: | N/A
| Design: | RCT | | Placebo
| | | | Placebo for 6 Months
| Jadad: | 2 | 2 | Stain drug | N entered: | N/A
| | | | 40 mg orally for 6 Months | | N/A
| Population: | Unspecified | | Co-Q10
| | | | 60 mg orally for 6 Months
| Condition: | CAD
Leppala 2000a | Named trial: | ATBC | 1 | Placebo | N entered: | 7153 | Excluded from meta-analysis of death as primary prevention study. ATBC study for vitamin E had small significant increase in fatal hemorrhagic stroke risk, non-significant reduction in stroke risk, no effect on incidence or mortality from total strokes.
| | | | Placebo for 6 Years | N analyzed: | 6901
| Design: | RCT | 2 | Vitamin E | N entered: | 7120
| | | | 50 mg orally for 6 Years | N analyzed: | 6869
| Jadad: | 3 | 3 | Beta-carotene | N entered: | 7128
| | | | 20 mg orally for 6 Years | N analyzed: | 6832
| Population: | Smokers | 4 | Vitamin E | N entered: | 7118
| Condition: | CVA/TIA | | 50 mg orally for 6 Years | N analyzed: | 6860
| | | | Beta-carotene
| | | | 20 mg orally for 6 Years
Leppala 2000b | Named trial: | ATBC | 1 | Placebo | N entered: | 7153 | Excluded from meta-analysis of death due to insufficient statistics. The ATBC study for vitamin E showed a small but significant increase in risk of hemorrhagic stroke, a significant reduction in risk of stroke among hypertensive men.
| | | | Placebo for 6 Years | N analyzed: | N/A
| Design: | RCT | 2 | Beta-carotene | N entered: | 7128
| | | | 20 mg orally for 6 Years | N analyzed: | N/A
| Jadad: | 3 | 3 | Vitamin E | N entered: | 7120
| | | | 50 mg orally for 6 Years | N analyzed: | N/A
| Population: | Smokers | 4 | Vitamin E | N entered: | 7118
| | | | 50 mg orally for 6 Years | N analyzed: | N/A
| Condition: | CVA/TIA | | Beta-carotene
| | | | 20 mg orally for 6 Years
Mark | Named trial: | Linxian | 1 | Placebo | N entered: | N/A | Excluded from meta-analysis of death as primary prevention study. Reductions in total mortality was found among the group receiving vitamin E in combination with other antioxidants. No improvement was found in blood pressure.
1998 | | | | Placebo for 5.25 Years | N analyzed: | N/A
| Design: | RCT | 2 | Niacin | N entered: | N/A
| | | | 40 mg orally for 5.25 Years | N analyzed: | N/A
| Jadad: | 1 | | Multi-vitamin
| | | | Multi-vitamin orally for 5.25 Years
| Population: | Unspecified | Years
| | | 3 | Vitamin C | N entered: | N/A
| Condition | CVA/TIA, HTN | | 120 mg orally for 5.25 Years | N analyzed: | N/A
| | | | Multi-vitamin
| | | | Multi-vitamin orally for 5.25 Years
| | | 4 | Vitamin C | N entered: | N/A
| | | | 120 mg orally for 5.25 Years | N analyzed: | N/A
| | | | Multi-vitamin
| | | | Multi-vitamin orally for 5.25 Years
| | | 5 | Vitamin E | N entered: | N/A
| | | | 30 mg orally for 5.25 Years | N analyzed: | N/A
| | | | Multi-vitamin
| | | | Multi-vitamin orally for 5.25 Years
| | | 6 | Vitamin C | N entered: | N/A
| | | | 120 mg orally for 5.25 Years | N analyzed: | N/A
| | | | Vitamin E
| | | | 30 mg orally for 5.25 Years
| | | | Multi-vitamin
| | | | Multi-vitamin orally for 5.25 Years
| | | 7 | Vitamin C | N entered: | N/A
| | | | 120 mg orally for 5.25 Years | N analyzed: | N/A
| | | | Vitamin E
| | | | 30 mg orally for 5.25 Years
| | | | Multi-vitamin
| | | | Multi-vitamin orally for 5.25 Years
| | | 8 | Vitamin E | N entered: | N/A
| | | | 30 mg orally for 5.25 Years | N analyzed: | N/A
| | | | Multi-vitamin
| | | | Multi-vitamin orally for 5.25 Years
Mazzola 1987 | Named trial: | Other | 1 | Placebo | N entered: | 20 | Excluded from statistical analysis because no outcomes of interest were reported. Significant reduction of anginal symptoms and heart failure scores and improved effort tolerance among Co-Q10 group.
| | | | Placebo for 4 Weeks | N analyzed: | 20
| Design: | RCT | 2 | Co-Q10 | N entered: | 20
| | | | 60 mg orally for 4 Weeks | N analyzed: | 20
| Jadad: | 2
| Population: | Unspecified
| Condition: | CHF, angina
McDowell 1994 | Named trial: | Other | 1 | Placebo | N entered: | 8 | Included in meta-analysis of lipids.
| | | | Placebo for 8 Weeks | N analyzed: | 8
| Design: | RCT | | Statin drug
| | | | 20 mg orally for 8 Weeks
| Jadad: | 2 | 2 | Probucol | N entered: | 8
| | | | 1000 mg orally for 8 Weeks | N analyzed: | 8
| Population: | Unspecified | | Statin drug
| | | | 20 mg orally for 8 Weeks
| Condition: | CAD, LL oxidation | 3 | Vitamin E | N entered: | 8
| | | | 400 IU orally for 8 Weeks | N analyzed: | 8
| | | | Statin drug
| | | | 20 mg orally for 8 Weeks
McGavin 2001 | Named trial: | Other | 1 | Placebo | N entered: | 40 | Included in meta-analysis of lipids.
| | | | Placebo for 8 Weeks | N analyzed: | 35
| Design: | RCT | 2 | Vitamin E | N entered: | 40
| | | | 28 IU orally for 8 Weeks | N analyzed: | 37
| Jadad: | 3 | 3 | Vitamin E | N entered: | 10
| | | | 200 IU orally for 8 Weeks | N analyzed: | 10
| Population: | Unspecified
| Condition: | CAD
Meagher 2001 | Named trial: | Other | 1 | Placebo | N entered: | 5 | Excluded from statistical analysis because no outcomes of interest were reported. No effect of vitamin E on lipid peroxidation.
| | | | Placebo for 8 Weeks | N analyzed: | 5
| Design: | RCT | 2 | Vitamin E | N entered: | 5
| | | | 200 IU orally for 8 Weeks | N analyzed: | 5
| Jadad: | 3 | 3 | Vitamin E | N entered: | 5
| | | | 400 IU orally for 8 Weeks | N analyzed: | 5
| Population: | Unspecified | 4 | Vitamin E | N entered: | 5
| | | | 800 IU orally for 8 Weeks | N analyzed: | 5
| Condition: | CAD | 5 | Vitamin E | N entered: | 5
| | | | 1200 IU orally for 8 Weeks | N analyzed: | 5
| | | 6 | Vitamin E | N entered: | 5
| | | | 2000 IU orally for 8 Weeks | N analyzed: | 5
Mensink 1999 | Named trial: | Other | 1 | Vitamin E | N entered: | 20 | Excluded from meta-analysis of lipids due to no placebo arm. No effect of vitamin E concentrate versus low-dose vitamin E on serum lipids among men with hyperlipidemia.
| | | | 80 mg orally for 6 Weeks | N analyzed: | 20
| Design: | RCT | | Palm olein
| | | | 960 mg orally for 6 Weeks
| Jadad: | 2 | | Tocotrienols in general
| | | | 160 mg orally for 6 Weeks
| Population: | Unspecified | 2 | Vitamin E | N entered: | 20
| | | | 80 mg orally for 6 Weeks | N analyzed: | 20
| Condition: CAD, LDL oxidation | | | Palm olein
| | | | 1120 mg orally for 6 Weeks
Meraji | Named trial: | Other | 1 | Beta-carotene | N entered: | 10 | Excluded from meta-analysis of lipids due to insufficient statistics. Vitamin E group showed significantly higher reduction in lipid oxidation than the other groups.
1997 | | | | 30 mg orally for 10 Weeks | N analyzed: | 7
| Design: | RCT | | Placebo
| | | | Placebo for 10 Weeks
| Jadad: | 2 | 2 | Beta-carotene | N entered: | 11
| | | | 30 mg orally for 10 Weeks | N analyzed: | 9
| Population: | Unspecified | | Vitamin E
| | | | 400 IU orally for 10 Weeks
| Condition: | CAD
Morisco 1993 | Named trial: | Other | 1 | Placebo | N entered: | 322 | Excluded from meta-analysis of death as not relevant intervention. CO-Q10 group had significantly fewer episodes of pulmonary edema and hospitalizations over the placebo group among heart failure subjects
| | | | Placebo for 52 Weeks | N analyzed: | 281
| Design: | RCT | 2 | Co-Q10 | N entered: | 319
| | | | 2 mg/kg orally for 52 Weeks | N analyzed: | 282
| Jadad: | 4
| Population: | Unspecified
| Condition: | CHF
Morisco 1994 | Named trial: | Other | 1 | Placebo | N entered: | 6 | Excluded from statistical analysis because no outcomes of interest were reported. Statistically significant improvement in hemodynamics at exercise in Co-Q10 group.
| | | | Placebo for 4 Weeks | N analyzed: | 6
| Design: | RCT | 2 | Co-Q10 | N entered: | 6
| | | | 150 mg orally for 4 Weeks | N analyzed: | 6
| Jadad: | 2
| Population: | Unspecified
| Condition: | CHF
Mosca 1996 | Named trial: | Other | 1 | Placebo | N entered: | 15 | Excluded from statistical analysis because no outcomes of interest were reported. Antioxidant combination including vitamins C and E was associated with decreased LDL oxidation.
| | | | Placebo for 12 Weeks | N analyzed: | N/A
| Design: | RCT | 2 | Vitamin E | N entered: | 15
| | | | 400 IU orally for 12 Weeks | N analyzed: | N/A
| Jadad: | 1 | | Vitamin C
| | | | 500 mg orally for 12 Weeks
| Population: | Unspecified | | Beta-carotene
| | | | 12 mg orally for 12 Weeks
| Condition: | CAD, LDL oxidation | 3 | Vitamin E | N entered: | 15
| | | | 800 IU orally for 12 Weeks | N analyzed: | N/A
| | | | Vitamin C
| | | | 1000 mg orally for 12 Weeks
| | | | Beta-carotene
| | | | 24 mg orally for 12 Weeks
Mosca 1997 | Named trial: | Other | 1 | Placebo | N entered: | 15 | Included in meta-analysis of lipids.
| | | | Placebo for 12 Weeks | N analyzed: | 14
| Design: | RCT | 2 | Vitamin E | N entered: | 15
| | | | 400 IU orally for 12 Weeks | N analyzed: | 13
| Jadad: | 4 | | Vitamin C
| | | | 500 mg orally for 12 Weeks
| Population: | Unspecified | | Beta-carotene
| | | | 12 mg orally for 12 Weeks
| Condition: | CAD | 3 | Vitamin E | N entered: | 15
| | | | 800 IU orally for 12 Weeks | N analyzed: | 14
| | | | Vitamin C
| | | | 1000 mg orally for 12 Weeks
| | | | Beta-carotene
| | | | 24 mg orally for 12 Weeks
Mottram 1999 | Named trial: | Other | 1 | Placebo | N entered: | 14 | Included in meta-analysis of lipids.
| | | | Placebo for 8 Weeks | N analyzed: | 14
| Design: | RCT | 2 | Vitamin E | N entered: | 14
| | | | 400 IU orally for 8 Weeks | N analyzed: | 14
| Jadad: | 3
| Population: | Unspecified
| Condition: | CAD
Munday 1999 | Named trial: | Other | 1 | Garlic - whole | N entered: | 9 | Excluded from meta-analysis of lipids due to insufficient followup time. Vitamin E group showed significant reduction in LDL oxidation as compared to placebo.
| | | | 6 gm orally for 7 Days | N analyzed: | 9
| Design: | RCT | 2 | Garlic - AGE | N entered: | 9
| | | | 2.4 gm orally for 7 Days | N analyzed: | 9
| Jadad: | 2 | 3 | Vitamin E | N entered: | 9
| | | | 800 mg orally for 7 Days | N analyzed: | 9
| Population: | Unspecified
| Condition: | CAD
Munkholm | Named trial: | Other | 1 | Placebo | N entered: | 11 | Excluded from statistical analysis because no outcomes of interest were reported. Co-Q10 group showed statistically significant improvement in some, but not all, measures of hemodynamics.
1999 | | | | Placebo for 12 Weeks | N analyzed: | 11
| Design: | RCT | 2 | Co-Q10 | N entered: | 11
| | | | 200 mg orally for 12 Weeks | N analyzed: | 11
| Jadad: | 2
| Population: | Unspecified
| Condition: | CHF
Nappo 1999 | Named trial: | Other | 1 | Placebo | N entered: | 20 | Excluded from meta-analysis of lipids as not relevant intervention. No significant change in blood pressure among any of the groups.
| | | | Placebo for 1 Day | N analyzed: | 20
| Design: | RCT | 2 | L-methionine | N entered: | 20
| | | | 100 mg/kg orally for 1 Day | N analyzed: | 20
| Jadad: | 2 | 3 | Vitamin E | N entered: | 20
| | | | 800 IU orally for 1 Day | N analyzed: | 20
| Population: | Unspecified | | Vitamin C
| | | | 1000 mg orally for 1 Day
| Condition: | Endothelial | | L-methionine
| dysfunction | | | 100 mg/kg orally for 1 Day
| | | 4 | Vitamin E | N entered: | 10
| | | | 800 IU orally for 1 Day | N analyzed: | 10
| | | | Vitamin C
| | | | 1000 mg orally for 1 Day
Ness | Named trial: | CHAOS | 1 | Placebo | N entered: | N/A | Excluded from meta-analysis of death and MI due to insufficient followup time. The ATBC trial and the CHAOS trial showed non-significant increases in all-cause mortality and coronary deaths with vitamin E treatment.
1999 | | | | No dosage data reported | N analyzed: | 967
| Design: | RCT | 2 | Vitamin E | N entered: | N/A
| | | | No dosage data reported | N analyzed: | 1035
| Jadad: | 3
| Population: | Unspecified
| Condition: | CAD
Nyyssonen | Named trial: | Other | 1 | Placebo | N entered: | 20 | Included in meta-analysis of lipids.
1994 | | | | Placebo for 3 Months | N analyzed: | 20
| Design: | RCT | 2 | Vitamin C | N entered: | 20
| | | | 400 mg orally for 3 Months | N analyzed: | 20
| Jadad: | 2 | | Vitamin E
| | | | 200 mg orally for 3 Months
| Population: | Smokers | | Selenium
| | | | 100 μg orally for 3 Months
| Condition: | CAD | | Beta-carotene
| | | | 30 mg orally for 3 Months
Nyyssonen | Named trial: | MASIT | 1 | Placebo | N entered: | N/A | Excluded from meta-analysis of lipids as not relevant intervention. Vitamin C showed no significant effect on lipid oxidation among smokers.
1997 | | | | Placebo for 2 Months | N analyzed: | 19
| Design: | RCT | 2 | Vitamin C | N entered: | N/A
| | | | 500 mg orally for 3 Months | N analyzed: | 20
| Jadad: | 3 | 3 | Vitamin C | N entered: | N/A
| | | | 500 mg orally for 2 Months | N analyzed: | 20
| Population: | Smokers
| Condition: | CAD, LDL oxidation
O'Byrne 2000 | Named trial: | Other | 1 | Placebo | N entered: | 13 | Excluded from meta-analysis of lipids as not relevant intervention. Vitamin E group showed no significant difference in total lipid levels, but did show significant reductions in lipid oxidation.
| | | | Placebo for 8 Weeks | N analyzed: | 13
| Design: | RCT | 2 | Alpha tocotrienol | N entered: | 13
| | | | 250 mg orally for 8 Weeks | N analyzed: | 13
| Jadad: | 4 | 3 | Gamma tocotrienol | N entered: | 13
| | | | 250 mg orally for 8 Weeks | N analyzed: | 12
| Population: | Unspecified | 4 | Delta tocotrienol | N entered: | 13
| Condition: | CAD, LDL oxidation | | 250 mg orally for 8 Weeks | N analyzed: | N/A
Oda | Named trial: | Other | 1 | Vitamin E | N entered: | N/A | Excluded from statistical analysis because no outcomes of interest were reported. Significant association found between Co-Q10 dose and measures of cardiac dysfunction among subjects with mitral valve prolapse.
1984 | | | | .75 mg/kg orally duration N/A | N analyzed: | 4
| Design: | CCT | 2 | Vitamin E | N entered: | N/A
| | | | 1.2 mg/kg orally duration N/A | N analyzed: | 47
| Jadad: | 0 | 3 | Vitamin E | N entered: | N/A
| | | | 1.7 mg/kg orally duration N/A | N analyzed: | 51
| Population: | Children | 4 | Vitamin E | N entered: | N/A
| | (under 18) | | 2.2 mg/kg orally duration N/A | N analyzed: | 62
| Condition: | MVP | 5 | Vitamin E | N entered: | N/A
| | | | 2.7 mg/kg orally duration N/A | N analyzed: | 21
| | | 6 | Vitamin E | N entered: | N/A
| | | | 3.2 mg/kg orally duration N/A | N analyzed: | 62
Oda | Named trial: | Other | 1 | Co-Q10 | N entered: | N/A | Excluded from statistical analysis because no outcomes of interest were reported. Positive dose response seen for Co-Q10 in measures of stress induced cardiac dysfunction among pediatric subjects with mitral valve prolapse.
1985 | | | | 0.6-0.9 mg/kg orally duration N/A | N analyzed: | 11
Study 1 | Design: | CCT
| | | 2 | Co-Q10 | N entered: | N/A
| Jadad: | 1 | | 1.0-1.4 mg/kg orally duration N/A | N analyzed: | 44
| Population: | Children | 3 | Co-Q10 | N entered: | N/A
| | (under 18) | | 1.5-1.9 mg/kg orally duration N/A | N analyzed: | 80
| Condition: | MVP | 4 | Co-Q10 | N entered: | N/A
| | | | 2.0-2.4 mg/kg orally duration N/A | N analyzed: | 166
| | | 5 | Co-Q10 | N entered: | N/A
| | | | 2.5-2.9 mg/kg orally duration N/A | N analyzed: | 54
| | | 6 | Co-Q10 | N entered: | N/A
| | | | 3.0-3.4 mg/kg orally duration N/A | N analyzed: | 45
Oda | Named trial: | Other | 1 | ATP | N entered: | 8 | Excluded from statistical analysis because no outcomes of interest were reported. Improvement seen in Co-Q10 group for stress induced cardiac dysfunction among pediatric subjects with mitral valve prolapse.
1985 | | | | 0.6–0.9 mg/kg orally duration N/A | N analyzed: | 8
Study 2 | Design: | RCT
| | | 2 | Co-Q10 | N entered: | 8
| Jadad: | 1 | | 1.0–1.4 mg/kg orally duration N/A | N analyzed: | 8
| Population: | Children
| | (under 18)
| Condition: | MVP
Oda | Named trial: | Other | 1 | Co-Q10 | N entered: | N/A | Excluded from statistical analysis because no outcomes of interest were reported. Significant association found between Co-Q10 dose and measures of cardiac dysfunction among pediatric subjects with mitral valve prolapse.
1986a | | | | 0.75 mg/kg orally duration N/A | N analyzed: | 11
| Design: | CCT | 2 | Co-Q10 | N entered: | N/A
| | | | 1.2 mg/kg orally duration N/A | N analyzed: | 44
| Jadad: | 0 | 3 | Co-Q10 | N entered: | N/A
| | | | 1.7 mg orally duration N/A | N analyzed: | 81
| Population: | Children | 4 | Co-Q10 | N entered: | N/A
| | (under 18) | | 2.2 mg orally duration N/A | N analyzed: | 58
| | | 5 | Co-Q10 | N entered: | N/A
| Condition: | MVP | | 2.7 mg orally duration N/A | N analyzed: | 112
| | | 6 | Co-Q10 | N entered: | N/A
| | | | 3.2 mg/kg orally duration N/A | N analyzed: | 166
Oda | Named trial: | Other | 1 | Co-Q10 | N entered: | N/A | Excluded from statistical analysis because no outcomes of interest were reported. Strong correlation was shown between dose of Co-Q10 and normalization of a test of cardiac dysfunction in children with mitral valve prolapse.
1986b | | | | 0.6–0.9 mg/kg orally duration N/A | N analyzed: | 11
| Design: | RCT
| | | 2 | Co-Q10 | N entered: | N/A
| Jadad: | 1 | | 1.0–1.4 mg/kg orally duration N/A | N analyzed: | 44
| Population: | Children | 3 | Co-Q10 | N entered: | N/A
| | (under 18) | | 1.5–1.9 mg/kg orally duration N/A | N analyzed: | 81
| Condition: | MVP | 4 | Co-Q10 | N entered: | N/A
| | | | 2.0–2.4 mg/kg orally duration N/A | N analyzed: | 166
| | | 5 | Co-Q10 | N entered: | N/A
| | | | 2.5–2.9 mg/kg orally duration N/A | N analyzed: | 54
| | | 6 | Co-Q10 | N entered: | N/A
| | | | 3.0–3.4 mg/kg orally duration N/A | N analyzed: | 45
Oda | Named trial: | Other | 1 | Co-Q10 | N entered: | 20 | Excluded from statistical analysis because no outcomes of interest were reported. Co-Q10 group exhibited improvement in cardiac dysfunction among subjects with mitral valve prolapse.
1990 | | | | 6.5 mg/kg orally for 7 Days | N analyzed: | 20
| Design: | RCT | 2 | Co-Q10 | N entered: | 40
| | | | 6.5 mg/kg orally for 14 Days | N analyzed: | 40
| Jadad: | 2
| Population: | Children (under 18)
| Condition: | CHF
Okamura 1983 | Named trial: | Other | 1 | Control or Usual care | N entered: | 18 | Excluded from statistical analysis because no outcomes of interest were reported. Co-Q10 group showed significant improvement in myocardial damage following cardiac surgery.
| | | | Control or Usual care for 2 Days | N analyzed: | 18
| Design: | CCT
| | | 2 | Co-Q10 | N entered: | 21
| Jadad: | 0 | | 5 mg/kg intravenously for 2 Days | N analyzed: | 21
| Population: | Unspecified
| Condition: | CAD
Okamura 1984 | Named trial: | Other | 1 | Control or Usual care | N entered: | 27 | Excluded from statistical analysis because no outcomes of interest were reported. There was increased ability to be weaned from intra-aortic balloon pump following aorto-coronary bypass surgery among the Co-Q10 group.
| | | | No dosage data reported | N analyzed: | N/A
| Design: | RCT | 2 | Co-Q10 | N entered: | 14
| | | | 5–10 mg/kg intravenously duration N/A | N analyzed: | N/A
| Jadad: | 1
| | | | Aprontin
| Population: | Unspecified | | 5000–10000 ku/kg intravenously duration N/A
| Condition: | CAD, CHF
Osilesi 1991 | Named trial: | Other | 1 | Placebo | N entered: | 20 | Excluded from meta-analysis of lipids due to study design. Reduction in systolic blood pressure was noted in vitamin C group with no change found in lipid levels.
| | | | Placebo for 6 Weeks | N analyzed: | 20
| Design: | RCT | 2 | Vitamin C | N entered: | 20
| | | | 1000 mg orally for 6 Weeks | N analyzed: | 20
| Jadad: | 2
| Population: | Unspecified
| Condition: | HTN
Palomaki 1998 | Named trial: | Other | 1 | Statin drug | N entered: | 20 | Excluded from meta-analysis of lipids as not relevant intervention. Small but significant improvement in LDL oxidation by Co-Q10 as compared to control among subjects receiving statin therapy.
| | | | 60 mg orally for 6 Weeks | N analyzed: | 19
| Design: | RCT | | Placebo
| | | | Placebo for 6 Weeks
| Jadad: | 3 | 2 | Co-Q10 | N entered: | 20
| | | | 180 mg orally for 6 Weeks | N analyzed: | 19
| Population: | Unspecified | | Statin drug
| | | | 60 mg orally for 6 Weeks
| Condition: | CAD
Palumbo 2000 | Named trial: | PPP | 1 | Control or Usual care | N entered: | N/A | Excluded from statistical analysis because no outcomes of interest were reported. No effect of vitamin E on blood pressure.
| | | | No dosage data reported | N analyzed: | 67
| Design: | RCT | 2 | Vitamin E | N entered: | N/A
| | | | 300 mg orally for 12 Weeks | N analyzed: | 75
| Jadad: | 3
| Population: | Unspecified
| Condition: | HTN
Paolisso 1995 | Named trial: | Other | 1 | Placebo | N entered: | 30 | Included in meta-analysis of lipids.
| | | | Placebo for 4 Months | N analyzed: | 30
| Design: | RCT | 2 | Vitamin E | N entered: | 30
| | | | 900 mg orally for 4 Months | N analyzed: | 30
| Jadad: | 2
| Population: | Elderly (over 65)
| Condition: | CAD
Park | Named trial: | Other | 1 | Placebo | N entered: | N/A | Excluded from statistical analysis because no outcomes of interest were reported. Antioxidant combination including vitamins C and E was associated with decreased cardiac allograft vasculopathy among transplant recipients.
1999 | | | | Placebo for 2 Years | N analyzed: | 16
| Design: | RCT | 2 | Vitamin E | N entered: | N/A
| | | | 600 mg orally for 2 Years | N analyzed: | 15
| Jadad: | 2 | | Vitamin C
| | | | 225 mg orally for 2 Years
| Population: | Unspecified | | Beta-carotene
| | | | 18 mg orally for 2 Years
| Condition: | CAD
Permanetter | Named trial: | Other | 1 | Placebo | N entered: | 26 | Excluded from statistical analysis because no outcomes of interest were reported. No effect of Co-Q10 on any hemodynamic measurements among subjects with idiopathic dilated cardiomyopathy.
1992 | | | | Placebo for 4 Months | N analyzed: | 25
| Design: | RCT | 2 | Co-Q10 | N entered: | 26
| | | | 100 mg orally for 4 Months | N analyzed: | 25
| Jadad: | 4
| Population: | Unspecified
| Condition: | CHF
Poggesi 1991 | Named trial: | Other | 1 | Placebo | N entered: | 20 | Excluded from statistical analysis because no outcomes of interest were reported. Co-Q10 group showed statistically significant improvement in some, but not all, measures of hemodynamics among subjects with dilated cardiomyopathy.
| | | | Placebo for 60 Days | N analyzed: | 18
| Design: | RCT | 2 | Co-Q10 | N entered: | 20
| | | | 100 mg orally for 60 Days | N analyzed: | 18
| Jadad: | 4
| Population: | Unspecified
| Condition: | CHF
Porkkala-Sarataho 1998 | Named trial: | MASIT | 1 | Placebo | N entered: | 20 | Included in meta-analysis of lipids.
| | | | Placebo for 2 Months | N analyzed: | 20
| Design: | RCT | 2 | Vitamin E | N entered: | 20
| | | | 200 mg orally for 2 Months | N analyzed: | 20
| Jadad: | 3 | 3 | Vitamin C | N entered: | 20
| | | | 500 mg orally for 2 Months | N analyzed: | 20
| Population: | Smokers | | Vitamin E
| | | | 200 mg orally for 2 Months
| Condition: | CAD
Porkkala-Sarataho 2000 | Named trial: | ASAP | 1 | Placebo | N entered: | 11 | Excluded from meta-analysis of lipids as not relevant outcome. Vitamin E alone and in combination with vitamin C reduced lipid oxidation whereas vitamin C alone had no effect.
| | | | Placebo for 36 Months | N analyzed: | 11
| Design: | RCT | 2 | Vitamin C | N entered: | 12
| | | | 500 mg orally for 36 Months | N analyzed: | 12
| Jadad: | 4 | 3 | Vitamin E | N entered: | 10
| | | | 272 IU orally for 36 Months | N analyzed: | 10
| Population: | Unspecified | 4 | Vitamin C | N entered: | 15
| | | | 500 mg orally for 36 Months | N analyzed: | 15
| Condition: | CAD | | Vitamin E
| | | | 272 IU orally for 36 Months
PPP | Named trial: | PPP | 1 | Placebo | N entered: | 2264 | Excluded from meta-analysis of death and MI as primary prevention study. Vitamin E showed no effect on the prevention of cardiovascular events among subjects at high risk.
2001 | | | | Placebo for 3.6 Years | N analyzed: | 2242
| Design: | RCT | 2 | Vitamin E | N entered: | 2231
| | | | 300 mg orally for 3.6 Years | N analyzed: | 1947
| Jadad: | 3
| Population: | Unspecified
| Condition: | CAD
Qureshi 1995 | Named trial: | Other | 1 | Vitamin E | N entered: | 16 | Excluded from meta-analysis of lipids due to insufficient followup time. Vitamin E led to significant reductions in lipid levels among hypercholesterolemic subjects.
| | | | 1 mg orally for 4 Weeks | N analyzed: | 16
| Design: | RCT | | Placebo
| | | | Placebo for 4 Weeks
| Jadad: | 0 | 2 | Vitamin E | N entered: | 20
| | | | 40 mg orally for 4 Weeks | N analyzed: | 20
| Population: | Unspecified | | Palm olein
| | | | 940 mg orally for 4 Weeks
| Condition: | CAD | | Alpha tocotrienol
| | | | 48 mg orally for 4 Weeks
| | | | Gamma tocotrienol
| | | | 112 mg orally for 4 Weeks
| | | | Delta tocotrienol
| | | | 60 mg orally for 4 Weeks
Raitakari 2000a | Named trial: | Other | 1 | Placebo | N entered: | 12 | Excluded from meta-analysis of lipids as not relevant outcome. Co-Q10 led to a significant decrease in LDL oxidation among subjects with moderate hypercholesterolemia.
| | | | Placebo for 4 Weeks | N analyzed: | 12
| Design: | RCT | 2 | Co-Q10 | N entered: | 12
| | | | 150 mg orally for 4 Weeks | N analyzed: | 12
| Jadad: | 2
| Population: | Unspecified
| Condition: | N/A
Raitakari 2000b | Named trial: | Other | 1 | Placebo | N entered: | 20 | Excluded from meta-analysis of lipids due to insufficient statistics. No effect of vitamin C on lipid levels among smokers.
| | | | Placebo for 2 Hours | N analyzed: | 20
| Design: | RCT | | Placebo
| | | | Placebo for 8 Weeks
| Jadad: | 2 | 2 | Vitamin C | N entered: | 20
| | | | 2 gm orally for 2 Hours | N analyzed: | 20
| Population: | Smokers | | Vitamin C
| | | | 1 gm orally for 8 Weeks
| Condition: | Endothelial dysfunction
Rapola 1996 | Named trial: | ATBC | 1 | Placebo | N entered: | 5549 | Excluded from statistical analysis because no outcomes of interest were reported. Small, but statistically significant, decrease in risk of angina symptoms with vitamin E among male smokers.
| | | | Placebo for 4.7 Years | N analyzed: | N/A
| Design: | RCT | 2 | Beta-carotene | N entered: | 5602
| | | | 20 mg orally for 4.7 Years | N analyzed: | N/A
| Jadad: | 3 | 3 | Vitamin E | N entered: | 5570
| | | | 50 mg orally for 4.7 Years | N analyzed: | N/A
| Population: | Smokers | 4 | Vitamin E | N entered: | 5548
| | | | 50 mg orally for 4.7 Years | N analyzed: | N/A
| Condition: | Angina
Rapola 1997 | Named trial: | ATBC | 1 | Placebo | N entered: | 438 | Included in meta-analysis of death and MI.
| | | | Placebo for 5.3 Years | N analyzed: | N/A
| Design: | RCT | 2 | Beta-carotene | N entered: | 461
| | | | 20 mg orally for 5.3 Years | N analyzed: | N/A
| Jadad: | 3 | 3 | Vitamin E | N entered: | 466
| | | | 50 mg orally for 5.3 Years | N analyzed: | N/A
| Population: | Smokers | 4 | Vitamin E | N entered: | 497
| | | | 50 mg orally for 5.3 Years | N analyzed: | N/A
| Condition: | CAD | | Beta-carotene
| | | | 20 mg orally for 5.3 Years
Reaven 1993 | Named trial: | Other | 1 | DL-alpha-tocopherol | N entered: | 8 | Excluded from meta-analysis of lipids due to no placebo arm. Vitamin E groups showed significant reductions in LDL oxidation.
| | | | 1600 mg orally for 2 Months | N analyzed: | 8
| Design: | RCT | 2 | RRR-alpha-tocopherol | N entered: | 8
| | | | 1600 mg orally for 2 Months | N analyzed: | 7
| Jadad: | 3
| Population: | Unspecified
| Condition: | CAD, LDL oxidation
Rokitzki 1994 | Named trial: | Other | 1 | Placebo | N entered: | N/A | Excluded from statistical analysis because no outcomes of interest were reported. No improvement in performance, but significant reduction in oxidative stress measures among athletes in vitamin E group.
| | | | Placebo for 151 Days | N analyzed: | 15
| Design: | RCT | 2 | Vitamin E | N entered: | N/A
| | | | 330 mg orally for 151 Days | N analyzed: | 15
| Jadad: | 3
| Population: | Unspecified
| Condition: | CAD
Rossi | Named trial: | Other | 1 | Placebo | N entered: | 10 | Excluded from statistical analysis because no outcomes of interest were reported. Improved exercise tolerance, but no change in resting hemodynamics, among Co-Q10 subjects.
1991 | | | | Placebo for 90 Days | N analyzed: | N/A
| Design: | RCT | 2 | Co-Q10 | N entered: | 10
| | | | 200 mg orally for 90 Days | N analyzed: | N/A
| Jadad: | 2
| Population: | Unspecified
| Condition: | CAD, CHF
Salonen 2000 | Named trial: | ASAP | 1 | Placebo | N entered: | 130 | Excluded from meta-analysis of death as primary prevention study. Significant reduction in progression of carotid atherosclerosis in vitamin combination group as compared to placebo.
| | | | Placebo for 3 Years | N analyzed: | 110
| Design: | RCT | 2 | Vitamin E | N entered: | 130
| | | | 272 IU orally for 3 Years | N analyzed: | 115
| Jadad: | 4 | 3 | Vitamin C | N entered: | 130
| | | | 500 mg orally for 3 Years | N analyzed: | 120
| Population: | Unspecified
| | | 4 | Vitamin C | N entered: | 130
| | | | 500 mg orally for 3 Years | N analyzed: | 113
| Condition: atherosclerosis | Carotid
| | | | Vitamin E
| | | | 272 IU orally for 3 Years
Samman 1997 | Named trial: | Other | 1 | Placebo | N entered: | 10 | Excluded from meta-analysis of lipids as not relevant intervention. Vitamin C showed no significant effect on lipid levels or on LDL oxidation among smokers.
| | | | Placebo for 2 Weeks | N analyzed: | 8
| Design: | RCT | 2 | Vitamin C | N entered: | 10
| | | | 1 gm orally for 2 Weeks | N analyzed: | 8
| Jadad: | 2
| Population: | Smokers
| Condition: | CAD, LDL oxidation
Schafer 1990 | Named trial: | Other | 1 | Placebo | N entered: | 15 | Included in meta-analysis of lipids.
| | | | Placebo for 3 Months | N analyzed: | 15
| Design: | RCT | 2 | Vitamin E | N entered: | 15
| | | | 300 mg orally for 3 Months | N analyzed: | 15
| Jadad: | 1 | | Selenium
| | | | 125 μg orally for 3 Months
| Population: | Female Elderly (Over 65)
| Condition: | CAD, LDL oxidation
Schardt, 1991 | Named trial: | Other | 1 | Placebo | N entered: | 15 | Excluded from statistical analysis because no outcomes of interest were reported. Statistically significant improved ST-segment depression in Co-Q10 group.
| | | | Placebo for 4 Days | N analyzed: | 15
| Design: | RCT | 2 | Co-Q10 | N entered: | 15
| | | | 600 mg orally for 4 Days | N analyzed: | 15
| Jadad: | 2
| Population: | Female
| Condition: | CAD, angina
Schardt 1986 | Named trial: | Other | 1 | Placebo | N entered: | 15 | Excluded from statistical analysis because no outcomes of interest were reported. Significant effect of Co-Q10 on ischemia-related ECG changes.
| | | | Placebo for 4 Days | N analyzed: | N/A
| Design: | RCT | 2 | Co-Q10 | N entered: | 15
| | | | 600 mg orally for 4 Days | N analyzed: | N/A
| Jadad: | 2
| Population: | Female
| Condition: | CAD
Schneeberger | Named trial: | Other | 1 | Placebo | N entered: | 12 | Excluded from statistical analysis because no outcomes of interest were reported. Co-Q10 group showed significantly improved measures of cardiac function.
1986 | | | | Placebo for 15 Weeks | N analyzed: | 6
| Design: | CCT | 2 | Co-Q10 | N entered: | 12
| | | | 100 mg orally for 15 Weeks | N analyzed: | 6
| Jadad: | 1
| Population: | Unspecified
| Condition: | CHF
Semple 1974 | Named trial: | Other | 1 | Control or Usual care | N entered: | 14 | Excluded from statistical analysis because no outcomes of interest were reported. No impact of vitamin E on intermittent claudication symptoms.
| | | | Control or Usual care for 6 Months | N analyzed: | 14
| Design: | CCT
| | | 2 | Vitamin E | N entered: | 12
| Jadad: | 0 | | 400 mg orally for 6 Months | N analyzed: | 12
| Population: | Unspecified
| Condition: | PVD
Serra | Named trial: | Other | 1 | Placebo | N entered: | 20 | Excluded from statistical analysis because no outcomes of interest were reported. Co-Q10 group showed statistically significant improvement in some, but not all, measures of hemodynamics.
1991 | | | | Placebo for 4 Weeks | N analyzed: | 20
| Design: | RCT | 2 | Co-Q10 | N entered: | 20
| | | | 60 mg orally for 4 Weeks | N analyzed: | 20
| Jadad: | 2
| Population: | Unspecified
| Condition: | CAD, CHF, angina
Simons 1996 | Named trial: | Other | 1 | Placebo | N entered: | 11 | Excluded from statistical analysis because no outcomes of interest were reported. Significant reduction in LDL oxidation among all doses of vitamin E as compared to placebo.
| | | | Placebo for 6 Weeks | N analyzed: | 11
| Design: | RCT | 2 | Vitamin E | N entered: | 11
| | | | 500 IU orally for 6 Weeks | N analyzed: | 11
| Jadad: | 3 | 3 | Vitamin E | N entered: | 9
| | | | 1000 IU orally for 6 Weeks | N analyzed: | 8
| Population: | Unspecified | 4 | Vitamin E | N entered: | 11
| | | | 1500 IU orally for 6 Weeks | N analyzed: | 11
| Condition: | CAD
Singh | Named trial: | Other | 1 | Placebo | N entered: | 62 | Excluded from meta-analysis of death and MI due to insufficient followup time. Antioxidant group showed significantly smaller infarction size after acute MI and significantly lower rates of lipid oxidation and most, but not all, cardiac end points.
1996 | | | | Placebo for 3 Days | N analyzed: | 62
| Design: | RCT | | Placebo
| | | | Placebo for 28 Days
| Jadad: | 4 | | Placebo
| | | | Placebo for 25 Days
| Population: | Unspecified | 2 | Vitamin A | N entered: | 63
| | | | 50000 IU intravenously for 3 Days | N analyzed: | 63
| Condition: | CAD
| | | | Vitamin C
| | | | 1000 mg intravenously for 3 Days
| | | | Vitamin E
| | | | 400 mg orally for 28 Days
| | | | Beta-carotene
| | | | 25 mg orally for 28 Days
| | | | Vitamin A
| | | | 50000 IU orally for 25 Days
| | | | Vitamin C
| | | | 1000 mg orally for 25 Days
Singh | Named trial: | Other | 1 | Placebo | N entered: | 71 | Excluded from meta-analysis of death as not relevant intervention. Excluded from meta-analysis of MI due to insufficient followup time. Co-Q10 group showed significant reductions in all adverse cardiovascular measures following acute MI compared to placebo.
1998 | | | | Placebo for 28 Days | N analyzed: | 71
| Design: | RCT | 2 | Co-Q10 | N entered: | 73
| | | | 120 mg orally for 28 Days | N analyzed: | 73
| Jadad: | 1
| Population: | Unspecified
| Condition: | CAD, angina
Singh | Named trial: | Other | 1 | Placebo | N entered: | 24 | Excluded from meta-analysis of lipids as not relevant intervention. Co-Q10 led to significant reduction over placebo in serum lipoproteins and lipid oxidation and significant elevation in HDL cholesterol among subjects with coronary artery disease.
1999a | | | | Placebo for 28 Days | N analyzed: | 22
| Design: | RCT | 2 | Co-Q10 | N entered: | 27
| Jadad: | 4 | | 120 mg orally for 28 Days | N analyzed: | 25
| Population: | Unspecified
| Condition: | CAD
Singh | Named trial: | Other | 1 | Multi-vitamin | N entered: | 32 | Excluded from meta-analysis of lipids as not relevant intervention. Co-Q10 group showed significant decrease in blood pressure, blood glucose levels, triglyceride levels in subjects with CAD and HTN with no change in placebo group.
1999b | | | | Multi-vitamin orally for 8 Weeks | N analyzed: | 29
| Design: | RCT
| | | 2 | Co-Q10 | N entered: | 32
| Jadad: | 4 | | 120 mg orally for 8 Weeks | N analyzed: | 30
| Population: | Unspecified
| Condition: | CAD
Singhal 2001 | Named trial: | Other | 1 | Placebo | N entered: | 35 | Excluded from meta-analysis of lipids due to insufficient followup time. No significant change in lipids in vitamin E or vitamin C groups. Vitamin E group showed the strongest reduction in lipid oxidation among all treatment groups.
| | | | Placebo for 30 Days | N analyzed: | 32
| Design: | RCT | 2 | Vitamin E | N entered: | 35
| | | | 400 IU orally for 30 Days | N analyzed: | 32
| Jadad: | 2 | 3 | Vitamin C | N entered: | 35
| | | | 1000 mg orally for 30 Days | N analyzed: | 31
| Population: | Unspecified | 4 | Vitamin A | N entered: | 35
| | | | 25000 IU orally for 30 Days | N analyzed: | 32
| Condition: | CAD, LDL oxidation | 5 | Fruit | N entered: | 35
| | | | 400 gm orally for 30 Days | N analyzed: | 30
Sisto | Named trial: | Other | 1 | Control or Usual care | N entered: | 25 | Excluded from meta-analysis of MI due to insufficient followup time. Significant improvements in cardiac event rates were noted in the intervention groups as compared to control groups among subjects status post cardiovascular surgery.
1995 | | | | No dosage data reported | N analyzed: | N/A
| Design: | RCT | 2 | Vitamin E | N entered: | 20
| | | | 600 mg orally for 28 Days | N analyzed: | N/A
| Jadad: | 2 | | Vitamin C
| | | | 2 gm orally for 3 Days
| Population: | Unspecified | | Allopurinol
| | | | 600 mg orally for 3 Days
| Condition: | CAD | 3 | Control or Usual care | N entered: | 19
| | | | No dosage data reported | N analyzed: | N/A
| | | 4 | Vitamin E | N entered: | 17
| | | | 600 mg orally for 2 Days | N analyzed: | N/A
| | | | Vitamin C
| | | | 2 gm orally for 3 Days
| | | | Allopurinol
| | | | 600 mg orally for 3 Days
Stampfer 1983 | Named trial: | Other | 1 | Placebo | N entered: | 15 | Included in meta-analysis of lipids.
| | | | Placebo for 16 Weeks | N analyzed: | 15
| Design: | RCT | 2 | Vitamin E | N entered: | 15
| | | | 800 IU orally for 16 Weeks | N analyzed: | 15
| Population: | Unspecified
| Condition: | CAD
Steiner 1995 | Named trial: | Other | 1 | Aspirin | N entered: | 48 | Excluded from meta-analysis of death due to insufficient statistics. Significant reduction in ischemic event rates among aspirin plus vitamin E group was found.
| | | | 325 mg orally for 2 Years | N analyzed: | 40
| Design: | RCT | 2 | Vitamin E | N entered: | 52
| | | | 400 IU orally for 2 Years | N analyzed: | 44
| Jadad: | 3 | | Aspirin
| | | | 325 mg orally for 2 Years
| Population: | Unspecified
| Condition: | CVA/TIA
Stephens 1996 | Named trial: | CHAOS | 1 | Placebo | N entered: | 967 | Included in meta-analysis of death and MI.
| | | | Placebo for 494 Days | N analyzed: | 948
| Design: | RCT | 2 | Vitamin E | N entered: | 546
| | | | 800 IU orally for 737 Days | N analyzed: | N/A
| Jadad: | 3 | 3 | Vitamin E | N entered: | 489
| | | | 400 IU orally for 366 Days | N analyzed: | N/A
| Population: | Unspecified
| Condition: | CAD
Taggart 1996 | Named trial: | Other | 1 | Placebo | N entered: | 10 | Excluded from statistical analysis because no outcomes of interest were reported. No improvement in myocardial protection following bypass surgery among subjects pretreated with Co-Q10.
| | | | Placebo for 12 Hours | N analyzed: | 10
| Design: | RCT | 2 | Co-Q10 | N entered: | 10
| | | | 600 mg orally for 12 Hours | N analyzed: | 10
| Jadad: | 4
| Population: | Unspecified
| Condition: | CAD
Takamatsu | Named trial: | Other | 1 | Vitamin E | N entered: | 73 | Excluded from meta-analysis of MI due to insufficient statistics. Excluded from meta-analysis of lipids due to no placebo arm. Higher rates of myocardial disease were found among subjects receiving the higher dose of vitamin E.
1995 | | | | 3 mg orally for 6 Years | N analyzed: | 63
| Design: | RCT | 2 | Vitamin E | N entered: | 74
| | | | 100 mg orally for 6 Years | N analyzed: | 69
| Jadad: | 5
| Population: | Unspecified
| Condition: | CAD
Tanaka 1982 | Named trial: | Other | 1 | Control or Usual care | N entered: | 25 | Excluded from statistical analysis because no outcomes of interest were reported. Statistically significant reduction in low cardiac output state following cardiac valve replacement in Co-Q10 group.
| | | | No dosage data reported | N analyzed: | 25
| Design: | RCT | 2 | Co-Q10 | N entered: | 25
| | | | 30–60 mg orally for 6 Days | N analyzed: | 25
| Jadad: | 1
| Population: | Unspecified
| Condition: | CHF
Tardif | Named trial: | MVP | 1 | Placebo | N entered: | 79 | Included in meta-analysis of death. Excluded from meta-analysis of MI as not relevant outcome. No statistically significant difference in outcomes following angioplasty between antioxidant and no antioxidant groups.
1997 | | | | Placebo for 7 Months | N analyzed: | 62
| Design: | RCT | 2 | Statin drug | N entered: | 80
| | | | 500 mg orally for 7 Months | N analyzed: | 58
| Jadad: | 3 | 3 | Vitamin C | N entered: | 78
| | | | 500 mg orally for 7 Months | N analyzed: | 54
| Population: | Unspecified | | Vitamin E
| | | | 700 IU orally for 7 Months
| Condition: | CAD | | Beta-carotene
| | | | 30000 IU orally for 7 Months
| | | | Vitamin E
| | | | 2000 IU orally for 1 Day
| | | 4 | Statin drug | N entered: | 80
| | | | 500 mg orally for 7 Months | N analyzed: | 56
| | | | Vitamin C
| | | | 500 mg orally for 7 Months
Tomeo 1995 | Named trial: | Other | 1 | Palm olein | N entered: | 25 | Included in meta-analysis of lipids.
| | | | 1200 mg orally for 18 Months | N analyzed: | 25
| Design: | RCT | 2 | Vitamin E | N entered: | 25
| | | | 64 mg orally for 18 Months | N analyzed: | 25
| Jadad: | 4 | | Palm olein
| | | | 960 mg orally for 18 Months
| Population: | Unspecified | | Alpha tocotrienol
| | | | 160 mg orally for 18 Months
| Condition: | Carotid
| | atherosclerosis | | Gamma tocotrienol
| | | | 160 mg orally for 18 Months
Toone | Named trial: | Other | 1 | Placebo | N entered: | 11 | Excluded from statistical analysis because no outcomes of interest were reported. Significant reduction in nitroglycerin use among subjects with ischemic heart disease given vitamin E.
1973 | | | | Placebo for 2 Years | N analyzed: | N/A
| Design: | CCT | 2 | Vitamin E | N entered: | 11
| | | | 1600 IU orally for 2 Years | N analyzed: | N/A
| Jadad: | 1
| Population: | Unspecified
| Condition: | CAD, angina
Tornwall 1997 | Named trial: | ATBC | 1 | Placebo | N entered: | 6573 | Excluded from statistical analysis because no outcomes of interest were reported. No preventative effect of vitamin E on intermittent claudication found from among male smokers.
| | | | Placebo for 4 Years | N analyzed: | 4667
| Design: | RCT | 2 | Vitamin E | N entered: | 6605
| | | | 50 mg orally for 4 Years | N analyzed: | 4690
| Jadad: | 3 | 3 | Beta-carotene | N entered: | 6559
| | | | 20 mg orally for 4 Years | N analyzed: | 4591
| Population: | Smokers | 4 | Vitamin E | N entered: | 6552
| Condition: | PVD | | 50 mg orally for 4 Years | N analyzed: | 4586
| | | | Beta-carotene
| | | | 20 mg orally for 4 Years
Tornwall 1999 | Named trial: | ATBC | 1 | Placebo | N entered: | 373 | Excluded from statistical analysis because no outcomes of interest were reported. No effect of vitamin E on claudication symptoms among men with baseline claudication.
| | | | Placebo for 3.7 Years | N analyzed: | N/A
| Design: | RCT | 2 | Beta-carotene | N entered: | 377
| | | | 20 mg orally for 3.7 Years | N analyzed: | N/A
| Jadad: | 3 | 3 | Vitamin E | N entered: | 344
| | | | 50 mg orally for 3.7 Years | N analyzed: | N/A
| Population: | Smokers | 4 | Vitamin E | N entered: | 390
| | | | 50 mg orally for 3.7 Years | N analyzed: | N/A
| Condition: | PVD | | Beta-carotene
| | | | 20 mg orally for 3.7 Years
Tornwall 2001 | Named trial: | ATBC | 1 | Placebo | N entered: | 7287 | Excluded from meta-analysis of death due to insufficient statistics. No significant preventive effect of vitamin E on abdominal aortic aneurysm formation or rupture.
| | | | Placebo for 5.8 Years | N analyzed: | N/A
| Design: | RCT | 2 | Vitamin E | N entered: | 7286
| | | | 50 mg orally for 5.8 Years | N analyzed: | N/A
| Jadad: | 3 | 3 | Beta-carotene | N entered: | 7282
| | | | 20 mg orally for 5.8 Years | N analyzed: | N/A
| Population: | Smokers | 4 | Vitamin E | N entered: | 7282
| | | | 50 mg orally for 5.8 Years | N analyzed: | N/A
| Condition: | AAA | | Beta-carotene
| | | | 20 mg orally for 5.8 Years
Tsai | Named trial: | Other | | Placebo | N entered: | 98 | Excluded from meta-analysis of lipids due to insufficient followup time. No significant change in lipids with vitamin E except for small but statistically significant increase in serum triglycerides among female subjects.
1978 | | | | Placebo for 4 Weeks | N analyzed: | 90
| Design: | RCT | 2 | Vitamin E | N entered: | 104
| | | | 600 IU orally for 4 Weeks | N analyzed: | 94
| Jadad: | 3
| Population: | Unspecified
| Condition: | CAD
Upritchard | Named trial: | Other | 1 | Placebo | N entered: | 13 | Excluded from statistical analysis because no outcomes of interest were reported. Decrease in LDL oxidation found among vitamin E group, but not among vitamin C group.
2000 | | | | Placebo for 4 Weeks | N analyzed: | 13
| Design: | RCT | 2 | Tomato juice | N entered: | 15
| | | | 500 ml orally for 4 Weeks | N analyzed: | 15
| Jadad: | 3 | 3 | Vitamin E | N entered: | 12
| | | | 800 IU orally for 4 Weeks | N analyzed: | 12
| Population: | Unspecified | 4 | Vitamin C | N entered: | 12
| Condition: | CAD | | 500 mg orally for 4 weeks | N analyzed: | 12
Vanfraechem | Named trial: | Other | 1 | Placebo | N entered: | N/A | Excluded from statistical analysis because no outcomes of interest were reported.
1986 | | | | Placebo for 12 Weeks | N analyzed: | N/A
| Design: | RCT | 2 | Co-Q10 | N entered: | N/A | Improvement in physical performance found in Co-Q10 group.
| | | | 99 mg orally for 12 Weeks | N analyzed: | N/A
| Jadad: | 2
| Population: | Unspecified
| Condition: | CHF
Virtamo 1998 | Named trial: | ATBC | 1 | Placebo | N entered: | 6849 | Excluded from meta-analysis of death and MI as primary prevention study. No statistically significant effect of vitamin E on fatal coronary heart disease or nonfatal myocardial infarction among male smokers.
| | | | Placebo for 6.1 Years | N analyzed: | N/A
| Design: | RCT | 2 | Vitamin E | N entered: | 6820
| | | | 50 mg orally for 6.1 Years | N analyzed: | N/A
| Jadad: | 3 | 3 | Beta-carotene | N entered: | 6821
| | | | 20 mg orally for 6.1 Years | N analyzed: | N/A
| Population: | Smokers | 4 | Vitamin E | N entered: | 6781
| | | | 50 mg orally for 6.1 Years | N analyzed: | N/A
| Condition: | CAD | | Beta-carotene
| | | | 20 mg orally for 6.1 Years
Wagdi | Named trial: | Other | 1 | Placebo | N entered: | N/A | Excluded from statistical analysis because no outcomes of interest were reported. No statistically significant effects of vitamins E and C on cardioprotection among subjects receiving toxic chemotherapy.
1996 | | | | No dosage data reported | N analyzed: | 13
| Design: | RCT | 2 | Vitamin E | N entered: | N/A
| | | | 600 mg orally duration N/A | N analyzed: | 12
| Jadad: | 3 | | Vitamin C
| | | | 1000 mg orally duration N/A
| Population: | Unspecified | | N-acetyl cysteine
| | | | 200 mg orally duration N/A
| Condition: | Cardiotoxicity
Watanabe | Named trial: | Other | 1 | Placebo | N entered: | 10 | Excluded from statistical analysis because no outcomes of interest were reported. Vitamin C group exhibited lower tolerance to intravenous nitrates among subjects with heart failure.
1998 | | | | Placebo for 24 Hours | N analyzed: | 10
| Design: | RCT | | Nitroglycerine
| | | | Dose N/A intravenously for 24 Hours
| Jadad: | 2
| | | 2 | Vitamin C | N entered: | 10
| Population: | Unspecified | | 55 microgram/kg | N analyzed: | 10
| | | | intravenously for 24 Hours
| Condition: | CHF | | Nitroglycerine
| | | | Dose N/A intravenously for 24 Hours
Watson 1999 | Named trial: | Other | 1 | Placebo | N entered: | 30 | Excluded from statistical analysis because no outcomes of interest were reported. No effect of Co-Q10 found on systolic function or quality of life measures among subjects with heart failure.
| | | | Placebo for 12 Weeks | N analyzed: | 27
| Design: | RCT | 2 | Co-Q10 | N entered: | 30
| | | | 99 mg orally for 12 Weeks | N analyzed: | 27
| Jadad: | 2
| Population: | Unspecified
| Condition: | CHF
Wen | Named trial: | Other | 1 | Control or Usual care | N entered: | 9 | Excluded from meta-analysis of lipids as not relevant outcome. Vitamin C showed no significant effect on lipid oxidation.
1997 | | | | No dosage data reported | N analyzed: | 9
| Design: | CCT | 2 | Vitamin C | N entered: | 11
| | | | 1000 mg orally for 4 Weeks | N analyzed: | 11
| Jadad: | 0
| Population: | Unspecified
| Condition: | CAD, LDL oxidation
Wen | Named trial: | Other | 1 | Placebo | N entered: | 22 | Excluded from meta-analysis of lipids due to insufficient statistics. Vitamin E group showed significant reduction in LDL oxidation as compared to placebo.
1999 | | | | Placebo for 30 Weeks | N analyzed: | 17
| Design: | RCT | 2 | Vitamin E | N entered: | 27
| | | | 100 IU orally for 6 Weeks | N analyzed: | 20
| Jadad: | 3 | | Vitamin E
| | | | 200 IU orally for 6 Weeks
| Population: | Unspecified | | Vitamin E
| | | | 400 IU orally for 6 Weeks
| Condition: | CAD, LDL oxidation | | Vitamin E
| | | | 800 IU orally for 6 Weeks
| | | | Vitamin E
| | | | 1600 IU orally for 6 Weeks
Westhuyzen | Named trial: | Other | 1 | Placebo | N entered: | 38 | Excluded from statistical analysis because no outcomes of interest were reported. No reduction in myocardial injury following cardiac surgery among vitamin E or vitamin C groups.
1997 | | | | Placebo for 10 Days | N analyzed: | 38
| Design: | RCT | | Placebo
| | | | Placebo for 1 Day
| Jadad: | 2 | 2 | Vitamin C | N entered: | 38
| | | | 1000 mg orally for 1 Day | N analyzed: | 38
| Population: | Unspecified | | Vitamin E
| | | | 750 IU orally for 10 Days
| Condition: | CAD, reperfusion injury
Whittaker 1987 | Named trial: | Other | 1 | Control or Usual care | | N/A | Excluded from statistical analysis because no outcomes of interest were reported. No cardioprotective effect of vitamin E among subjects receiving chemotherapy.
| | | | No dosage data reported | N analyzed: | N/A
| Design: | RCT | 2 | Digoxin | N entered: | N/A
| | | | 0.25 mg orally duration N/A | N analyzed: | N/A
| Jadad: | 1 | 3 | Vitamin E | N entered: | N/A
| | | | 600 mg orally duration N/A | N analyzed: | N/A
| Population: | Unspecified
| Condition: | Cardiotoxicity
Williams 1962 | Named trial: | Other | 1 | Placebo | N entered: | 17 | Excluded from statistical analysis because no outcomes of interest were reported.
| | | | No dosage data reported | N analyzed: | 17
| Design: | RCT | 2 | Vitamin E | N entered: | 16 | Suggestions of improvement of claudication symptoms with Co-Q10 treatment without statistical significance.
| | | | 1600 mg orally duration N/A | N analyzed: | 16
| Jadad: | 2
| Population: | Unspecified
| Condition: | PVD
Williams 1971 | Named trial: | Other | 1 | Placebo | N entered: | 29 | Excluded from statistical analysis because no outcomes of interest were reported. Vitamin E showed significant improvement among some, but not all, subjects with peripheral vascular occlusive disease.
| | | | Placebo for 13.4 Months | N analyzed: | N/A
| Design: | RCT | 2 | Vitamin E | N entered: | 45
| | | | 1600 mg orally for 26.8 Months | N analyzed: | N/A
| Jadad: | 2
| Population: | Unspecified
| Condition: | PVD
Wilson 1991 | Named trial: | Other | 1 | Placebo | N entered: | 17 | Excluded from statistical analysis because no outcomes of interest were reported. Statistically significant improvement in exercise duration with Co-Q10 among subjects with angina symptoms.
| | | | Placebo for 4 Weeks | N analyzed: | 17
| Design: | CCT | 2 | Co-Q10 | N entered: | 20
| | | | 150 mg orally for 4 Weeks | N analyzed: | 20
| Jadad: | 1 | 3 | Co-Q10 | N entered: | 21
| | | | 300 mg orally for 4 Weeks | N analyzed: | 21
| Population: | Unspecified
| Condition: | CAD, angina
Woodside 1999 | Named trial: | Other | | Placebo | N entered: | 33 | Excluded from statistical analysis because no outcomes of interest were reported. Combinations of antioxidants including vitamins C and E showed improvement in measures of LDL oxidation.
| | | | Placebo for 8 Weeks | N analyzed: | 26
| Design: | RCT | 2 | Multi-vitamin | N entered: | 32
| Jadad: | 4 | | Multi-vitamin orally for 8 Weeks | N analyzed: | 22
| Population: | Unspecified | 3 | Vitamin C | N entered: | 33
| | | | 150 mg orally for 8 Weeks | N analyzed: | 25
| Condition: | | | Vitamin E
| | Hyperhomocystinemia, | | 67 mg orally for 8 Weeks
| | LDL oxidation. | | Beta-carotene
| | | | 9 mg orally for 8 Weeks
| | | 4 | Vitamin C | N entered: | 34
| | | | 150 mg orally for 8 Weeks | N analyzed: | 28
| | | | Vitamin E
| | | | 67 mg orally for 8 Weeks
| | | | Beta-carotene
| | | | 9 mg orally for 8 Weeks
| | | | Multi-vitamin
| | | | Multi-vitamin orally for 8 Weeks
Yamagami | Named trial: | Other | 1 | Placebo | N entered: | 10 | Excluded from statistical analysis because no outcomes of interest were reported. Statistically significant reduction of systolic blood pressure found among Co-Q10 group.
1986 | | | | Placebo for 12 Weeks | N analyzed: | 10
| Design: | RCT | 2 | Co-Q10 | N entered: | 10
| | | | 100 mg orally for 12 Weeks | N analyzed: | 10
| Jadad: | 3
| Population: | Unspecified
| Condition: | HTN
Yamamura | Named trial: | Other | 1 | Co Q7 | N entered: | 21 | Excluded from statistical analysis because no outcomes of interest were reported. No significant effect on severity of heart failure in Co-Q10 group.
1977 | | | | 75 mg intravenously for 98 Days | N analyzed: | 21
| Design: | CCT
| | | 2 | Co Q7 | N entered: | 17
| Jadad: | 0 | | 60 mg orally for 98 Days | N analyzed: | 17
| | | 3 | Co-Q10 | N entered: | 17
| Population: | Unspecified | | 30 mg orally for 98 Days | N analyzed: | 17
| Condition: | CHF
Yau | Named trial: | Other | 1 | Placebo | N entered: | 14 | Excluded from statistical analysis because no outcomes of interest were reported. Significant functional and metabolic improvements were found post cardiac surgery among vitamin E group.
1994 | | | | Placebo for 14 Days | N analyzed: | 14
| Design: | RCT | 2 | Vitamin E | N entered: | 14
| | | | 300 mg orally for 14 Days | N analyzed: | 14
| Jadad: | 4
| Population: | Unspecified
| Condition: | CAD, reperfusion injury
Yusuf, 2000 | Named trial: | HOPE | 1 | Placebo | N entered: | 4780 | Included in meta-analysis of death and MI.
| | | | Placebo for 4.5 Years | N analyzed: | N/A
| Design: | RCT | 2 | Vitamin E | N entered: | 4761
| | | | 400 IU orally for 4.5 Years | N analyzed: | N/A
| Jadad: | 3
| Population: | Unspecified
| Condition: | CAD, CVA/TIA

AAA = abdominal aortic aneurysm; CAD = coronary artery disease; CCT = clinical controlled trial; CHF = congestive heart failure; CVA/TIA = cerebrovascular accident/transient ischemic attack; DM = diabetes melitus; HTN = hypertension; LDL = low density lipoprotein; MI = myocardial infarction; MVP = mitral valve prolapse; N/A = not applicable/not available; PVD = peripheral vascular disease; RCT = randomized controlled trial