# References

1 American Heart Association. 2002 Heart and Stroke Statistical Update. Dallas, TX: American Heart Association; 2001.
2 Yusuf S, Reddy S, Ounpuu S, et al. Global burden of cardiovascular diseases: part I: general considerations, the epidemiologic transition, risk factors, and impact of urbanization. Circulation. 2001;104(22):2746-53. [pmid: 11723030].
3 Lloyd-Jones D M, Larson M G, Leip E P, et al. Lifetime Risk for Developing Congestive Heart Failure. Circulation. 2002;106:3068-72. [pmid: 12473553].
4 Loscalzo J, Creager MA, Dzau VJ, editors. Vascular Medicine. A textbook of Vascular Biology and Diseases. Boston, MA: Little Brown and Co.; 1992.
5 Duthie G G, Arthur J R, James W P T. Effects of smoking and vitamin E on blood antioxidant status. Am J Clin Nutr. 1991;53:S1061-63.
6 Stamler J, Stamler R, Neaton J D, et al. Low risk-factor profile and long-term cardiovascular and noncardiovascular mortality and life expectancy: findings for 5 large cohorts of young adult and middle-aged men and women. JAMA. 1999;282(21):2012-8. [pmid: 10591383].
7 Stampfer M J, Hu F b, Manson J e, et al. Primary prevention of coronary heart disease in women through diet and lifestyle. New England Journal of Medicine. 2000;343(N1):16-22. [pmid: 10882764].
8 Expert Panel on Detection Evaluation and Treatment of High Blood Cholesterol in Adults. Executive Summary of the Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III). JAMA. 2001;285:2486-97. [pmid: 11368702].
9 The Panel on Dietary Antioxidants and Related Compounds, Food and Nutrition Board, Institute of Medicine. Dietary Reference Intakes for Vitamin C, Vitamin E, Selenium, and Carotenoids. Washington, DC: National Academy Press; 2000.
10 Ternay A, Sorokin V. Redox, radicals and antioxidants. In: Baskin SI, Salem H, editors. Oxidants, Antioxidants, and Free Radicals. Washington, DC: Taylor and Francis; 1997.
11 Krzanowski J J. Oxidants, antioxidants and cardiovascular disease. J Fla Med Assoc. 1991;78(7):435-8. [pmid: 1919497].
12 Duthie G, Bellizzi M C. Effects of antioxidants on vascular health. Br Med Bull. 1999;55(3):568-77. [pmid: 10746347].
13 Jha P, Flather M, Lonn E, et al. The antioxidant vitamins and cardiovascular disease: a critical review of epidemiologic and clinical trial data. Ann Intern Med. 1995;123:860-72. [pmid: 7486470].
14 Diplock A T. Antioxidant nutrients and disease prevention. Am J Clin Nutr. 1991;53:S189-93.
15 Hennekens C H, Gaziano J M. Antioxidants and heart disease: Epidemiology and clinical evidence. Clin Cardiol. 1993;16(4 Suppl):I10-I15. [pmid: 8472392].
16 Maxwell S. Antioxidant vitamin supplements. Update of their potential benefits and possible risks. Drug Safety. 1999;21(4):253-66. [pmid: 10514018].
17 Clifton P M. Antioxidant vitamins and coronary heart disease risk. Curr Opin Lipidology. 1995;6(1):20-4.
18 Asplund K. Antioxidant vitamins in the prevention of cardiovascular disease: a systematic review. J Intern Med. 2002;251(5):372-92. [pmid: 11982737].
19 Tribble D L. Antioxidant consumption and risk of coronary heart disease: Emphasis on vitamin C, vitamin E, and beta-carotene: A statement for healthcare professionals from the American Heart Association. Circulation. 1999;99(4):591-5. [pmid: 9927409].
20 German JB, Traber MG. Nutrients and Oxidation: Actions, Transport, and Metabolism of Dietary Antioxidants. In: Rucker RB, Suttie JW, McCormick DB, et al, editors. Handbook of Vitamins. 3rd ed. ed. New York, NY: Marcel Dekker; 2001.
21 Ervin RB, Wright JD, Kennedy-Stephenson J. Use of dietary supplements in the United States, 1988-94. Vital Health Stat 11 1999; (244):i–iii, 1–14.
22 Kaufman D W, Kelly J P, Rosenberg L, et al. Recent patterns of medication use in the ambulatory adult population of the United States: the Slone survey. JAMA. 2002;287(3):337-44. [pmid: 11790213].
23 Conner M, Kirk S F, Cade J E, et al. Why do women use dietary supplements? The use of the theory of planned behaviour to explore beliefs about their use. Soc Sci Med. 2001;52(4):621-33. [pmid: 11206658].
24 McKenzie J, Keller H H. Vitamin-mineral supplementation and use of herbal preparations among community-living older adults. Can J Public Health. 2001;92(4):286-90. [pmid: 11962114].
25 McGinnis L S. Alternative therapies, 1990. An overview. Cancer. 1991;67(6 Suppl):1788-92. [pmid: 2001579].
26 Frank E, Bendich A, Denniston M. Use of vitamin-mineral supplements by female physicians in the United States. Am J Clin Nutr. 2000;72(4):969-75. [pmid: 11010939].
27 Krauss R M, Eckel R H, Howard B, et al. AHA Dietary Guidelines: revision 2000: A statement for healthcare professionals from the Nutrition Committee of the American Heart Association. Circulation. 2000;102(18):2284-99. [pmid: 11056107].
28 Key T J, Thorogood M, Appleby P N, et al. Dietary habits and mortality in 11,000 vegetarians and health conscious people: results of a 17 year follow up. BMJ. 1996;313(7060):775-9. [pmid: 8842068].
29 de Lorgeril M, Salen P, Martin J C, et al. Mediterranean diet traditional risk factors and the rate of cardiovascular complications after myocardial infarction: final report of the Lyon Diet Heart Study. Circulation. 1999;99:779-85. [pmid: 9989963].
30 Trichopoulou A, Vasilopoulou E, Lagiou A. Mediterranean diet and coronary heart disease: are antioxidants critical?. Nutr Rev. 1999;57(8):253-5. [pmid: 10518412].
31 Strandhagen E, Hansson P O, Bosaeus I, et al. High fruit intake may reduce mortality among middle-aged and elderly men. The Study of Men Born in 1913. Eur J Clin Nutr. 2000;54(4):337-41. [pmid: 10745285].
32 Todd S, Woodward M, Tunstall-Pedoe H, et al. Dietary antioxidant vitamins and fiber in the etiology of cardiovascular disease and all-causes mortality: Results from the Scottish Heart Health Study. Am J Epidemiol. 1999;150(10):1073-80. [pmid: 10568622].
33 Bolton-Smith C, Woodard M, Tunstall-Pedoe H. Dietary intake by food frequency questionnaire and odds ratios for coronary heart disease risk. II. The antioxidant vitamins and fiber. Eur J Clin Nutr. 1992;46:85-93. [pmid: 1313760].
34 Gramenzi A, Gentile A, Fasoli M, et al. Association between certain foods and risk of acute myocardial infarction in women. BMJ. 1990;300(6727):771-3. [pmid: 2322737].
35 Law M R, Morris J K. By how much does fruit and vegetable consumption reduce the risk of ishaemic heart disease. Eur J Clin Nutr. 1998;52:549-56. [pmid: 9725654].
36 Keli S O, Hertog M G, Feskens E J, et al. Dietary flavonoids, antioxidant vitamins, and incidence of stroke: the Zutphen study. Arch Intern Med. 1996;156(6):637-42. [pmid: 8629875].
37 Singh R B, Gosh S, Niaz M A, et al. Dietary intake, plasma levels of antioxidant vitamins, and oxidative stress in relation to coronary artery disease in elderly subjects. Am J Cardiol. 1995;76:1233-38. [pmid: 7503002].
38 Knekt P, Reunanen A, Jarvinen R, et al. Antioxidant vitamin intake and coronary mortality in a longitudinal population study. Am J Epidemiol. 1994;139(12):1180-9. [pmid: 8209876].
39 Gey K F, Moser U K, Jordan P, et al. Increased risk of cardiovascular disease at suboptimal plasma concentrations of essential antioxidants: an epidemiological update with special attention to carotene and vitamin C. Am J Clin Nutr. 1993;57(5 Suppl):787S-97S. [pmid: 8475897].
40 Gale C, Ashurst H, Powers H, et al. Antioxidant vitamin status and carotid atherosclerosis in the elderly. Am J Clin Nutr. 2001;74(3):402-8. [pmid: 11522566].
41 Kritchevsky S B, Shimakawa T, Tell G S, et al. Dietary antioxidants and carotid artery wall thickness. The ARIC Study. Atherosclerosis Risk in Communities Study. Circulation. 1995;92(8):2142-50. [pmid: 7554194].
42 Ascherio A, Rimm E B, Hernan M A, et al. Relation of consumption of vitamin E, vitamin C, and carotenoids to risk for stroke among men in the United States. Ann Intern Med. 1999;130(12):963-70. [pmid: 10383366].
43 Yochum L A, Folsom A R, Kushi L H. Intake of antioxidant vitamins and risk of death from stroke in postmenopausal women. Am J Clin Nutr. 2000;72(2):476. [pmid: 10919944].
44 Kushi L H, Folsom A R, Prineas R J, et al. Dietary antioxidant vitamins and death from coronary heart disease in postmenopausal women. N Engl J Med. 1996;334:1156-62. [pmid: 8602181].
45 Hendler SS, Rovik D, editors. PDR for Nutritional Supplements. Montvale, NJ: Medical Economics Company; 2001.
46 Trout D L. Vitamin C and cardiovascular risk factors. Am J Clin Nutr. 1991;53:322S-5S. [pmid: 1985405].
47 Gey K F. Vitamins E plus C and interacting conutrients required for optimal health. A critical and constructive review of epidemiology and supplementation data regarding cardiovascular disease and cancer. Biofactors. 1998;7(12):113-74. [pmid: 9523035].
48 Niki E. Action of ascorbic acid as a scavenger of active and stable oxygen radicals. Am J Clin Nutr. 1991;54:S1119-24.
49 Baskin SI, Salem H, editors. Oxidants, Antioxidants and Free Radicals. Washington, DC: Taylor and Francis; 1997.
50 Block G, Levine M. Vitamin C: a new look. Ann Intern Med. 1991;114:909-10. [pmid: 2014955].
51 Gey K F, Stahelin H B, Eichholzer M. Poor plasma status of carotene and vitamin C is associated with higher mortality from ischemic heart disease and stroke: Basel Prospective Study. Clin Investig. 1993;71(1):3-6.
52 Ginter E. Decline in coronary mortality in United States and vitamin C. Am J Clin Nutr. 1979;32:511-2. [pmid: 420142].
53 Enstrom J E, Kanim L E, Klein M A. Vitamin C intake and mortality among a sample of the United States population. Epidemiol. 1992;3:194-202.
54 Maxwell S R, Lip G Y. Free radicals and antioxidants in cardiovascular disease. Br J Clin Pharmacol. 1997;44(4):307-17. [pmid: 9354304].
55 Mosca L, Rubenfire M, Mandel C, et al. Antioxidant nutrient supplementation reduces the susceptibility of low density lipoprotein to oxidation in patients with coronary artery disease. J Am Coll Cardiol. 1997;30(2):392-9. [pmid: 9247510].
56 Vogel R. Cholesterol lowering and endothelial function. Am J Med. 1999;107(5):479-87. [pmid: 10569303].
57 Chow C. Vitamin E. In: Rucker RB, Suttie JW, McCormick DB, et al, editors. Handbook of Vitamins. Basel, Switzerland: Marcel Dekker; 2001.
58 Iuliano L, Micheletta F, Maranghi M, et al. Bioavailability of vitamin E as function of food intake in healthy subjects: effects on plasma peroxide-scavenging activity and cholesterol-oxidation products. Arterioscler Thromb Vasc Biol. 2001;21(10):E34-7. [pmid: 11597949].
59 Murphy SP, Subar AF, Block G. Vitamin E intakes and sources in the United States. American Journal of Clinical Nutrition 1990; v52(n2):361(7).
60 Pryor W. Vitamin E and heart disease: Basic science to clinical intervention trials. Free Radic Biol Med. 2000;28(1):141-64. [pmid: 10656300].
61 Rimm E B, Stampfer M J, Ascherio A, et al. Vitamin E consumption and the risk of coronary heart disease in men. N Engl J Med. 1993;328:1450-56. [pmid: 8479464].
62 Stampfer M J, Hennekens C H, Manson J E, et al. Vitamin E consumption and the risk of coronary heart disease in women. N Engl J Med. 1993;328:1444-49. [pmid: 8479463].
63 Pruthi S, Allison T, Hensrud D. Vitamin E supplementation in the prevention of coronary heart disease. Mayo Clin Proc. 2001;76(11):1131-6. [pmid: 11702901].
64 Kleijnen J, Mackerras D. Vitamin E for intermittent claudication. Cochrane Database Syst Rev 2000; (2):CD000987.
65 Kleijnen J, Knipschild P, ter Riet G. Vitamin E and cardiovascular disease. Eur J Clin Pharmacol. 1989;37(6):541-4. [pmid: 2693114].
66 Gey K F, Puska P, Jordan P, et al. Inverse correlation between plasma vitamin E and mortality from ischemic heart disease in cross-cultural epidemiology. Am J Clin Nutr. 1991;53:S326-34.
67 Giugliano D. Dietary antioxidants for cardiovascular prevention. Nutr Metab Cardiovasc Dis. 2000;10(1):38-44. [pmid: 10812586].
68 Upston J M, Terentis A C, Stocker R. Tocopherol-mediated peroxidation of lipoproteins: implications for vitamin E as a potential antiatherogenic supplement. FASEB J. 1999;13:977-94. [pmid: 10336881].
69 Keaney JF, Frei B. Antioxidant protection of low density lipoprotein and its role in the prevention of atherosclerotic vascular disease. In: Frei B, editor. Natural antioxidants in human health and disease. San Diego, CA: Academic Press; 1994. p. 303–51.
70 Kristenson M, Zieden B, Kucinskiene Z, et al. Antioxidant state and mortality form coronary heart disease in Lithuanian and Swedish men: concomitant cross sectional study of men aged 50. BMJ. 1997;314:629-33. [pmid: 9066473].
71 Street D A, Comstock G W, Salkeld R M, et al. Serum antioxidants and myocardial infarction. Are low levels of carotenoids and alpha-tocopherol risk factors for myocardial infarction?. Circulation. 1994;90(3):1154-61. [pmid: 8087925].
72 Suzukawa M, Ayaori M, Shige H, et al. Effect of supplementation with vitamin E on LDL oxidizability and prevention of atherosclerosis. Biofactors. 1998;7(12):51-4. [pmid: 9523028].
73 Steiner M. Vitamin E: More than an antioxidant. Clin Cardiol. 1993;16(4 Suppl):I16-I18. [pmid: 8472393].
74 Crane F L. Biochemical functions of coenzyme Q10. J Am Coll Nutr. 2001;20(6):591-8. [pmid: 11771674].
75 De Pinieux G, Chariot P, Ammi-Said M, et al. Lipid-lowering drugs and mitochondrial function: effects of HMG-CoA reductase inhibitors on serum ubiquinone and blood lactate/pyruvate ratio. Br J Clin Pharmacol. 1996;42(3):333-7. [pmid: 8877024].
76 Watts G F, Castelluccio C, Rice-Evans C, et al. Plasma coenzyme Q (ubiquinone) concentrations in patients treated with simvastatin. J Clin Pathol. 1993;46(11):1055-7. [pmid: 8254097].
77 Ghirlanda G, Oradei A, Manto A, et al. Evidence of plasma CoQ10-lowering effect by HMG-CoA reductase inhibitors: A double-blind, placebo-controlled study. J Clin Pharmacol. 1993;33(3):226-9. [pmid: 8463436].
78 Palomaki A, Malminiemi K, Solakivi T, et al. Ubiquinone supplementation during lovastatin treatment: effect on LDL oxidation ex vivo. J Lipid Res. 1998;39(7):1430-7. [pmid: 9684746].
79 Bargossi A M, Grossi G, Fiorella P L, et al. Exogenous CoQ10 supplementation prevents plasma ubiquinone reduction induced by HMG-CoA reductase inhibitors. Mol Aspects Med. 1994;15(Suppl):s187-93. [pmid: 7752830].
80 Singh R B, Niaz M A, Rastogi V, et al. Coenzyme Q in cardiovascular disease. J Assoc Physicians India. 1998;46(3):299-306. [pmid: 11273351].
81 Folkers K, Vadhanavikit S, Mortensen S A. Biochemical rationale and myocardial tissue data on the effective therapy of cardiomyopathy with coenzyme Q10. Proc Natl Acad Sci U S A. 1985;82(3):901-4. [pmcid: 397155]. [pmid: 3856239].
82 Mortensen S A. Perspectives on therapy of cardiovascular diseases with coenzyme Q10 (ubiquinone). Clin Investig. 1993;71(Suppl 8):S116-23.
83 Crestanello J A, Kamelgard J, Lingle D M, et al. Elucidation of a tripartite mechanism underlying the improvementin cardiac tolerance to ischemia by coenzyme Q10 pretreatment. J Thorac Cardiovasc Surg. 1996;111(2):443-50. [pmid: 8583819].
84 Thomas S R, Neuzil J, Stocker R. Inhibition of LDL oxidation by ubiquinol-10. A protective mechanism for coenzyme Q in atherogenesis?. Mol Aspects Med. 1997;18(Suppl):S85-103. [pmid: 9266510].
85 Hanaki Y, Sugiyama S, Ozawa T, et al. Co-enzyme Q10 and coronary artery disease. Clin Invest. 1993;71:S112-15.
86 Jameson S. Statistical data support prediction of death within 6 months on low levels of coenzyme Q10 and other entities. Clin Investig. 1993;71(8 Suppl):S137-9.
87 Soja A M, Mortensen S A. Treatment of congestive heart failure with coenzyme Q-10 illuminated by meta-analyses of clinical trials. Mol Aspects Med. 1997;18(Supp):s159-68. [pmid: 9266518].
88 Bendich A. Safety issues regarding the use of vitamin supplements. Ann N Y Acad Sci 1992; 669:300–10; discussion 311–2.
89 Bendich A, Machlin L J. Safety of oral intake of vitamin E. Am J Clin Nutr. 1988;48:612-9. [pmid: 3046299].
90 Lockwood K, Moesgaard S, Hanioka T, et al. Apparent partial remission of breast cancer in 'high risk' patients supplemented with nutritional antioxidants, essential fatty acids and coenzyme Q10. Mol Aspects Med. 1994;15(Suppl):s231-40. [pmid: 7752835].
91 Hansten PD, Horn JR. Drug Interactions Analysis and Management. Vancouver, WA: Applied Therapeutics Inc.; 1997.
92 Leppala J M, Virtamo J, Fogelholm R, et al. Controlled trial of alpha-tocopherol and beta-carotene supplements on stroke incidence and mortality in male smokers. Arterioscler Thromb Vasc Biol. 2000;20(1):230-5. [pmid: 10634823].
93 Malila N, Virtamo J, Virtanen M, et al. The effect of alpha-tocopherol and beta-carotene supplementation on colorectal adenomas in middle-aged male smokers. Cancer Epidemiol Biomarkers Prev. 1999;8(6):489-93. [pmid: 10385137].
94 MRC/BHF Heart Protection Study Collaborative group. MRC/BHF Heart Protection Study of antioxidant vitamin supplementation in 20536 high-risk individuals: a randomised placebo-controlled trial. Lancet. 2002;360:23-33. [pmid: 12114037].
95 Jellin JM, Batz F, Hitchens MK, editors. Pharmacist’s Letter/Prescriber’s Letter Natural Medicines Comprehensive Database. Stockton, CA: Therapeutic Research Facility; 2001.
96 Levine M, Rumsey S C, Daruwala R, et al. Criteria and recommendations for vitamin C intake. JAMA. 1999;281(15):1415-23. [pmid: 10217058].
97 Bendich A, Langseth L. The health effects of vitamin C supplementation: a review. J Am Coll Nutr. 1995;14(2):124-36. [pmid: 7790686].
98 Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
99 Schulz K F, Chalmers I, Hayes R J, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
100 Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352(9128):609-13. [pmid: 9746022].
101 Microsoft Excel for Windows 2000 [computer program]. Redmond, WA: Microsoft Corporation; 2000.
102 Stata Statistical Software: Release 6.0, Version 6.0 [computer program]. College Station, TX: Stata Corporation; 1999.
103 Hedges LV, Olkin I. Statistical methods for meta-analysis. San Diego, CA: Academic Press; 1985.
104 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
105 Begg C B, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1994;50(4):1088-101. [pmid: 7786990].
106 Egger M, Davey Smith G, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-34. [pmid: 9310563].
107 Virtamo J, Rapola J M, Ripatti S, et al. Effect of vitamin E and beta carotene on the incidence of primary nonfatal myocardial infarction and fatal coronary heart disease. Arch Intern Med. 1998;158(6):668-75. [pmid: 9521232].
108 Rapola J M, Virtamo J, Ripatti S, et al. Randomised trial of alpha-tocopherol and beta-carotene supplements on incidence of major coronary events in men with previous myocardial infarction. Lancet. 1997;349(9067):1715-20. [pmid: 9193380].
109 Rapola J M, Virtamo J, Ripatti S, et al. Effects of alpha tocopherol and beta carotene supplements on symptoms, progression, and prognosis of angina pectoris. Heart. 1998;79(5):454-8. [pmid: 9659191].
110 Mark S D, Wang W, Fraumeni J F, et al. Do nutritional supplements lower the risk of stroke or hypertension?. Epidemiology. 1998;9:9-15. [pmid: 9430262].
111 de Gaetano G. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. Lancet. 2001;357(9250):89-95. [pmid: 11197445].
112 Yusuf S, Dagenais G, Pogue J, et al. Vitamin E supplementation and cardiovascular events in high-risk patients. The Heart Outcomes Prevention Evaluation Study Investigators. N Engl J Med. 2000;342(3):154-60. [pmid: 10639540].
113 Porkkala-Sarataho EK, Nyyssonen MK, Kaikkonen JE, et al. A randomized, single-blind, placebo-controlled trial of the effects of 200 mg alpha-tocopherol on the oxidation resistance of atherogenic lipoproteins. Am J Clin Nutr 1998; 1034–41.
114 Salonen J T, Nyyssonen K, Salonen R, et al. Antioxidant Supplementation in Atherosclerosis Prevention (ASAP) study: A randomized trial of the effect of vitamins E and C on 3-year progression of carotid atherosclerosis. J Int Med. 2000;248(5):377-86.
115 GISSI-Prevenzione Investigators (Gruppo Italiano per lo Studio della Sopravvianza nell'Infarto Miocardico). Dietary supplementation with n-3 polyunsaturated fatty acids and vitamin E after myocardial infarction: results of the GISSI-Prevenzione trial. Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto miocardico. Lancet. 1999;354(9177):447-55. [pmid: 10465168].
116 Stephens N G, Parsons A, Schofield P M, et al. Randomised controlled trial of vitamin E in patients with coronary disease: Cambridge Heart Antioxidant Study (CHAOS). Lancet. 1996;347(9004):781-6. [pmid: 8622332].
117 Brown B G, Xue-Qiao Z, Chait A, et al. Simvastatin and niacin, antioxidant vitamins, or the combination for the prevention of coronary disease. N Engl J Med. 2001;345(22):1583-92. [pmid: 11757504].
118 Tardif J C, Cote G, Lesperance J, et al. Probucol and multivitamins in the prevention of restenosis after coronary angioplasty. Multivitamins and Probucol Study Group. N Engl J Med. 1997;337(6):365-72. [pmid: 9241125].
119 Boaz M, Smetana S, Weinstein T, et al. Secondary prevention with antioxidants of cardiovascular disease in endstage renal disease (SPACE): Randomised placebo-controlled trial. Lancet. 2000;356(9237):1213-8. [pmid: 11072938].
120 Gillilan R E, Mondell B, Warbasse J R. Quantitative evaluation of vitamin E in the treatment of angina pectoris. Am Heart J. 1977;93(4):444-9. [pmid: 320856].
121 Ness A, Smith G D. Mortality in the CHAOS trial. Cambridge Heart Antioxidant Study. Lancet. 1999;353(9157):1017-8. [pmid: 10459945].
122 Singh R B, Niaz M A, Rastogi S S, et al. Usefulness of antioxidant vitamins in suspected acute myocardial infarction (the Indian experiment of infarct survival-3). Am J Cardiol. 1996;77(4):232-6. [pmid: 8607399].
123 Hofman-Bang C, Rehnqvist N, Swedberg K, et al. Coenzyme Q10 as an adjunctive in the treatment of chronic congestive heart failure. The Q10 Study Group. J Card Fail. 1995;1(2):101-7. [pmid: 9420639].
124 Khatta M, Alexander B S, Krichten C M, et al. The effect of coenzyme Q10 in patients with congestive heart failure. Ann Intern Med. 2000;132(8):636-40. [pmid: 10766682].
125 Leppala J M, Virtamo J, Fogelholm R, et al. Vitamin E and beta carotene supplementation in high risk for stroke: a subgroup analysis of the Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study. Arch Neurol. 2000;57(10):1503-9. [pmid: 11030804].
126 Steiner M, Glantz M, Lekos A. Vitamin E plus aspirin compared with aspirin alone in patients with transient ischemic attacks. Am J Clin Nutr. 1995;62(6 Suppl):1381S-4S. [pmid: 7495235].
127 Tornwall M E, Virtamo J, Haukka J K, et al. Alpha-tocopherol (vitamin E) and beta-carotene supplementation does not affect the risk for large abdominal aortic aneurysm in a controlled trial. Atherosclerosis. 2001;157(1):167-73. [pmid: 11427217].
128 Di Somma S, Carati L. Efficacy of coenzyme Q10 in association with conventional therapy in the treatment of heart failure and ischemic heart disease. In: Folkers K, Yamamura Y, editors. Biomedical and Clincal Aspects of Coenzyme Q10. Amsterdam: Elsevier; 1991. p. 257–65.
129 Rapola J M, Virtamo J, Ripatti S, et al. Effects of vitamin E and beta-carotene supplementation on the incidence of major coronary events in men with previous myocardial infarction. Eur Heart. 1997;18(Abstr. Suppl):251.
130 Stollerman G H. Vitamin E, coronary artery disease, and CHAOS. Hosp Pract (Off Ed). 1996;31(6):21-2.
131 Haeger K. The treatment of peripheral occlusive arterial disease with alpha-tocopherol as compared with vasodilator agents and antiprothrombin (dicumarol). Vasc Dis. 1968;5(4):199-213. [pmid: 4177853].
132 Haeger K. Letter: Vitamin E in intermittent claudication. Lancet. 1974;1(7870):1352. [pmid: 4134338].
133 Waters D D, Alderman E L, Hsia J, et al. Effects of hormone replacement therapy and antioxidant vitamin supplements on coronary atherosclerosis in postmenopausal women: a randomized controlled trial. JAMA. 2002;288(19):2432-40. [pmid: 12435256].
134 Takamatsu S, Takamatsu M, Satoh K, et al. Effects on health of dietary supplementation with 100 mg d-alpha-tocopheryl acetate, daily for 6 years. J Int Med Res. 1995;23(5):342-57. [pmid: 8529777].
135 Kuklinski B, Weissenbacher E, Fahnrich A. Coenzyme Q10 and antioxidants in acute myocardial infarction. Mol Aspects Med. 1994;15(Suppl):s143-7. [pmid: 7752825].
136 Sisto T, Paajanen H, Metsa-Ketela T, et al. Pretreatment with antioxidants and allopurinol diminishes cardiac onset events in coronary artery bypass grafting. Ann Thorac Surg. 1995;59(6):1519-23. [pmid: 7771834].
137 Singh R B, Wander G S, Rastogi A, et al. Randomized, double-blind placebo-controlled trial of coenzyme Q10 in patients with acute myocardial infarction. Cardiovasc Drugs Ther. 1998;12(4):347-53. [pmid: 9825179].
138 Kaikkonen J, Kosonen L, Nyyssonen K, et al. Effect of combined coenzyme Q10 and d-alpha-tocopheryl acetate supplementation on exercised-induced lipid peroxidation and muscular damage: a placebo-controlled double-blind study in marathon runners. Free Radic Res. 1998;13:1528-33.
139 Wen Y, Cooke T, Feely J. The effect of pharmacological supplementation with vitamin C on low-density lipoprotein oxidation. Br J Clin Pharmacol. 1997;44:94-7. [pmid: 9241103].
140 Porkkala-Sarataho E, Salonen J T, Nyyssonen K, et al. Long-term effects of vitamin E, vitamin C, and combined supplementation on urinary 7-hydro-8-oxo-2'-deoxyguanosine, serum cholesterol oxidation products, and oxidation resistance of lipids in nondepleted men. Arterioscler Thromb Vasc Biol. 2000;20(9):2087-93. [pmid: 10978253].
141 Raitakari O T, McCredie R J, Witting P, et al. Coenzyme Q improves LDL resistance to ex vivo oxidation but does not enhance endothelial function in hypercholesterolemic young adults. Free Radic Biol Med. 2000a;28(7):1100-5. [pmid: 10832071].
142 Iino K, Abe K, Kariya S, et al. A controlled, double-blind study of dl-alpha-tocopheryl nicotinate (Juvela-Nicotinate) for treatment of symptoms in hypertension and cerebral arteriosclerosis. Jpn Heart J. 1977;18(3):277-83. [pmid: 881743].
143 O'Byrne D, Grundy S, Packer L, et al. Studies of LDL oxidation following alpha-, gamma-, or delta-tocotrienyl acetate supplementation of hypercholesterolemic humans. Free Radic Biol Med. 2000;29(9):834-45. [pmid: 11063909].
144 Samman S, Brown A J, Beltran C, et al. The effect of ascorbic acid on plasma lipids and oxidisability of LDL in male smokers. Eur J Clin Nutr. 1997;51:472-7. [pmid: 9234031].
145 Gatto L M, Hallen G K, Brown A J, et al. Ascorbic acid induces favorable lipoprotein profile in women. J Am Coll Nutr. 1996;15:154-8. [pmid: 8778145].
146 Nyyssonen K, Poulsen H E, Hayn M, et al. Effect of supplementation of smoking men with plain or slow release ascorbic acid on lipoprotein oxidation. Eur J Clin Nutr. 1997;51:154-63. [pmid: 9076405].
147 Nappo F, De Rosa N, Marfella R, et al. Impairment of endothelial functions by acute hyperhomocysteinemia and reversal by antioxidant vitamins. JAMA. 1999;281(22):2113-8. [pmid: 10367822].
148 Lankin V Z, Tikhaze A K, Kaminnaya V I, et al. In vivo intensification of free-radical oxidation of low-density lipoproteins in the plasma of patients with coronary heart disease treated with beta-hydroxy-beta-methylglutaryl coenzyme A reductase inhibitor pravastatin and inhibition of lipid peroxidation with ubiquinone Q10. Bull Exp Biol Med. 2000;129(2):151-4.
149 Singh R B, Niaz M A. Serum concentration of lipoprotein(a) decreases on treatment with hydrosoluble coenzyme Q10 in patients with coronary artery disease: discovery of a new role. Int J Cardiol. 1999a;68(1):23-9. [pmid: 10077397].
150 Singh R B, Niaz M A, Rastogi S S, et al. Effect of hydrosoluble coenzyme Q10 on blood pressures and insulin resistance in hypertensive patients with coronary artery disease. J Hum Hypertens. 1999b;13(3):203-8. [pmid: 10204818].
151 Kaikkonen J, Nyyssonen K, Tomasi A, et al. Antioxidative efficacy of parallel and combined supplementation with coenzyme Q10 and d-alpha-tocopherol in mildly hypercholesterolemic subjects: a randomized placebo-controlled clinical study. Free Radic Res. 2000;33(3):329-40. [pmid: 10993487].
152 Anderson J W, Gowri M S, Turner J, et al. Antioxidant supplementation effects on low-density lipoprotein oxidation for individuals with type 2 diabetes mellitus. J Am Coll Nutr. 1999;18(5):451-61. [pmid: 10511327].
153 Osilesi O D, Trout L, Ogunwole J O, et al. Blood pressure and plasma lipids during ascorbic acid supplementation in borderline hypertensive and normotensive adults. Nutr Res. 1991;11:405-12.
154 Guetta V, Panza J A, Waclawiw M A, et al. Effect of combined 17 beta-estradiol and vitamin E on low-density lipoprotein oxidation in postmenopausal women. Am J Cardiol. 1995;75(17):1274-6. [pmid: 7778557].
155 Inal M, Sunal E, Kanbak G, et al. Effects of postmenopausal hormone replacement and alpha-tocopherol on the lipid profiles and antioxidant status. Clin Chim Acta. 1997;268(12):21-9. [pmid: 9495568].
156 Mensink RP, Houwelingen ACv, Kromhout D, et al. A vitamin E concentrate rich in tocotrienols had no effect on serum lipids, lipoproteins, or platelet function in men with mildly elevated serum lipid concentrations. Am J Clin Nutr 1999; 69(2):213(1).
157 Reaven P D, Witztum J L. Comparison of supplementation of RRR-alpha-tocopherol and racemic alpha-tocopherol in humans: effects on lipid levels and lipoprotein susceptibility to oxidation. Arterioscl Thromb. 1993;13:601-8. [pmid: 8466895].
158 Qureshi A A, Bradlow B A, Brace L, et al. Response of hypercholesterolemic subjects to administration of tocotrienols. Lipids. 1995;30(12):1171-7. [pmid: 8614309].
159 Munday J S, James K A, Fray L M, et al. Daily supplementation with aged garlic extract, but not raw garlic, protects low density lipoprotein against in vitro oxidation. Atherosclerosis. 1999;143(2):399-404. [pmid: 10217370].
160 Singhal S, Gupta R, Goyle A. Comparison of antioxidant efficacy of vitamin E, vitamin C, vitamin A and fruits in coronary heart disease: a controlled trial. J Assoc Physicians India. 2001;49:327-31. [pmid: 11291971].
161 Tsai A, Kelly J, Peng B, et al. Study on the effect of megavitamin E supplementation in man. Am J Clin Nutr. 1978;31:831-7. [pmid: 347918].
162 Dieber-Rotheneder M, Puhl H, Waeg G, et al. Effect of oral supplementation with D-alpha-tocopherol on the vitamin E content of human low density lipoproteins and resistance to oxidation. J Lipid Res. 1991;32:1325-32. [pmid: 1770314].
163 Harats D, Ben-Naim M, Dabach Y, et al. Effect of vitamin C and E supplementation on susceptibility of plasma lipproteins to peroxidation induced by acute smoking. Atherosclerosis. 1990;85:47-54. [pmid: 2282108].
164 Meraji S, Ziouzenkova O, Resch U, et al. Enhanced plasma level of lipid peroxidation in Iranians could be improved by antioxidants supplementation. Eur J Clin Nutr. 1997;51(5):318-25. [pmid: 9152683].
165 Raitakari O, Adams M R, McCredie R J, et al. Oral vitamin C and endothelial function in smokers: Short-term improvement, but no sustained beneficial effect. J Am Coll Cardiol. 2000b;35(6):1616-21. [pmid: 10807468].
166 Wen Y, Killalea S, Norris L A, et al. Vitamin E supplementation in hyperlipidaemic patients: effect of increasing doses on in vitro and in vivo low-density lipoprotein oxidation. Eur J Clin Invest. 1999;29(12):1027-34. [pmid: 10583450].
167 Brown K M, Morrice P C, Duthie G G. Vitamin E supplementation suppresses indexes of lipid peroxidation and platelet counts in blood of smokers and nonsmokers but plasma lipoprotein concentrations remain unchanged. Am J Clin Nutr. 1994;60(3):383-7. [pmid: 8074069].
168 De Waart F J, Moser U, Kok F J. Vitamin E supplementation in elderly lowers the oxidation rate of linoleic acid in LDL. Atherosclerosis. 1997;133:255-63. [pmid: 9298686].
169 DeMaio S J, King S B 3, Lembo N J, et al. Vitamin E supplementation, plasma lipids and incidence of restenosis after percutaneous transluminal coronary angioplasty (PTCA). J Am Coll Nutr. 1992;11(1):68-73. [pmid: 1541798].
170 Fuller C J, Chandalia M, Garg A, et al. RRR-alpha-tocopheryl acetate supplementation at pharmacologic doses decreases low-density-lipoprotein oxidative susceptibility but not protein glycation in patients with diabetes mellitus. Am J Clin Nutr. 1996b;63(5):753-9.
171 Hoffman R M, Garewal H S. Alpha-tocopherol supplementation for men with existing coronary artery disease: a feasibility study. Prev Med. 1999;29(2):112-8. [pmid: 10446037].
172 Jain S K, McVie R, Jaramillo J J, et al. The effect of modest vitamin E supplementation on lipid peroxidation products and other cardiovascular risk factors in diabetic patients. Lipids. 1996;31(Suppl):S87-90. [pmid: 8729100].
173 Jialal I, Fuller C J, Huet B A. The effect of alpha-tocopherol supplementation on LDL oxidation: a dose response study. Arterioscler Thromb Vasc Biol. 1995;15:190-98. [pmid: 7749825].
174 Jialal I, Grundy S M. Effect of dietary supplementation with alpha-tocopherol on the oxidative modification of low density lipoprotein. J Lipid Res. 1992;33:899-906. [pmid: 1512513].
175 Jialal I, Grundy S M. Effect of combined supplementation with alpha-tocopherol, ascorbate, and beta carotene on low-density lipoprotein oxidation. Circulation. 1993;88(6):2780-6. [pmid: 8252691].
176 McDowell I, Brennan G, McEneny J. The effect of probucol and vitamin E treatment on the oxidation of low-density lipoprotein and forearm vascular responses in humans. Eur J Clin Invest. 1994;24:759-65. [pmid: 7890014].
177 McGavin J K, Mann J I, Skeaff C M, et al. Comparison of a vitamin E-rich diet and supplemental vitamin E on measures of vitamin E status and lipoprotein profile. Eur J Clin Nutr. 2001;55(7):555-61. [pmid: 11464229].
178 Mottram P, Shige H, Nestel P. Vitamin E improves arterial compliance in middle-aged men and women. Atherosclerosis. 1999;145(2):399-404. [pmid: 10488969].
179 Nyyssonen K, Porkkala E, Salonen R, et al. Increase in oxidation resistance of atherogenic serum lipoproteins followign antioxidant supplementation: a randomized double-blind placebo-controlled trial. Eur J Clin Nutr. 1997;48:633-42. [pmid: 8001520].
180 Paolisso G, Gambardella A, Giugliano D, et al. Chronic intake of pharmacological doses of vitamin E might be useful in the therapy of elderly patients with coronary heart disease. Am J Clin Nutr. 1995;61(4):848-52. [pmid: 7702030].
181 Schafer L, Thorling E B. Lipid peroxidation and antioxidant supplementation in old age. Scand J Clin Lab Invest. 1990;50(1):69-75. [pmid: 2315645].
182 Stampfer M J, Willett W, Castelli W P, et al. Effect of vitamin E on lipids. Am J Clin Pathol. 1983;79(6):714-6. [pmid: 6342362].
183 Tomeo A C, Geller M, Watkins T R, et al. Antioxidant effects of tocotrienols in patients with hyperlipidemia and carotid stenosis. Lipids. 1995;30(12):1179-83. [pmid: 8614310].
184 de Lorgeril M, Boissonnat P, Salen P, et al. The beneficial effect of dietary antioxidant supplementation on platelet aggregation and cyclosporine treatment in heart transplant recipients. Transplantation. 1994;58(2):193-5. [pmid: 8042237].
185 Okamura T, Sunamori M, Amano J, et al. Significant myocardial protection by coenzyme Q10 in coronary bypass surgery. J Mol Cell Cardiol. 1983;15(Suppl 1):276.
186 Tanaka J, Tominaga R, Yoshitoshi M, et al. Coenzyme Q10: the prophylactic effect on low cardiac output following cardiac valve replacement. Ann Thorac Surg. 1982;33(2):145-51. [pmid: 7039533].
187 Judy W V, Stogsdill W W, Folkers K. Myocardial preservation by therapy with coenzyme Q10 during heart surgery. Clin Investig. 1993;71(8 Suppl):S155-61.
188 Chen Y F, Lin Y T, Wu S C. Effectiveness of coenzyme Q10 on myocardial preservation during hypothermic cardioplegic arrest. J Thorac Cardiovasc Surg. 1994;107(1):242-7. [pmid: 8283892].
189 Chello M, Mastroroberto P, Romano R, et al. Protection by coenzyme Q10 from myocardial reperfusion injury during coronary artery bypass grafting. Ann Thorac Surg. 1994;58(5):1427-32. [pmid: 7979670].
190 Taggart D P, Jenkins M, Hooper J, et al. Effects of short-term supplementation with coenzyme Q10 on myocardial protection during cardiac operations. Ann Thorac Surg. 1996;61(3):829-33. [pmid: 8619701].
191 Chello M, Mastroroberto P, Romano R, et al. Protection by coenzyme Q10 of tissue reperfusion injury during abdominal aortic cross-clamping. J Cardiovasc Surg (Torino). 1996;37(3):229-35.
192 Morisco C, Trimarco B, Condorelli M. Effect of coenzyme q10 therapy in patients with congestive heart failure: a long-term multicenter randomized study. Clin Investig. 1993;71(supp):s134-36.
193 Watson P S, Scalia G M, Galbraith A, et al. Lack of effect of coenzyme Q on left ventricular function in patients with congestive heart failure. J Am Coll Cardiol. 1999;33(6):1549-52. [pmid: 10334422].
194 Grady D, Herrington D, Bittner V, et al. Cardiovascular disease outcomes during 6.8 years of hormone therapy: Heart and Estrogen/progestin Replacement Study follow-up (HERS II). JAMA. 2002;288(1):49-57. [pmid: 12090862].
195 Major outcomes in high-risk hypertensive patients randomized to angiotensin-converting enzyme inhibitor or calcium channel blocker vs diuretic: The Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). JAMA 2002; 288(23): 2981–97.