# Appendix B Search Methodology

## SEARCH #1 (PERFORMED 11/16/01)

### DATABASES SEARCHED/TIME PERIOD COVERED

MEDLINE | 1966-2001/Dec W2
MANTIS | 1880-2001/Aug
Allied & Complementary Medicine | 1984-2001/Dec
Cancerlit | 1975-2001/Oct
CAB HEALTH | 1983-2001/Oct
TGG Health&Wellness DB | 1976-2001/Nov W1
Biosis Previews | 1969-2001/Nov W2
EMBASE | 1974-2001/Nov W2
Social SciSearch | 1972-2001/Nov W3
SciSearch Cited Ref Sci | 1990-2001/Nov W3
SciSearch Cited Ref Sci | 1974-1989/Dec
ELSEVIER BIOBASE | 1994-2001/Nov W2

### SEARCH STRATEGY

ubiquinone OR ubidecarenone OR coenzyme q10 OR co-enzyme q10 OR coenzyme q 10 OR co-enzyme q 10 OR coenzyme q-10 OR co-enzyme q-10

AND

cardiovascular diseases(exploded) from Medline,CancerLit

OR cardiovascular disease(exploded) from EMBASE

OR cardiovascular disease* OR coronary artery disease*

OR coronary atherosclerosis OR heart disease*

OR congestive heart failure OR myocardial OR coronary ischemia

OR acute coronary syndrome OR coronary plaque OR heart plaque

OR arter* plaque

AND

(prevention OR preventive OR therapy OR therapeutic OR treatment) in title,subject heading fields

AND

Human

NOT

(cell OR cells) in subject heading field

TOTAL NUMBER OF ITEMS RETRIEVED: 582

## SEARCH #2a (PERFORMED 11/27/01)

### DATABASES SEARCHED/TIME PERIOD COVERED

MEDLINE | 1966-2001/Dec W4
MANTIS | 1880-2001/Aug
Allied & Complementary Medicine | 1984-2001/Dec
Cancerlit | 1975-2001/Oct
CAB HEALTH | 1983-2001/Oct
TGG Health&Wellness DB | 1976-2001/Nov W2
Biosis Previews | 1969-2001/Nov W3
EMBASE | 1974-2001/Nov W3
Social SciSearch | 1972-2001/Nov W4
SciSearch Cited Ref Sci | 1990-2001/Nov W4
SciSearch Cited Ref Sci | 1974-1989/Dec
ELSEVIER BIOBASE | 1994-2001/Nov W4

### SEARCH STRATEGY

ascorbic acid(exploded)from Medline, Embase OR ascorbic acid OR

dehydroascorbic acid* OR ascorbate OR vitamin c OR antiscorbutic vitamin*

OR cevitamic acid*

AND

cardiovascular diseases(exploded) from Medline,CancerLit

OR cardiovascular disease(exploded) from EMBASE

OR cardiovascular disease* OR coronary artery disease*

OR coronary atherosclerosis OR heart disease*

OR congestive heart failure OR myocardial OR coronary ischemia

OR acute coronary syndrome OR coronary plaque OR heart plaque

OR arter* plaque

AND

(prevention OR preventive OR therapy OR therapeutic OR treatment) in title,subject heading fields

AND

human

NOT

(cell OR cells) in subject heading field

TOTAL NUMBER OF ITEMS RETRIEVED: 2228 [NOTE: NOT ALL DUPLICATE RECORDS WERE DELETED FROM THESE RESULTS - RS]

## SEARCH #2b (PERFORMED 11/7/01)

### DATABASES SEARCHED

Cochrane Library

### SEARCH STRATEGY

vitamin c OR ascorbic acid OR ascorbate OR antiscorbutic vitamin OR cevitamic acid OR dehydroascorbic acid

AND

cardiovascular diseases(exploded)

TOTAL NUMBER OF ITEMS RETRIEVED:

The Cochrane Database of Systematic Reviews

Complete reviews - 11

Database of Abstracts of Reviews of Effectiveness

Abstracts of quality assessed systematic reviews - 3

The Cochrane Controlled Trials Register (CENTRAL/CCTR)

References - 155

## SEARCH #3a (PERFORMED 12/4/01)

### DATABASES SEARCHED/TIME PERIOD COVERED

MEDLINE | 1966-2001/Dec W5
MANTIS | 1880-2001/Aug
Allied & Complementary Medicine | 1984-2001/Jan
Cancerlit | 1975-2001/Oct
CAB HEALTH | 1983-2001/Oct
TGG Health&Wellness DB | 1976-2001/Nov W3
Biosis Previews | 1969-2001/Nov W4
EMBASE | 1974-2001/Nov W4
Social SciSearch | 1972-2001/Dec W1
SciSearch Cited Ref Sci | 1990-2001/Dec W1
SciSearch Cited Ref Sci | 1974-1989/Dec
ELSEVIER BIOBASE | 1994-2001/Dec W1

### SEARCH STRATEGY

vitamin e (exploded) from Medline OR vitamin e OR alpha tocopherol* OR d1 alpha tocopherol* OR d alpha tocopherol OR rrr alpha tocopherol* OR all rac alpha tocopherol*

AND

cardiovascular diseases(exploded) from Medline,CancerLit

OR cardiovascular disease(exploded) from EMBASE

OR cardiovascular disease* OR coronary artery disease*

OR coronary atherosclerosis OR heart disease*

OR congestive heart failure OR myocardial OR coronary ischemia

OR acute coronary syndrome OR coronary plaque OR heart plaque

OR arter* plaque

AND

(prevention OR preventive OR therapy OR therapeutic OR treatment) in title,subject heading fields

AND

human

TOTAL NUMBER OF ITEMS RETRIEVED: 3578

## SEARCH #3b (PERFORMED 12/19/01)

### DATABASES SEARCHED/TIME PERIOD COVERED

Cochrane Library | 1922-2001

### SEARCH STRATEGY

vitamin-e

AND

cardiovascular diseases(exploded) OR coronary

OR heart OR myocardial

TOTAL NUMBER OF ITEMS RETRIEVED:

The Cochrane Database of Systematic Reviews - Complete reviews: 1

Database of Abstracts of Reviews of Effectiveness

Abstracts of quality assessed systematic reviews: 1

Other reviews: bibliographic details only: 3

The Cochrane Controlled Trials Register (CENTRAL/CCTR) - References: 187

## SEARCH #4 (PERFORMED 1/25/02)

### DATABASES SEARCHED/TIME PERIOD COVERED

MEDLINE | 1966-2002/JAN W3
MANTIS | 1880-2001/Oct
Allied & Complementary Medicine | 1984-2002/Feb
Cancerlit | 1975-2001/Oct
CAB HEALTH | 1983-2001/Dec
TGG Health&Wellness DB | 1976-2002/Jan W1
Biosis Previews | 1969-2002/Jan W3
EMBASE | 1974-2002/Jan W3
Social SciSearch | 1972-2002/Jan W4
SciSearch Cited Ref Sci | 1990-2002/Jan W4
SciSearch Cited Ref Sci | 1974-1989/Dec
ELSEVIER BIOBASE | 1994-2002/Jan W3

### SEARCH STRATEGY

ubidecarenon* OR isoprostane* OR f2 isoprostane*

AND

cardiovascular diseases (exploded) from Medline, CancerLit, Embase OR cardiovascular disease* OR coronary artery disease* OR coronary atherosclerosis OR heart disease* OR congestive heart failure OR myocardial OR coronary ischemia OR acute coronary syndrome OR coronary plaque OR heart plaque OR arter* plaque

AND

Human

NOT

(coenzyme OR co enzyme) within 2 words of (q10 or q 10)

TOTAL NUMBER OF ITEMS RETRIEVED: 503

## SEARCH #5 PERFORMED 11/7/01

### DATABASE SEARCHED

Cochrane Library

### SEARCH STRATEGY

coenzyme q10 or coenzyme q 10 OR co enzyme q10 OR co enzyme q 10 OR co q10 OR co q 10 OR ubiquinone

TOTAL NUMBER OF ITEMS RETRIEVED:

The Cochrane Database of Systematic Reviews - Complete reviews - 1

The Cochrane Controlled Trials Register (CENTRAL/CCTR) References - 110