# Appendix A Acknowledgments

Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

David Atkins, MD

Chief Medical Officer

Agency for Healthcare Research and Quality

Rockville, MD

Jeffrey Bland, M.D.

Institute for Functional Medicine

Gig Harbor, WA

Jeffrey Blumberg, PhD, FACN, CNS

Nutrition Research Center on Aging

Tufts University

Boston, MA

Julie Buring, ScD

Brigham and Women's Hospital

Harvard Medical School

Boston, MA

Rebecca Costello, PhD

Office of Dietary Supplements

National Institutes of Health

Bethesda, MD

David Golde, MD

Memorial Sloan-Kettering Cancer Center

New York, NY

Charles Hennekens, MD, FACC

School of Medicine

University of Miami

Boca Raton, FL

Martin Kendall, MD, FRCP

Department of Medicine

University of Birmingham

Birmingham, United Kingdom

Michael Rich, MD

Cardiovascular Division,

Washington University School of Medicine

St. Louis, MO

Melvyn Rubenfire, MD

Preventive Cardiology

University of Michigan

Ann Arbor, MI

Alex Sevanian, MD

Department of Molecular Pharmacology and Toxicology

University of Southern California

Los Angeles, CA

Technical Expert Panel

We wish to acknowledge the work of our technical expert panel:

Betty L. Chang, DNSc, FNP-C, FAAN

Professor, School of Nursing

University of California, Los Angeles

Los Angeles, CA

Seigward-Markus Elsas, MD

Clinical Fellow in Neurophysiology

University of California, Los Angeles

Los Angeles, CA

Glenn Clark, DDS

School of Dentistry

University of California, Los Angeles

Los Angeles, CA

Deborah Glik, Ph.D.

Associate Professor, School of Public Health

University of California, Los Angeles

Los Angeles, CA

Michael Goldstein, PhD

Professor, School of Public Health

University of California, Los Angeles

Los Angeles, CA

Eric Hurwitz, DC, PhD

Assistant Professor, Department of Epidemiology,

School of Public Health, University of California

Los Angeles, CA

Ka Kit Hui, MD, FACP

Director, UCLA Center for East-West Medicine

University of California

Los Angeles, CA

Simon Mills, MA, MCPP, FNIMH

Director for the Center of Complementary Medicine

University of Exeter

Exeter, England

Lakshmi C. Mishra, BIMS, M Pharm, PhD

Professor of Research

Southern California University of Health Science

Whittier, CA

Shri K. Mishra, MD, MS, Doctor of Ayurveda

Professor of Neurology and Coordinator Integrative Medicine

USC School of Medicine

USC Keck School of Medicine

Los Angeles, CA

Lucy Postolov, LAc

Postolova Acupuncture Group

Los Angeles, CA

David Riley, MD

Clinical Associate Professor

University of North West Medical School,

Director, Integrative Medicine Research

Santa Fe, NM

Betsy B. Singh, PhD

Dean of Research

Southern California University of Health Sciences

Whittier, CA

George Solomon, MD

Professor Emeritus, UCLA School of Medicine,

Dept. of Psychiatry and Biobehavioral Medicine

University of California

Los Angeles, CA

Hitoshi Tomizawa, MD

Director, Japanese Executive Medical Services,

Cedars-Sinai Medical Center

Los Angeles, CA

Xiao-Ping Xu, LAc

Burns and Allen Research Institute

Cedars Sinai Medical Center

Los Angeles CA