# Evidence Tables

Evidence Table 1. ACE Inhibitor-Accepted Articles

Author, Date | Drug Studied | Sample | Followup | Data reported for specific subpop/comorb | Data may be at patient level for specific subpop/ comorb | Study name
| CHF Defined
| Study population
(Pitt B, 1992) | enalapril | 6797 | NR | NR | Black patients | SOLVD
| Systolic dysfunction | | | | Very old (Age 80+) patients
| Both sympt and asympt patients | | | | Nursing home patients
(Yusuf S, 1992) | enalapril | 4228 | NR | Diabetic patients | Black patients | SOLVD
| Systolic dysfunction | | | | Female patients
| Post MI and reduced LVEF
(The SOLVD Investigators, 1991) | enalapril | 2569 | NR | NR | Black patients | SOLVD
| Systolic dysfunction | | | | Diabetic patients
| Symptomatic patients
(Moye LA, 1994) | captopril | 2231 | 2 yr | Black patients | No subpopulations | SAVE
| Systolic dysfunction | | | Female patients
| Asymptomatic patients | | | Diabetic patients
(Pfeffer MA, 1992) | captopril | 2231 | NR | NR | Very old (Age 80+) patients | SAVE
| Systolic dysfunction | | | | Female patients
| Post MI and reduced LVEF | | | | Diabetic patients
(Ball SG, 1993) | ramipril | 2006 | NR | NR | Female patients | AIRE
| CHF unspecified | | | | Diabetic patients
| Symptomatic patients
(Cleland JG, 1997) | ramipril | 2006 | NR | NR | No subpopulations | AIRE
| CHF unspecified
| Symptomatic patients
(Exner DV, 2000) | enalapril | 1996 | NR | Black patients | NR | SOLVD
| Systolic dysfunction
| Symptomatic patients
(Exner DV, 2001) | enalapril | 1996 | NR | Black patients | No subpopulations | SOLVD
| Systolic dysfunction
| Both sympt and asympt patients
(Kober L, 1995) | trandolapril | 1749 | NR | NR | Very old (Age 80+) patients | TRACE
| Systolic dysfunction | | | | Female patients
| Symptomatic patients | | | | Diabetic patients
(Torp-Pedersen C, 1996) | trandolapril | 1749 | NR | Diabetic patients | Female patients | TRACE
| Systolic dysfunction | | | Renal failure patients
| Symptomatic patients
(Ambrosioni E, 1995) | zofenopril | 1556 | NR | Diabetic patients | Female patients | SMILE
| Systolic dysfunction | | | | None
| Asymptomatic patients
(Hall AS, 1997) | ramipril | 603 | NR | NR | Female patients | AIRE
| CHF unspecified | | | | Diabetic patients
| Symptomatic patients
(Bulpitt CJ, 1998) | captopril, cilazapril | 367 | 12 wk | NR | Very old (Age 80+) patients | Cilazapril/Captopril Multicentre Group
| CHF unspecified | | | | Female patients
| Symptomatic patients
(Captopril-Digoxin Multicenter Research Group, 1988) | captopril | 300 | 6 mo | NR | Very old (Age 80+) patients | Captopril-Digoxin Multicenter Research Group
| Systolic dysfunction | | | | Female patients
| Symptomatic patients
(Swedberg K, 1999) | enalapril | 253 | NR | NR | Female patients | CONSENSUS
| Systolic dysfunction
| Symptomatic patients
(Kjekshus J, 1989) | enalapril | 253 | NR | Renal failure patients | Very old (Age 80+) patients | CONSENSUS
| Systolic dysfunction | | | | Female patients
| Symptomatic patients | | | | Diabetic patients
(CONSENSUS, 1987) | enalapril | 253 | NR | NR | Female patients | CONSENSUS
| CHF unspecified | | | | Diabetic patients
| Symptomatic patients
(Jerie P, 1997) | spirapril | 248 | 12 wk | NR | Female patients | CASSIS
| CHF unspecified
| Symptomatic patients
(Widimsky J, 1995) | spirapril | 248 | 12 wk | NR | Female patients | CASSIS
| Systolic dysfunction | | | | Diabetic patients
| Symptomatic patients
(van Veldhuisen DJ, 1998) | imidapril | 244 | 12 wk | NR | Female patients
| Systolic dysfunction
| Symptomatic patients
(Brown EJ Jr, 1995) | fosinopril | 241 | 24 wk | NR | Black patients | Fosinopril Heart Failure Study Group
| Systolic dysfunction | | | | Female patients
| Symptomatic patients
(Gustafsson I, 1999) | trandolapril | 237 | NR | Diabetic patients | Female patients | TRACE
| Systolic dysfunction
| Symptomatic patients
(Pflugfelder PW, 1993) | quinapril | 224 | 16 wk | NR | Female patients
| Systolic dysfunction
| Symptomatic patients
(Gundersen T, 1995) | ramipril | 223 | 12 wk | NR | Female patients | Ramipril Multicentre Study
| Systolic dysfunction
| Symptomatic patients
(Giles TD, 1990) | lisinopril | 193 | 12 wk | NR | No subpopulations | lisinopril HF group
| CHF unspecified
| Symptomatic patients
(Kleber FX, 1992) | captopril | 170 | NR | NR | Female patients | Munich Mild Heart Failure
| CHF unspecified
| Symptomatic patients
(Ghose JC, 1993) | captopril | 153 | 6 mo | Other | Female patients
| CHF unspecified
| Symptomatic patients
(Barabino A, 1991) | captopril | 150 | NR mo | Nursing home | Very old (Age 80+) patients
| CHF unspecified | | | | Nursing home patients
| Symptomatic patients
(Chalmers JP, 1987) | lisinopril | 130 | 12 wk | NR | Black patients
| CHF unspecified | | | | Female patients
| Symptomatic patients
(Newman TJ, 1988) | captopril | 105 | NR | NR | Black patients | Captopril Multicenter Research Group
| Systolic dysfunction | | | | Female patients
| Symptomatic patients
(Magnani B , 1988) | captopril | 94 | 6 mo | NR | Female patients
| CHF unspecified
| Symptomatic patients
(Magnani B, 1986) | captopril | 94 | 6 mo | NR | Female patients
| CHF unspecified
| Symptomatic patients
(Kleber FX, 1987) | captopril | 59 | NR | NR | NR
| CHF unspecified
| Symptomatic patients
(Keren G, 1994) | captopril | 50 | 1 yr | NR | Female patients
| Systolic dysfunction
| Symptomatic patients
(Pouleur HG, 1993) | enalapril | 49 | 12 mo | NR | Female patients | SOLVD
| Systolic dysfunction
| Asymptomatic patients
(Sharpe DN, 1984) | enalapril | 36 | 3 mo | NR | Very old (Age 80+) patients
| CHF unspecified
| Symptomatic patients
(Bussmann WD, 1987) | captopril | 23 | 6 mo | NR | No subpopulations
| CHF unspecified
| Symptomatic patients
(Creager MA, 1985) | enalapril | 23 | 12 wk | NR | NR
| Systolic dysfunction
| Symptomatic patients

Evidence Table 2. Beta-Blockers-Accepted Articles

ID | Drug Studied | Sample | Followup | Data reported for specific subpop/comorb | Data may be at patient level for specific subpop/ comorb | Study name
| CHF Defined
| Study population
(Hjalmarson A, 1999) | metoprolol | 3991 | NR | Female patients | Black patients | MERIT-HF
| Systolic dysfunction | | | Diabetic patients
| Symptomatic patients
(Hjalmarson A, 2000) | metoprolol | 3991 | NR | Female patients | Black patients | MERIT-HF
| Systolic dysfunction | | | Diabetic patients
| Symptomatic patients
(Wedel H, 2001) | metoprolol | 3991 | NR | Black patients | Black patients | MERIT-HF
| Systolic dysfunction | | | Female patients | Female patients
| Symptomatic patients | | | Diabetic patients
(Plehn JF, 2000) | bucindolol | 2708 | NR | Black patients | NR | BEST
| Systolic dysfunction
| Symptomatic patients
(The Beta-Blockers Evaluation of Survival Trial Investigators (BEST, 2001) | bucindolol | 2708 | NR | Black patients | Black patients | BEST
| Systolic dysfunction | | | Female patients | Female patients
| Symptomatic patients | | | Diabetic patients
(CIBIS II, 1999) | bisoprolol | 2647 | NR | NR | Female patients | CIBIS
| Systolic dysfunction
| Symptomatic patients
(Erdmann E, 2001) | bisoprolol | 2647 | NR | Female patients | NR | CIBIS
| Systolic dysfunction | | | Diabetic patients
| Symptomatic patients | | | Renal failure patients
(Packer M, 2001) | carvedilol | 2289 | NR | Female patients | Female patients | US Carvedilol HF Study
| Systolic dysfunction
| Symptomatic patients
(Packer M , 1996) | carvedilol | 1094 | NR | Female patients | NR | US Carvedilol HF Study
| Systolic dysfunction
| Symptomatic patients
(Yancy CW, 2001) | carcedelol | 1094 | NR | Black patients | No subpopulations | US Carvedilol HF Study
| Systolic dysfunction
| Symptomatic patients
(Yancy CW, 1997) | carvedilol | 1025 | NR | Black patients | NR | US Carvedilol HF Study
| Systolic dysfunction
| Symptomatic patients
(CIBIS Investigators, 1994) | bisoprolol | 641 | NR | NR | Female patients | CIBIS
| Systolic dysfunction
| Symptomatic patients
(Eicchorn EJ, 2000) | bucindolol | 627 | NR | Black patients | NR | BEST
| Systolic dysfunction
| Symptomatic patients
(The RESOLVD Investigators 2000) | metoprolol | 426 | 24 wk | NR | Black patients | RESOLVD
| Systolic dysfunction | | | | Female patients
| Symptomatic patients | | | | Diabetic patients
(Australia/New Zealand Heart Failure Research Collaborative Group, 1997) | carvedilol | 415 | NR | NR | Female patients | Australia/ NZ HF Research Group
| Systolic dysfunction
| Symptomatic patients
(Waagstein F, 1993) | metoprolol | 383 | NR | NR | Female patients | Metoprolol in Dilated Cardiomyopathy
| Systolic dysfunction
| Symptomatic patients
(Colucci WS, 1996) | carcedilol | 366 | NR | Black patients | No subpopulations | US Carvedilol HF Study
| Systolic dysfunction | | | Other patients
| Symptomatic patients | | | Very old (Age 80+) patients
(Bristow MR, 1996) | carcedilol | 345 | NR | NR | Black patients | Mocha investigation
| Systolic dysfunction | | | | Very old (Age 80+) patients
| Symptomatic patients
(Packer M, 1996) | carvedilol | 278 | 6 mo | Female patients | Female patients | PRECISE
| Systolic dysfunction
| Symptomatic patients
(Herlitz J, 1997) | metoprolol | 262 | NR | NR | Female patients | Goteborg Metoprolol Trial
| CHF unspecified | | | | Diabetic patients
| Post MI and reduced LVEF
(Cice G, 2000) | carvedilol | 168 | 6 mo | NR | Female patients
| Systolic dysfunction
| Symptomatic patients
(Bristow MR, 1994) | bucindolol | 139 | 12 wk | NR | Female patients
| Systolic dysfunction
| Symptomatic patients
(Witchitz S, 2000) | celiprolol | 132 | 1 yr | NR | Female patients | Celicard
| Systolic dysfunction
| Symptomatic patients
(Cohn JN, 1997) | carvedilol | 131 | 6 mo | NR | Black patients | US Carvedilol HF Study
| Systolic Dysfunction | | | | Very old (Age 80+) patients
| Symptomatic patients | | | | Female patients
(Doughty RN, 2000) | carvedilol | 119 | 6 mo | NR | Female patients | Australia/ NZ HF Research Group
| Systolic dysfunction | | | | None
| Symptomatic patients
(Krum H, 1995) | carvedilol | 56 | NR | NR | Female patients
| Systolic dysfunction
| Symptomatic patients
(Genth-Zotz S, 2000) | metoprolol | 52 | 6 mo | NR | Female patients | MIC
| Systolic dysfunction
| Symptomatic patients
(Anderson JL, 1985) | metoprolol | 50 | NR | NR | Female patients
| Systolic dysfunction
| Symptomatic patients
(Fisher ML, 1994) | metoprolol | 50 | 6 mo | NR | Female patients
| Systolic dysfunction | | | | Diabetic patients
| Symptomatic patients
(Woodley SL, 1991) | bucindolol | 49 | 12 wk | NR | Very old (Age 80+) patients
| Systolic dysfunction
| Symptomatic patients
(Andersson B, 1994) | metoprolol | 41 | 6 mo | NR | Very old (Age 80+) patients
| Systolic dysfunction
| Symptomatic patients
(Gilbert EM, 1990) | bucindolol | 24 | 3 mo | NR | Female patients
| Systolic dysfunction
| Symptomatic patients
(Eichhorn EJ, 1994) | metaprolol | 24 | 3 mo | NR | Black patients
| Systolic dysfunction
| Symptomatic patients
(Wisenbaugh T, 1993) | nebivolol | 24 | 3 mo | NR | Very old (Age 80+) patients
| Systolic dysfunction
| Symptomatic patients
(Cucchini F, 1988) | metoprolol | 20 | 6 mo | NR | Female patients
| Systolic dysfunction
| Symptomatic patients

Evidence Table 3. ACE Inhibitor Studies Contributing to the Meta-Analysis

Study Name | Author Date | Mean Treatment Duration | Patient Level Data | ARM # | N | Drug
| Add'l Articles
AIRE | Hall, 1991 | 15 months | | 1 | 982 | placebo
AIRE Study Investigators, 1993 | Cleland, 1997 | | | 2 | 1004 | ramipril
ID #00098 | Hall, 1997
| Spargias, 1998
CONSENSUS | Swedberg, 1988 | 188 days | X | 1 | 126 | placebo
CONSENSUS Trial Study Group, 1987 | Kjekshus, 1989 | | | 2 | 127 | enalapril
ID #00128 | Eriksson, 1990
| Swedberg, 1990
| Ljungman, 1992
| Swedberg, 1999
SAVE | Moyé, 1994 | 42 months | | 1 | 1112 | Placebo
Pfeffer, 1992 | Rutherford, 1994 | | | 2 | 1113 | captopril
ID #00101 | Hager, 1998
SMILE | Borghi, 1996 | 6 weeks | | 1 | 784 | placebo
Ambrosioni, 1995 | Ambrosioni, 1994 | | | 2 | 772 | zofenopril
ID #00065 | Boghi, 1999
SOLVD-prevention | The SOLVD Invesigators, 1990 | 37 months | X | 1 | 2117 | placebo
Yusuf, 1992 | The SOLVD Investigators, 1991 | | | 2 | 2111 | enalapril
ID #00072 | Hood, 1991
| Pitt, 1992
| Konstam, 1992
| Bangdiwala, 1992
| Johnstone, 1992
SOLVD-treatment | Pouleur, 1992 | 41 months | X | 1 | 1283 | placebo
Yusuf, 1991 | Pouleur, 1993 | | | 2 | 1284 | enalapril
ID #00075 | Rogers, 1994
| Benedict, 1996
| Konstam, 1996
| Kostis, 1996
| Shindler, 1996
| Dries, 1999
| Knight, 1999
| Exner, 2000
| Exner, 2001
| Bourassa, 1993
TRACE | Kober, 1996 | varied | X | 1 | 873 | placebo
Kober, 1995 | Torp-Pedersen, 1996 | | | 2 | 876 | trandolapril
ID #00094 | Gustafsson, 1999

Evidence Table 4. Beta-Blocker Studies Contributing to the Meta-Analysis

Study Name | Author Date | Mean Treatment Duration | Patient Level Data | ARM # | N | Drug
| Add'l Articles
BEST | Plehn, 2000 | 2 years | | 1 | 1354 | placebo
The Beta-Blocker Evaluation of Survival Trial Investigators, 2001 | Eichhorn, 2000 | | | 2 | 1354 | bucindolol
ID #00439 | The BEST Steering Cmte., 1995
CIBIS | CIBIS Investigators and Cmtes., 1994 | 1.3 years | | 1 | 1148 | placebo
CIBIS Investigators, 1999 | Pousset, 1996 | | | 2 | 1137 | bisoprolol
ID #0006 | Copie, 1996
| Lechat, 1997
| Funck-Brentano, 2000
| Erdmann, 2001
COPERNICUS | | 10.4 months | X | 1 | 1133 | placebo
Packer, 2001 | | | | 2 | 1156 | carvedilol
ID #00441
MERIT-HF | The Int'l Steering Cmte. On Behalf of the MERIT-HF Study Group, 1997 | 1 year | X | 1 | 2001 | placebo
Hjalmarson, 1999 | Goldstein, 1999 | | | 2 | 1990 | metoprolol
ID #0007 | Mylona, 1999
| Fagerberg, 2000
| Hjalmarson, 2000
| Wedel, 2001
| Ghali, 2002
US Carvedilol Study | Yancy, 1997 | 6.5 months | | 1 | 398 | placebo
Packer, 1996 | Colucci, 1996 | | | 2 | 696 | carvedilol
ID #0005 | Yancy, 2001