# Bibliography

### Accepted Articles

Ambrosioni E, Borghi C, Magnani B. The effect of the angiotensin-converting-enzyme inhibitor zofenopril on mortality and morbidity after anterior myocardial infarction. N Engl J Med. 1995;332(2):80-85. [pmid: 7990904].
Anderson J L, Lutz J R, Gilbert E M, Sorensen S G, Yanowitz F G, Menlove R L, et al. A randomized trial of low-dose beta-blockade therapy for idiopathic dilated cardiomyopathy. Am J Cardio. 1985;55(4):p471-5.
Andersson B, Hamm C, Persson S, Wikstrom G, Sinagra G, Hjalmarson A, et al. Improved exercise hemodynamic status in dilated cardiomyopathy after beta-adrenergic blockade treatment. J Am Coll Cardiol. 1994;23(6):1397-404. [pmid: 8176099].
Australia/New Zealand Heart Failure Research Collaborative Group. Randomised, placebo-controlled trial of carvedilol in patients with congestive heart failure due to ischaemic heart disease. Australia/New Zealand Heart Failure Research Collaborative Group. Lancet. 1997;349(9049):p375-80. [pmid: 9033462].
Ball S G, Hall A S, Mackintosh A F, et al. Effect of ramipril on mortality and morbidity of survivors of acute myocardial infarction with clinical evidence of heart failure. The Acute Infarction Ramipril Efficacy (AIRE) Study Investigators. Lancet. 1993;342(8875):p821-8. [pmid: 8104270].
Barabino A, Galbariggi G, Pizzorni C, et al. Comparative effects of long-term therapy with captopril and ibopamine in chronic congestive heart failure in old patients. Cardiology. 1991;78:289-296. [pmid: 6615401].
Bristow M R, Gilbert E M, Abraham W T, Adams K F, Fowler M B, Hershberger R E, et al. Carvedilol produces dose-related improvements in left ventricular function and survival in subjects with chronic heart failure. Circulation. 1996;94:2807-2816. [pmid: 8941106].
Bristow M R, O'Connell J B, Gilbert E M, French W J, Leatherman G, Kantrowitz N E, et al. Dose-response of chronic beta-blocker treatment in heart failure from either idiopathic dilated or ischemic cardiomyopathy. Bucindolol Investigators. Circulation. 1994;89(4):p1632-42. [pmid: 7908610].
Brown E J Jr, Chew P H, MacLean A, Gelperin K, Ilgenfritz J P, Blumenthal M. Effects of fosinopril on exercise tolerance and clinical deterioration in patients with chronic congestive heart failure not taking digitalis. Fosinopril Heart Failure Study Group. Am J Cardio. 1995;75(8):p596-600.
Bulpitt C J, Fletcher A E, Dossegger L, Neiss A, Nielsen T, Viergutz S. Quality of life in chronic heart failure: cilazapril and captopril versus placebo. Cilazapril-Captopril Multicentre Group. Heart. 1998;79(6):593-8. [pmid: 10078088]. [pmcid: 1728718].
Bussmann W D, Storger H, Hadler D, et al. Long-term treatment of severe chronic heart failure with captopril: a double-blind randomized, placebo-controlled long-term study. J Cardiovasc Pharmacol. 1987;9(suppl. 2):S50-S60. [pmid: 2441202].
Captopril-Digoxin Multicenter Research Group. Comparative effects of therapy with captopril and digoxin in patients with mild to moderate heart failure. The Captopril-Digoxin Multicenter Research Group. JAMA. 1988;259(4):539-44. [pmid: 2447297].
Chalmers J P, West M J, Cyran J, De La Torre D, Englert M, Kramar M, et al. Placebo-controlled study of lisinopril in congestive heart failure: a multicentre study. J Cardiovasc Pharmacol. 1987;9(Suppl 3):pS89-97. [pmid: 2442560].
CIBIS Investigators and Committees. A randomized trial of beta-blockade in heart failure. The Cardiac Insufficiency Bisoprolol Study (CIBIS). Circulation. 1994;90(4):1765-73. [pmid: 7923660].
CIBIS-II: The Cardiac Insufficiency Bisoprolol Study II: a randomised trial Lancet. 1999;353(9146):9–13.
Cice G, Tagliamonte E, Ferrara L, Iacono A. Efficacy of carvedilol on complex ventricular arrhythmias in dilated cardiomyopathy: double-blind, randomized, placebo-controlled study. Eur Heart J. 2000;21(15):1259-64. [pmid: 10924316].
Cleland J G, Erhardt L, Murray G, Hall A S, Ball S G. Effect of ramipril on morbidity and mode of death among survivors of acute myocardial infarction with clinical evidence of heart failure. A report from the AIRE Study Investigators. Eur Heart J. 1997;18(1):41-51. [pmid: 9049514].
Cohn J N, Fowler M B, Bristow M R, Colucci W S, Gilbert E M, Kinhal V, et al. Safety and efficacy of carvedilol in severe heart failure. The U.S. Carvedilol Heart Failure Study Group. Journal of Cardiac Failure. 1997;3(3):p173-9. [pmid: 9330125].
Colucci W S, Packer M, Bristow M R, Gilbert E M, Cohn J N, Fowler M B, et al. Carvedilol inhibits clinical progression in patients with mild symptoms of heart failure. Circulation. 1996;94:280-2806. [pmid: 8941105].
The CONSENSUS Trial Study Group. Effects of enalapril on mortality in severe congestive heart failure. Results of the Cooperative North Scandinavian Enalapril Survival Study (CONSENSUS). N Engl J Med. 1987;316(23):1429-35. [pmid: 2883575].
Creager M A, Massie B M, Fascon D P, et al. Acute and long-term effects of Enalapril on the cardiovascular response to exercise and exercise tolerance in patients with congestive heart failure. JACC. 1985;6:163-70. [pmid: 2989349].
Cucchini F, Compostella L, Papalia D, de Domenico R, Iavernaro A, Zeppellini R. [Chronic treatment of dilated cardiomyopathy by beta blocking agents. Clinical and hemodynamic follow-up]: <Original> Trattamento cronico della cardiomiopatia dilatativa con betabloccanti. Controllo clinico ed emodinamico a distanza. Giornale Italiano Di Cardiologia. 1988;18(10):p835-42. [pmid: 2907743].
Doughty R N, Whalley G A, Gamble G, MacMahon S, Sharpe N. Effects of carvedilol on left ventricular regional wall motion in patients with heart failure caused by ischemic heart disease. Australia-New Zealand Heart Failure Research Collaborative Group. J Card Fail. 2000;6(1):11-8. [pmid: 10746814].
Eichhorn EJ, Domanski MJ, Adams K, et al. Effect of beta-blockade on mortality in African-Americans: The beta-blocker evaluation of survival trial. Circulation. 2000;102 (suppl 2)(18).
Eichhorn E J, Heesch C M, Barnett J H, Alvarez L G, Fass S M, Grayburn P A, et al. Effect of metoprolol on myocardial function and energetics in patients with nonischemic dilated cardiomyopathy: a randomized, double-blind, placebo-controlled study. J Am Coll Cardiol. 1994;24(5):1310-20. [pmid: 7930255].
Erdmann E, Lechat P, Verkenne P, Wiemann H. Results from post-hoc analyses of the CIBIS II trial: effect of bisoprolol in high-risk patient groups with chronic heart failure. Euro J Heart Failure. 2001;3:469-479.
Exner D V, Dries D L, Domanski M J, Cohn J N. Lesser response to angiotensin-converting-enzyme inhibitor therapy in black as compared with white patients with left ventricular dysfunction. N Eng J Med. 2001;344(18):1351-7.
Exner DV, Dries DL, Domanski MJ, et al. Enalapril therapy and outcome in Black versus White patients enrolled in the studies of left ventricular dysfunction. Circulation. 2000;102(18).
Fisher M L, Gottlieb S S, Plotnick G D, Greenberg N L, Patten R D, Bennett S K, et al. Beneficial effects of metoprolol in heart failure associated with coronary artery disease: a randomized trial. J Am Coll Cardiol. 1994;23(4):p943-50. [pmid: 8106700].
Genth-Zotz S, Zotz R J, Sigmund M, Hanrath P, Hartmann D, Bohm M, et al. MIC trial: metoprolol in patients with mild to moderate heart failure: effects on ventricular function and cardiopulmonary exercise testing. Eur J Heart Fail. 2000;2(2):p175-81. [pmid: 10856731].
Ghose J C, Chakraborty S, Mondal M, Bhandari B. Effect of vasodilator therapy on mortality in chronic congestive heart failure. Journal of the Association of Physicians of India. 1993;41(5):p269-71. [pmid: 8300456].
Gilbert E M, Anderson J L, Deitchman D, Yanowitz F G, O'Connell J B, Renlund D G, et al. Long-term beta-blocker vasodilator therapy improves cardiac function in idiopathic dilated cardiomyopathy: a double-blind, randomized study of bucindolol versus placebo. Am J Med. 1990;88(3):p223-9. [pmid: 1968710].
Giles T D. Lisinopril Chronic Heart Failure Group. Lisinopril treatment of congestive heart failure-results of a placebo controlled trial. Circulation. 1990;82(suppl 4)::III-323.
Gundersen T, Wiklund I, Swedberg K, Amtorp O, Remes J, Nilsson B. Effects of 12 weeks of ramipril treatment on the quality of life in patients with moderate congestive heart failure: results of a placebo-controlled trial. Ramipril Study Group. Cardiovascular Drugs and Therapy. 1995;9(4):p589-94. [pmid: 8547209].
Gustafsson I, Torppedersen C, Kober L, Gustafsson F, Hildebrandt P. Effect of the angiotensin-converting enzyme inhibitor trandolapril on mortality and morbidity in diabetic patients with left ventricular dysfunction after acute myocardial infarction. J Am Coll Cardiol. 1999;34(N1. JUL)::83-89. [pmid: 10399995].
Hall A S, Murray G D, Ball S G. Follow-up study of patients randomly allocated ramipril or placebo for heart failure after acute myocardial infarction: AIRE Extension (AIREX) Study. Acute Infarction Ramipril Efficacy. Lancet. 1997;349(9064):p1493-7. [pmid: 9167457].
Herlitz J, Waagstein F, Lindqvist J, Swedberg K, Hjalmarson A. Effect of metoprolol on the prognosis for patients with suspected acute myocardial infarction and indirect signs of congestive heart failure (a subgroup analysis of the Goteborg Metoprolol Trial). Am J Cardio. 1997;80(9B):p40J-44J.
Hjalmarson A, Goldstein S, Fagerberg B, Wedel H, Waagstein F, Kjekshus J, et al. Effects of controlled-release metoprolol on total mortality, hospitalizations, and well-being in patients with heart failure: the Metoprolol CR/XL Randomized Intervention Trial in congestive heart failure (MERIT-HF). MERIT-HF Study Group. JAMA. 2000;283(10):p1295-302. [pmid: 10714728].
Hjalmarson A, Goldstein S, Fagerberg B, Wedel H, Waagstein F, Kjekshus J, et al. Effect of metoprolol CR/XL in chronic heart failure: Metoprolol CR/XL Randomised Intervention Trial in Congestive Heart Failure (MERIT-HF). Lancet. 1999;353(9169):2001-2007. [pmid: 10376614].
Jerie P, Kremer H J, Uhlir O, Widimsky J. [A Czech and Slovak interventional study of spirapril (the CASSIS study). A randomized, double-blind, multicenter, placebo-controlled study in chronic heart failure]: <Original> Ceska a slovenska intervencni studie se spiraprilem (studie CASSIS). Randomizovana, dvojiteslepa, multicentricka studie, kontrolovana aktivne i placebem chronickeho srdecniho selhani. Za resitele studie CASSIS. Vnitrni Lekarstvi. 1997;43(6):p351-8. [pmid: 9601864].
Keren G, Pardes A, Eschar Y, Koifman B, Scherez J, Geleranter I, et al. One-year clinical and echocardiographic follow-up of patients with congestive cardiomyopathy treated with captopril compared to placebo. Israel Journal of Medical Sciences. 1994;30(1):p90-8. [pmid: 8138400].
Kjekshus J, Swedberg K. Enalapril for congestive heart failure. Am J Cardio. 1989;63(8):p26D-32D.
Kleber FX, Laube A, Osterkorn K, et al. Captopril in mild to moderate heart failure after 18 months: effects on morbidity and mortality. JACC. 1987;9:42A (Abstr).
Kleber F X, Niemoller L, Doering W. Impact of converting enzyme inhibition on progression of chronic heart failure: results of the Munich Mild Heart Failure Trial. British Heart Journal. 1992;67(4):p289-96. [pmid: 1389702]. [pmcid: 1024835].
Kober L, Torp-Pedersen C, Carlsen J E, Bagger H, Eliasen P, Lyngborg K, et al. A clinical trial of the angiotensin-converting-enzyme inhibitor trandolapril in patients with left ventricular dysfunction after myocardial infarction. Trandolapril Cardiac Evaluation (TRACE) Study Group. N Engl J Med. 1995;333(25):p1670-6. [pmid: 7477219].
Krum H, Sackner-Bernstein J D, Goldsmith R L, Kukin M L, Schwartz B, Penn J, et al. Double-blind, placebo-controlled study of the long-term efficacy of carvedilol in patients with severe chronic heart failure. Circulation. 1995;92(6):p1499-506. [pmid: 7664433].
Magnani B. Converting enzyme inhibition and heart failure. Am J Med. 1988;84(3A):p87-91. [pmid: 3064604].
Magnani B, Magelli C. Captopril in mild heart failure: preliminary observations of a long-term, double-blind, placebo-controlled multicentre trial. Postgraduate Medical Journal. 1986;62(Suppl 1):p153-8. [pmid: 3534852].
Moye L A, Pfeffer M A, Wun C C, Davis B R, Geltman E, Hayes D, et al. Uniformity of captopril benefit in the SAVE study: Subgroup analysis. Eur Heart J. 1994;15(SUPPL. B)::2-8. [pmid: 8076658].
Newman T J, Maskin C S, Dennick L G, Meyer J H, Hallows B G, Cooper W H. Effects of captopril on survival in patients with heart failure. Am J Med. 1988;84(3A):p140-4. [pmid: 3064591].
Packer M, Bristow M R, Cohn J N, Colucci W S, Fowler M B, Gilbert E M, et al. The effect of carvedilol on morbidity and mortality in patients with chronic heart failure. U.S. Carvedilol Heart Failure Study Group. N Engl J Med. 1996;334(21):1349-55. [pmid: 8614419].
Packer M, Coats A J S, Fowler M B, Katus H A, Krum H, Mohacsi P, et al. Effect of carvedilol on survival in severe chronic heart failure. N Engl J Med. 2001;344(22):1651-8. [pmid: 11386263].
Packer M, Colucci W S, Sackner-Bernstein J D, Liang C S, Goldscher D A, Freeman I, et al. Double-blind, placebo-controlled study of the effects of carvedilol in patients with moderate to severe heart failure. The PRECISE Trial. Prospective Randomized Evaluation of Carvedilol on Symptoms and Exercise. Circulation. 1996;94(11):2793-9. [pmid: 8941104].
Pfeffer M A, Braunwald E, Moye L A, Basta L, Brown E J Jr, Cuddy T E, et al. Effect of captopril on mortality and morbidity in patients with left ventricular dysfunction after myocardial infarction. Results of the survival and ventricular enlargement trial. The SAVE Investigators. N Engl J Med. 1992;327(10):p669-77. [pmid: 1386652].
Pflugfelder P W, Baird M G, Tonkon M J, DiBianco R, Pitt B. Clinical consequences of angiotensin-converting enzyme inhibitor withdrawal in chronic heart failure: a double-blind, placebo-controlled study of quinapril. The Quinapril Heart Failure Trial Investigators. J Am Coll Cardiol. 1993;22(6):1557-63. [pmid: 8227822].
Pitt B, Yusuf S, the SOLVD Investigators. Studies of left ventricular dysfunction (SOLVD) subgroup results. J Am Coll Cardiol. 1992;19:215A.
Plehn JF, Krause-Steinrauf H, Anand IS, et al. Effect of race on cause-specific cardiovascular mortality in BEST. Circulation. 2000;102 (suppl 2)(18).
Pouleur H G, Konstam M A, Udelson J E, Rousseau M F. Changes in ventricular volume, wall thickness and wall stress during progression of left ventricular dysfunction. The SOLVD Investigators. J Am Coll Cardiol. 1993;22(4 Suppl A):43A-48A. [pmid: 8376696].
Sharpe D N, Murphy J, Coxon R, et al. Enalapril in patients with chronic heart failure: a placebo controlled randomized double-blind study. Circulation. 1984;70:271-8. [pmid: 6329547].
Swedberg K, Kjekshus J. Snapinn SOLVD Long-term survival in severe heart failure in patients treated with enalapril. Ten year follow-up of CONSENSUS I. Eur Heart J. 1999;20(2):p136-9. [pmid: 10099910].
The Beta-Blocker Evaluation of Survival Trial Investigators (BEST). A trial of the beta-blocker bucindolol in patients with advanced chronic heart failure. N Engl J Med. 2001;344(22):1659-67. [pmid: 11386264].
The RESOLVD Investigators. Effects of metoprolol CR in patients with ischemic and dilated cardiomyopathy: the randomized evaluation of strategies for left ventricular dysfunction pilot study. Circulation. 2000;101(4):p378-84. [pmid: 10653828].
The SOLVD Investigators. Effect of enalapril on survival in patients with reduced left ventricular ejection fractions and congestive heart failure. N Engl J Med. 1991;325(5):293-302. [pmid: 2057034].
Torp-Pedersen C, Kober L, Carlsen J. Angio-converting enzyme inhibition after myocardial infarction: the Trandolapril Cardiac Evaluation Study. Am Heart J. 1996;132(1 Pt 2 Su):235-43. [pmid: 8677862].
van Veldhuisen D J, Genth-Zotz S, Brouwer J, Boomsma F, Netzer T, Man T, Veld A J, et al. High- versus low-dose ACE inhibition in chronic heart failure: a double-blind, placebo-controlled study of imidapril. J Am Coll Cardiol. 1998;32(7):p1811-8. [pmid: 9857856].
Waagstein F, Bristow M R, Swedberg K, Camerini F, Fowler M B, Silver M A, et al. Beneficial effects of metoprolol in idiopathic dilated cardiomyopathy. Metoprolol in Dilated Cardiomyopathy (MDC) Trial Study Group. Lancet. 1993;342(8885):p1441-6. [pmid: 7902479].
Wedel H, DeMets D, Deedwania P, et al. Challenges of subgroup analyses in multinational clinical trials: Experiences from the MERIT-HR trial. Am Heart J. 2001;142:502-11. [pmid: 11526365].
Widimsky J, Kremer H J, Jerie P, Uhlir O. Czech and Slovak spirapril intervention study (CASSIS). A randomized, placebo and active-controlled, double-blind multicentre trial in patients with congestive heart failure. European Journal of Clinical Pharmacology. 1995;49(12):p95-102. [pmid: 8751029].
Wisenbaugh T, Katz I, Davis J, Essop R, Skoularigis J, Middlemost S, et al. Long-term (3-month) effects of a new beta-blocker (nebivolol) on cardiac performance in dilated cardiomyopathy. J Am Coll Cardiol. 1993;21(5):1094-100. [pmid: 8096228].
Witchitz S, Cohen-Solal A, Dartois N, Weisslinger N, Juste K, Darmon J Y. Treatment of heart failure with celiprolol, a cardioselective beta blocker with beta-2 agonist vasodilatory properties. The CELICARD Group. Am J Cardio. 2000;85(12):p1467-71.
Woodley S L, Gilbert E M, Anderson J L, O'Connell J B, Deitchman D, Yanowitz F G, et al. Beta-blockade with bucindolol in heart failure caused by ischemic versus idiopathic dilated cardiomyopathy. Circulation. 1991;84(6):2426-41. [pmid: 1683602].
Yancy C W, Fowler M B, Colucci W S, Gilbert E M, Bristow M R, Cohn J N, et al. Race and the response to adrenergic blockade with carvedilol in patients with chronic heart failure. N Engl J Med. 2001;344(18):1358-65. [pmid: 11333992].
Yancy C W, Fowler M B, Colucci W S, Gilbert E M, Lukas M A, Young S T. Response of black heart failure patients to carvedilol [abstract]. J Am Coll Cardiol. 1997;29:284A.
Yusuf S, Nicklas J M, Timmis G, Breneman G, Jafri S M, Duvernoy W F C, et al. Effect of enalapril on mortality and the development of heart failure in asymptomatic patients with reduced left ventricular ejection fractions. The SOLVD Investigators. N Engl J Med. 1992;327(10):685-691. [pmid: 1463530].

### Rejected Articles

Acanfora D, Lanzillo T, Papa A, Longobardi G, Furgi G, Rengo C, et al. Congestive heart failure in elderly patients: controlled study of delapril versus captopril. Am J Cardiol. 1995;75(18):37F-43F. [pmid: 7778533].
Afzal A, Ananthasubramaniam K, Sharma N, al-Malki Q, Ali A S, Jacobsen G, et al. Racial differences in patients with heart failure. Clin Cardiol. 1999;22(12):791-4. [pmid: 10626081].
Afzal A, Brar J S, Ali A S, et al. Racial differences in patients with chest pain syndrome and abnormal coronary angiogram. Chest. 1997;112:245.
Ajayi A A, Balogun M O, Oyewo E A, Ladipo G O. Enalapril in African patients with congestive cardiac failure. Br J Clin Pharmacol. 1989;27(3):p400-3. [pmid: 2541754]. [pmcid: 1379843].
Akinkugbe OO, Nicholson GD, Cruickshank JK. Heart disease in blacks of Africa and the Caribbean. Saunders E. (editor). Cardiovascular Disease in Blacks. Philadelphia: F.A. Davis, 1991:377–91.
Alexander M, Grumbach K, Selby J, et al. Hospitalization for congestive heart failure: explaining racial differences. JAMA. 1990;263:2344-6. [pmid: 2182918].
Ambrosioni E, Borghi C, Magnani B. Survival of myocardial infarction long-term evaluation (SMILE) study: rationale, design, organization, and outcome definitions. Control Clin Trials. 1994;15(3):201-10. [pmid: 8039405].
Ambrosioni E, Borghi C, Magnani B. The effect of the angiotensin-converting-enzyme inhibitor zofenopril on mortality and morbidity after anterior myocardial infarction. N Engl J Med. 1995;332(2):80-85. [pmid: 7990904].
American Heart Association. Heart and Stroke Facts: 1996 Statistical Supplement. Dallas, Texas: American Heart Association, 1996, 15.
Anderson F, Nilsson B, Gundersen T, Swedberg K, Amtorp O, Remes J. The effect on healthcare costs of adding ramipril to conventional therapy for patients with congestive heart failure. Br J Med Econ. 1995;8(3):125-135.
Anderson J L, Lutz J R, Gilbert E M, Sorensen S G, Yanowitz F G, Menlove R L, et al. A randomized trial of low-dose beta-blockade therapy for idiopathic dilated cardiomyopathy. Am J Cardio. 1985;55(4):p471-5.
Andersson B, Hamm C, Persson S, Wikstrom G, Sinagra G, Hjalmarson A, et al. Improved exercise hemodynamic status in dilated cardiomyopathy after beta-adrenergic blockade treatment. J Am Coll Cardiol. 1994;23(6):1397-404. [pmid: 8176099].
Arcensio S R, Barretto A C, Szambock F, Mady C, Arteaga E, da Luz P L, et al. [Comparative study between ibopamine and captopril in mild and moderate heart failure. A double-blind study]. Arq Bras Cardiol. 1994;63(5):409-13. [pmid: 7611921].
Aronow W S, Ahn C, Kronzon I. Effect of propranolol versus no propranolol on total mortality plus nonfatal myocardial infarction in older patients with prior myocardial infarction, congestive heart failure, and left ventricular ejection fraction > or = 40% treated with diuretics plus angiotensin-converting enzyme inhibitors. Am J Cardio. 1997;80(2):p207-9.
Aronow W S, Ahn C, Kronzon J. Congestive heart failure, coronary events and atherothrombotic brain infarction in elderly blacks and whites with systemic hypertension and with and without echocardiographic and eletrocardiographic evidence of left ventricular hypertrophy. Am J Cardiol. 1991;67:295-299. [pmid: 1825011].
Aronow W S, Greenfield R S, Alimadadian H, et al. Effect of the vasodilator trimazosin vs. placebo on exercise performance in chronic left ventricular failure. Am J Cardiol. 1977;40:789-793. [pmid: 335867].
Aronow W S, Lurie M, Turbow M, et al. Effect of prazosin vs. placebo on chronic left ventricular heart failure. Circulation. 1979;59:344-350. [pmid: 365391].
Australia/New Zealand Heart Failure Research Collaborative Group. Randomised, placebo-controlled trial of carvedilol in patients with congestive heart failure due to ischaemic heart disease. Australia/New Zealand Heart Failure Research Collaborative Group. Lancet. 1997;349(9049):375-80. [pmid: 9033462].
Bakris G L, Weir M R. Angiotensin-converting enzyme inhibitor-associated elevations in serum creatinine—is this a cause for concern?. Arch Int Med. 2000;160(N5):685-693. [pmid: 10724055].
Ball S G, Hall A S, Mackintosh A F, et al. Effect of ramipril on mortality and morbidity of survivors of acute myocardial infarction with clinical evidence of heart failure. The Acute Infarction Ramipril Efficacy (AIRE) Study Investigators. Lancet. 1993;342(8875):p821-8. [pmid: 8104270].
Bangdiwala S I, Weiner D H, Bourassa M G, Friesinger G C 2d, Ghali J K, Yusuf S. Studies of Left Ventricular Dysfunction (SOLVD) Registry: rationale, design, methods and description of baseline characteristics. Am J Cardiol. 1992;70(3):347-53. [pmid: 1632401].
Barabino A, Galbariggi G, Pizzorni C, et al. Comparative effects of long-term therapy with captopril and ibopamine in chronic congestive heart failure in old patients. Cardiology. 1991;78:289-296. [pmid: 6615401].
Barr C S, Lang C C, Hanson J, Arnott M, Kennedy N, Struthers A D. Effects of adding spironolactone to an angiotensin-converting enzyme inhibitor in chronic congestive heart failure secondary to coronary artery disease. Am J Cardio. 1995;76(17):1259-1265.
Baruch L, Anand I, Cohen I S, Ziesche S, Judd D, Cohn J N. Augmented short- and long-term hemodynamic and hormonal effects of an angiotensin receptor blocker added to angiotensin converting enzyme inhibitor therapy in patients with heart failure. Vasodilator Heart Failure Trial (V-HeFT) Study Group. Circulation. 1999;99(20):2658-64. [pmid: 10338459].
Bayliss J, Canepa-Anson R, Norell M, Poole-Wilson P, Sutton G. The renal response to neuroendocrine inhibition in chronic heart failure: double-blind comparison of captopril and prazosin. Eur Heart J. 1986;7(10):877-84. [pmid: 3539615].
Beermann B, Nyquist O, Hoglund C, Jacobsson K A, Naslund U, Jensen-Urstad M. Acute haemodynamic effects and pharmacokinetics of ramipril in patients with heart failure. A placebo controlled three-dose study. Eur J Clin Pharmacol. 1993;45(3):241-6. [pmid: 8276048].
Behrens S, Ney G, Fisher S G, Fletcher R D, Franz M R, Singh S N. Effects of amiodarone on the circadian pattern of sudden cardiac death (Department of Veterans Affairs Congestive Heart Failure-Survival Trial of Antiarrhythmic Therapy). Am J Cardiol. 1997;80(1):45-8. [pmid: 9205018].
Benedict C R, Shelton B, Johnstone D E, Francis G, Greenberg B, Konstam M, et al. Prognostic significance of plasma norepinephrine in patients with asymptomatic left ventricular dysfunction. SOLVD Investigators. Circulation. 1996;94(4):690-7. [pmid: 8772689].
Beneficial effects of captopril on prognosis in patients with acute myocardial infarction. Chinese Journal of Cardiology 1996;24(3):187–190.
Berger P B, Holmes D R Jr, Ohman E M, O'Hanesian M A, Murphy J G, Schwartz R S, et al. Restenosis, reocclusion and adverse cardiovascular events after successful balloon angioplasty of occluded versus nonoccluded coronary arteries. Results from the Multicenter American Research Trial With Cilazapril After Angioplasty to Prevent Transluminal Coronary Obstruction and Restenosis (MARCATOR). J Am Coll Cardiol. 1996;27(1):1-7. [pmid: 8522681].
Bergler-Klein J, Sochor H, Pouleur H, Pacher R, Porenta G, Glogar D. Safety of concomitant potassium-sparing diuretics in angiotensin- converting enzyme inhibitor therapy in severe congestive heart failure. J Cardiovasc Pharmacol. 1994;24(2):194-198. [pmid: 7526050].
The BEST Steering Committee, Design of the Beta-Blocker Evaluation Survival Trial (BEST). Am J Cardio. 1995;75(17) p1220–3.
The Beta-Blocker Evaluation of Survival Trial Investigators (BEST). A trial of the beta-blocker bucindolol in patients with advanced chronic heart failure. N Engl J Med. 2001;344(22):1659-67. [pmid: 11386264].
Beynon J H, Pathy M S. An open, parallel group comparison of quinapril and captopril, when added to diuretic therapy, in the treatment of elderly patients with heart failure. Curr Med Res Opin. 1997;13(10):p583-92. [pmid: 9327193].
Boccanelli A, Zachara E, Liberatore S M, Carboni G P, Prati P L. Addition of captopril versus increasing diuretics in moderate but deteriorating heart failure: a double-blind comparative trial. Postgrad Med J. 1986;62(Suppl 1):184-7. [pmid: 3534859].
Bohler S, Saubadu S, Scheldewaert R, Figulla H R. Betaxolol versus carvedilol in chronic heart failure (BETACAR study). Rationale and design. Arzneimittelforschung. 1999;49(4):311-7. [pmid: 10337449].
Borghi C, Ambrosioni E, Magnani B. Effects of the early administration of zofenopril on onset and progression of congestive heart failure in patients with anterior wall acute myocardial infarction. The SMILE Study Investigators. Survival of Myocardial Infarction Long-term Evaluation. Am J Cardiol. 1996;78(3):317-22. [pmid: 8759812].
Borghi C, Bacchelli S, Esposti D D, Bignamini A, Magnani B, Ambrosioni E. Effects of the administration of an angiotensin-converting enzyme inhibitor during the acute phase of myocardial infarction in patients with arterial hypertension. SMILE Study Investigators. Survival of Myocardial Infarction Long-term Evaluation. Am J Hypertens. 1999;12(7):665-72. [pmid: 10411363].
Borghi C, Marino P, Zardini P, Magnani B, Collatina S, Ambrosioni E. Short- and long-term effects of early fosinopril administration in patients with acute anterior myocardial infarction undergoing intravenous thrombolysis: results from the Fosinopril in Acute Myocardial Infarction Study. FAMIS Working Party. Am Heart J. 1998;136(2):213-25. [pmid: 9704681].
Borghi C, Magelli C, Costa F V, Magnani B, Ambrosioni E. Captopril improves hemodynamic response to static exercise in patients with congestive heart failure: a double-blind, placebo-controlled, randomized trial. Clin Cardiol. 1990;13(5):329-34. [pmid: 2189613].
Bounhoure J P, Bottineau G, Lechat P, et al. Apport du perindopril au traitement de l'insuffisance cardiaque chronique congestive. Arch Mal Coeur. 1989;82:73-8. [pmid: 2505716].
Bourassa M G, Gurne O, Bangdiwala S I, Ghali J K, Young J B, Rousseau M, Johnstone D E, Yusuf S. Natural history and patterns of current practice in heart failure. The Studies of Left Ventricular Dysfunction (SOLVD) Investigators. J Am Coll Cardiol. 1993;22(4 Suppl A):14A-19A. [pmid: 8376685].
Braunwald E. Expanding indications for beta-blockers in heart failure. N Engl J Med. 2001;344(22):1711-12. [pmid: 11386271].
Bristow M R, Gilbert E M, Abraham W T, Adams K F, Fowler M B, Hershberger R E, et al. Carvedilol produces dose-related improvements in left ventricular function and survival in subjects with chronic heart failure. Circulation. 1996;94:2807-2816. [pmid: 8941106].
Bristow M R, O'Connell J B, Gilbert E M, French W J, Leatherman G, Kantrowitz N E, et al. Dose-response of chronic beta-blocker treatment in heart failure from either idiopathic dilated or ischemic cardiomyopathy. Bucindolol Investigators. Circulation. 1994;89(4):p1632-42. [pmid: 7908610].
Brown E J Jr, Chew P H, MacLean A, Gelperin K, Ilgenfritz J P, Blumenthal M. Effects of fosinopril on exercise tolerance and clinical deterioration in patients with chronic congestive heart failure not taking digitalis. Fosinopril Heart Failure Study Group. Am J Cardio. 1995;75(8):596-600.
Buchwald A, Unterberg C, van der Does R, Wiegand V. [Acute hemodynamic effects of the vasodilator beta blocker carvedilol in heart failure]. Z Kardiol. 1990;79(6):424-8. [pmid: 1974100].
Bulpitt C J, Fletcher A E, Dossegger L, Neiss A, Nielsen T, Viergutz S. Quality of life in chronic heart failure: cilazapril and captopril versus placebo. Cilazapril-Captopril Multicentre Group. Heart. 1998;79(6):593-8. [pmid: 10078088]. [pmcid: 1728718].
Bussmann W D, Storger H, Hadler D, et al. Long-term treatment of severe chronic heart failure with captopril: a double-blind randomized, placebo-controlled long-term study. J Cardiovasc Pharmacol. 1987;9(suppl. 2):S50-S60. [pmid: 2441202].
Califf R M, Adams K F, McKenna W J, Gheorghiade M, Uretsky B F, McNulty S E, et al. A randomized controlled trial of epoprostenol therapy for severe congestive heart failure: The Flolan International Randomized Survival Trial (FIRST). Am Heart J. 1997;134(1):44-54. [pmid: 9266782].
Captopril-Digoxin Multicenter Research Group. Comparative effects of therapy with captopril and digoxin in patients with mild to moderate heart failure. The Captopril-Digoxin Multicenter Research Group. JAMA. 1988;259(4):539-44. [pmid: 2447297].
Captopril Multicenter Research Group. A placebo-controlled trial of captopril in refractory chronic congestive heart failure. J Am Coll Cardiol. 1983;63:755-763. [pmid: 6350401].
Carson P, Ziesche S, Johnson G, Cohn J N. Racial differences in response to therapy for heart failure: analysis of the vasodilator-heart failure trials. Vasodilator-Heart Failure Trial Study Group. J Card Fail. 1999;5(3):178-87. [pmid: 10496190].
Chalmers J P, West M J, Cyran J, De La Torre D, Englert M, Kramar M, et al. Placebo-controlled study of lisinopril in congestive heart failure: a multicentre study. J Cardiovasc Pharmacol. 1987;9(Suppl 3):pS89-97. [pmid: 2442560].
Chantrel F, Moulin B, Hannedouche T. Blood pressure, diabetes and diabetic nephropathy. Diabetes Metab. 2000;26(Suppl 4):37-44. [pmid: 10922972].
Chizzola P R, Freitas H F, Caldas M A, da Costa J M, Meneghetti C, Marinho N V, et al. Effects of carvedilol in heart failure due to dilated cardiomyopathy. Results of a double-blind randomized placebo-controlled study (CARIBE study). Arquivos Brasileiros De Cardiologia. 2000;74(3):p233-42. [pmid: 10951826].
Chrysant S G, Gollub S, Dunn M I, et al. Hemodynamic and metabolic effects of enalapril in patients with heart failure. Clin Cardiol. 1985;8:585-590. [pmid: 2998663].
CIBIS Investigators and Committees, A randomized trial of beta-blockade in heart failure. The Cardiac Insufficiency Bisoprolol Study (CIBIS). Circulation. 1994;90(4) p1765–73.
CIBIS II Investigators and Committee, The Cardiac Insufficiency Bisoprolol Study II (CIBIS-II): a randomised trial. Lancet 1999;353(9146):9–13.
The CIBIS II Scientific Committee. Design of the cardiac insufficiency bisoprolol study II (CIBIS II). Fund Clin Pharmacol. 1997;11:38-42.
Cice G, Tagliamonte E, Ferrara L, Iacono A. Efficacy of carvedilol on complex ventricular arrhythmias in dilated cardiomyopathy: double-blind, randomized, placebo-controlled study. Eur Heart J. 2000;21(15):1259-64. [pmid: 10924316].
Circo A, Platania F, Mangiameli S, Putignano E. Multicenter, randomized, placebo-controlled, double-blind study of the safety and efficacy of oral delapril in patients with congestive heart failure. Am J Cardiol. 1995;75(18):18F-24F. [pmid: 7778529].
Cleland J G, Armstrong P, Horowitz J D, Massie B, Packer M, Poole-Wilson P A, et al. Baseline clinical characteristics of patients recruited into the assessment of treatment with lisinopril and survival study. Eur J Heart Fail. 1999;1(1):73-9. [pmid: 10937983].
Cleland J G, Dargie H J, Gillen G, Robertson I, East B W, Ball S G, et al. Captopril in heart failure: a double-blind study of the effects on renal function. J Cardiovasc Pharmacol. 1986;8(4):700-6. [pmid: 2427807].
Cleland J G, Erhardt L, Murray G, Hall A S, Ball S G. Effect of ramipril on morbidity and mode of death among survivors of acute myocardial infarction with clinical evidence of heart failure. A report from the AIRE Study Investigators. Eur Heart J. 1997;18(1):41-51. [pmid: 9049514].
Cleland J G, Pennel D, Ray S, Murray G, MacFarlane P, Cowley A, et al. The carvedilol hibernation reversible ischaemia trial; marker of success (CHRISTMAS). The CHRISTMAS Study Steering Committee and Investigators. Eur J Heart Fail. 1999;1(2):191-6. [pmid: 10937930].
Cleland J G, Tendera M, Adamus J, Freemantle N, Gray C S, Lye M, et al. Perindopril for elderly people with chronic heart failure: the PEP-CHF study. The PEP investigators. Eur J Heart Fail. 1999;1(3):p211-7. [pmid: 10935667].
Cleland J G F, Dargie H J, Hodsman G P, et al. Captopril in heart failure: a double blind controlled trial. Br Heart J. 1984;52:530-5. [pmid: 6388612]. [pmcid: 481676].
Cleland J G F, Dargie H J, Ball S G, et al. Effects of enalapril in heart failure: a double blind study of effects on exercise performance, renal function, hormones, and metabolic state. Br Heart J. 1985;54:305-311. [pmid: 2994698]. [pmcid: 481900].
Cleland J G F, Shah D, Krikler S, Frost G, Oakley C M. Angiotensin-converting enzyme-inhibitors, left-ventricular dysfunction, and early heart-failure. Am J Cardio. 1992;70(N10. OCT 8)::C55-C61.
Clement D L, De Buyzere M, Tomas M, Vanavermaete G. Long-term effects of clinical outcome with low and high dose in the Captopril in Heart Insufficient Patients Study (CHIPS). Acta Cardiol. 2000;55(1):1-7. [pmid: 10707752].
Cohn J N, Archibald D G, Ziesche S, et al. Effects of vasodilator therapy on mortality in chronic congestive heart failure. N Engl J Med. 1986;314:1547-1552. [pmid: 3520315].
Cohn J N, Fowler M B, Bristow M R, Colucci W S, Gilbert E M, Kinhal V, et al. Safety and efficacy of carvedilol in severe heart failure. The U.S. Carvedilol Heart Failure Study Group. Journal of Cardiac Failure. 1997;3(3):p173-9. [pmid: 9330125].
Cohn J N, Goldstein S O, Greenberg B H, Lorell B H, Bourge R C, Jaski B E, et al. A dose-dependent increase in mortality with vesnarinone among patients with severe heart failure. Vesnarinone Trial Investigators. N Engl J Med. 1998;339(25):1810-6. [pmid: 9854116].
Cohn J N, Johnson G, Ziesche S, et al. A comparison of enalapril with hydralazine-isosorbide dinitrate in the treatment of chronic congestive heart failure. N Engl J Med. 1991;325:303-10. [pmid: 2057035].
Cohn J N, Tognoni G, Glazer R D, Spormann D, Hester A. Rationale and design of the Valsartan Heart Failure Trial: a large multinational trial to assess the effects of valsartan, an angiotensin-receptor blocker, on morbidity and mortality in chronic congestive heart failure. J Card Fail. 1999;5(2):155-60. [pmid: 10404355].
Colfer H T, Ribner H S, Gradman A, Hughes C V, Kapoor A, Laidlaw J C. Effects of once-daily benazepril therapy on exercise tolerance and manifestations of chronic congestive heart failure. The Benazepril Heart Failure Study Group. Am J Cardio. 1992;70(3):p354-8.
Colfer H T, Ribner H S, Gradman A, et al. Effects of once-daily benazepril therapy on exercise tolerance and manifestations of chronic congestive heart failure. Am J Cardiol. 1992;70:354-358. [pmid: 1632402].
Colucci W S, Packer M, Bristow M R, Gilbert E M, Cohn J N, Fowler M B, et al. Carvedilol inhibits clinical progression in patients with mild symptoms of heart failure. Circulation. 1996;94:280-2806. [pmid: 8941105].
Colucci W S, Sonnenblick E H, Adams K F, Berk M, Brozena S C, Cowley A J, et al. Efficacy of phosphodiesterase inhibition with milrinone in combination with converting enzyme inhibitors in patients with heart failure. The Milrinone Multicenter Trials Investigators. J Am Coll Cardiol. 1993;22(4 Suppl A):113A-118A. [pmid: 8376682].
Colucci W S, Wynne J, Holman B L, et al. Long-term therapy of heart failure with prazosin: a randomized double blind trial. Am J Cardiol. 1980;45:337-344. [pmid: 6766650].
Comstock G W. An epidemiological study of blood pressure levels in a biracial community in the southern United States. Am J Hygiene. 1957;65:271-315.
Conradson T B. Hydralazine vs. placebo in CHF-preliminary results from a multicenter long-term study in Sweden. Acta Med Scand. 1981;652(suppl):177-180.
Copie X, Pousset F, Lechat P, Jaillon P, Guize L, Le Heuzey J Y. Effects of beta-blockade with bisoprolol on heart rate variability in advanced heart failure: analysis of scatterplots of R-R intervals at selected heart rates. Am Heart J. 1996;132(2 Pt 1):369-75. [pmid: 8701900].
Coughlin S S, Myers L, Michaels R K. What explains black-white differences in survival in idiopathic dilated cardiomyopathy? The Washington, DC, dilated cardiomyopathy study. Journal of the National Medical Association. 1997;89(N4):277-282. [pmid: 9145633].
Council on Ethical and Judicial Affairs. Black-white disparities in health. JAMA. 1990;263:2344-6. [pmid: 2182918].
Cowley A J, Stainer K, Wynne R D, Rowley J M, Hampton J R. Comparison of the effects of captopril and enoximone in patients with severe heart failure: a placebo controlled double-blind study. Int J Cardiol. 1989;24(3):311-6. [pmid: 2527829].
Creager M A, Massie B M, Fascon D P, et al. Acute and long-term effects of Enalapril on the cardiovascular response to exercise and exercise tolerance in patients with congestive heart failure. JACC. 1985;6:163-70. [pmid: 2989349].
Cucchini F, Compostella L, Papalia D, de Domenico R, Iavernaro A, Zeppellini R. [Chronic treatment of dilated cardiomyopathy by beta blocking agents. Clinical and hemodynamic follow-up]: <Original> Trattamento cronico della cardiomiopatia dilatativa con betabloccanti. Controllo clinico ed emodinamico a distanza. Giornale Italiano Di Cardiologia. 1988;18(10):p835-42. [pmid: 2907743].
Currie P J, Kelly M J, McKenzie A, Harper R W, Lim Y L, Federman J, et al. Oral beta-adrenergic blockade with metoprolol in chronic severe dilated cardiomyopathy. J Am Coll Cardiol. 1984;3(1):203-9. [pmid: 6140277].
Davies R F, Beanlands D S, Nadeau C, Phaneuf D, Morris A, Arnold J M, et al. Enalapril versus digoxin in patients with congestive heart failure: a multicenter study. Canadian Enalapril Versus Digoxin Study Group. J Am Coll Cardiol. 1991;18(7):1602-9. [pmid: 1960303].
Debock V D, Mets T, Romagnoli M, Derde M P. Captopril treatment of chronic heart-failure in the very old. Journals of Gerontology. 1994;49(N3. MAY)::M148-M152. [pmid: 8169337].
Denis B, Machecourt J. Renitec et insuffisance cardiaque. Tempo Medical. 1985;5:40-3.
Dickstein K, Aarsland T. Effect on exercise performance of enalapril therapy initiated early after myocardial infarction. Nordic Enalapril exercise Trial. J Am Coll Cardiol. 1993;22(4):975-83. [pmid: 8409072].
Dickstein K, Barvik S, Aarsland T. Effect of long-term enalapril therapy on cardiopulmonary exercise performance in men with mild heart failure and previous myocardial infarction. J Am Coll Cardiol. 1991;18:596-602. [pmid: 1856429].
Diercks G F, Janssen W M, van Boven A J, Bak A A, de Jong P E, Crijns H J, et al. Rationale, design, and baseline characteristics of a trial of prevention of cardiovascular and renal disease with fosinopril and pravastatin in nonhypertensive, nonhypercholesterolemic subjects with microalbuminuria (the Prevention of REnal and Vascular ENdstage Disease Intervention Trial PREVEND IT). Am J Cardiol. 2000;86(6):635-8. [pmid: 10980214].
Dorszewski A, Gohmann E, Dorszewski B, Werner G S, Kreuzer H, Figulla H R. Vasodilation by urapidil in the treatment of chronic congestive heart failure in addition to angiotensin-converting enzyme inhibitors is not beneficial: results of a placebo-controlled, double-blind study. Journal of Cardiac Failure. 1997;3(2):p91-6. [pmid: 9220308].
Dossegger L, Bernink, Braun, Burger, Calvert, Deimann, et al. Comparison of the effects of cilazapril and captopril versus placebo on exercise testing in chronic heart-failure patients—a double-blind, randomized, multicenter trial. Cardiology. 1995;86(S1):34-40. [pmid: 7728786].
Doughty R N, Whalley G A, Gamble G, MacMahon S, Sharpe N. Left ventricular remodeling with carvedilol in patients with congestive heart failure due to ischemic heart disease. Australia-New Zealand Heart Failure Research Collaborative Group. J Am Coll Cardiol. 1997;29(5):1060-6. [pmid: 9120160].
Doughty R N, Whalley G A, Gamble G, MacMahon S, Sharpe N. Effects of carvedilol on left ventricular regional wall motion in patients with heart failure caused by ischemic heart disease. Australia-New Zealand Heart Failure Research Collaborative Group. J Card Fail. 2000;6(1):11-8. [pmid: 10746814].
Doval H C, Nul D R, Grancelli H O, Perrone S V, Bortman G R, Curiel R. Randomised trial of low-dose amiodarone in severe congestive heart failure. Grupo de Estudio de la Sobrevida en la Insuficiencia Cardiaca en Argentina (GESICA). Lancet. 1994;344(8921):493-8. [pmid: 7914611].
Drexler H, Banhardt U, Meinertz T, Wollschlager H, Lehmann M, Just H. Contrasting peripheral short-term and long-term effects of converting enzyme inhibition in patients with congestive heart failure. A double-blind, placebo-controlled trial. Circulation. 1989;79(3):p491-502. [pmid: 2521816].
Dries DL, Exner DV, Gersh J, Cooper HA, Carson PE, Domanski MJ. Racial differences in the outcome of left ventricular dysfunction [published erratum appears in N Engl J Med 1999 Jul 22;341(4):298]. N Engl J Med. 1999;340(8):609–16.
Dries D L, Exner D V, Domanski M J, Greenberg B, Stevenson L W. The prognostic implications of renal insufficiency in asymptomatic and symptomatic patients with left ventricular systolic dysfunction. J Am Coll Cardiol. 2000;35(3):p681-9. [pmid: 10716471].
East MA, Peterson ED, Shaw LK, et al. Racial differences in the outcome of patients with diastolic heart failure: Results from the Duke Databank of Cardiovascular Disease. Circulation. 2000;102 (suppl)(18).
Eichhorn EJ, Domanski MJ, Adams K, et al. Effect of beta-blockade on mortality in African-Americans: The beta-blocker evaluation of survival trial. Circulation. 2000;102 (suppl 2)(18).
Eichhorn EJ, Domanski MJ, Bristow MR, et al. Hemodynamic, myocardial functional and neurohormonal responses to beta-blockade in Black vs. Non-Black patients in BEST. Circulation. 2000;102 (suppl II)(18).
Eichhorn E J, Heesch C M, Barnett J H, Alvarez L G, Fass S M, Grayburn P A, et al. Effect of metoprolol on myocardial function and energetics in patients with nonischemic dilated cardiomyopathy: a randomized, double-blind, placebo-controlled study. J Am Coll Cardiol. 1994;24(5):1310-20. [pmid: 7930255].
Enalapril CHF Investigators. Long-term effects of enalapril in patients with congestive heart failure: a multicenter, placebo-controlled trial. Heart Failure. 1987;3:102-107.
Engelmeier R S, O'Connell J B, Walsh R, Rad N, Scanlon P J, Gunnar R M. Improvement in symptoms and exercise tolerance by metoprolol in patients with dilated cardiomyopathy: a double-blind, randomized, placebo-controlled trial. Circulation. 1985;72(3):p536-46. [pmid: 3893793].
Erdmann E, Lechat P, Verkenne P, Wiemann H. Results from post-hoc analyses of the CIBIS II trial: effect of bisoprolol in high-risk patient groups with chronic heart failure. Euro J Heart Failure. 2001;3:469-479.
Eriksson SV, Offstad J, Kjekshus J. M-mode echocardiography in patients with severe congestive heart failure. A subgroup analysis in the Cooperative North Scandinavian Enalapril Survival Study (CONSENSUS). Drugs. 1990;39 Suppl 4:43–8; discussion 53–4.
Erlemeier H H, Kupper W, Bleifeld W. Comparison of hormonal and haemodynamic changes after long-term oral therapy with pimobendan or enalapril--a double-blind randomized study. Eur Heart J. 1991;12(8):889-99. [pmid: 1915427].
Exner D V, Dries D L, Domanski M J, Cohn J N. Lesser response to angiotensin-converting-enzyme inhibitor therapy in black as compared with white patiens with left ventricular dysfunction. N Eng J Med. 2001;344(18):1351-7.
Exner DV, Dries DL, Domanski MJ, et al. Enalapril therapy and outcome in Black versus White patients enrolled in the studies of left ventricular dysfunction. Circulation. 2000;102(18).
Fagan T C. Diltiazem: its place in the antihypertensive armamentarium. J Cardiovasc Pharmacol. 1991;18(Suppl 9):S26-31. [pmid: 1725539].
Fagerberg B. Screening, endpoint classification, and safety monitoring in the Metoprolol CR/XL Randomised Intervention Trial in Congestive Heart Failure (MERIT-HF). Eur J Heart Fail. 2000;2(3):315-24. [pmid: 10938494].
Fang J, Madhavan S, Alderman M H. The association between birthplace and mortality from cardiovascular causes among black and white residents of New York City. N Engl J Med. 1996;335:1545-51. [pmid: 8900086].
Figulla H R, Luig H, Nieschlag F, Kreuzer H. [Clinical and hemodynamic effects of nisoldipine and captopril in heart failure: a double-blind comparative study of long and short-term effects]. Z Kardiol. 1987;76(3):167-74. [pmid: 3109142].
Fisher M L, Gottlieb S S, Plotnick G D, Greenberg N L, Patten R D, Bennett S K, et al. Beneficial effects of metoprolol in heart failure associated with coronary artery disease: a randomized trial. J Am Coll Cardiol. 1994;23(4):p943-50. [pmid: 8106700].
Flather M D, Yusuf S, Kober L, Pfeffer M, Hall A, Murray G, et al. Long-term ACE-inhibitor therapy in patients with heart failure or left-ventricular dysfunction: a systematic overview of data from individual patients. ACE-Inhibitor Myocardial Infarction Collaborative Group. Lancet. 2000;355(9215):p1575-81. [pmid: 10821360].
Fletcher A E, Bulpitt C J, Chase D M, Collins W C, Furberg C D, Goggin T K, et al. Quality of life with three antihypertensive treatments. Cilazapril, atenolol, nifedipine. Hypertension. 1992;19(6 Pt 1):499-507. [pmid: 1534312].
Forman D E, Chander R B, Lapane K L, Shah P, Stoukides J. Evaluating the use of angiotensin-converting enzyme inhibitors for older nursing home residents with chronic heart failure. JAGS. 1998;46(12):p1550-4.
Franciosa J A, Cohn J N. Sustained hemodynamic effects without tolerance during lon-term isosorbide dinitrate treatment of chronic left ventricular failure. Am J Cardiol. 1980;45:648-654. [pmid: 6766653].
Franciosa J A, Jordan R A, Wilen M M, et al. Minoxidil in patients with chronic left heart failure: contrasting hemodynamic and clinical effects in a controlled trial. Circulation. 1984;70:63-68. [pmid: 6373050].
Franciosa J A, Nordstrom L A, Cohn J N. Nitrate therapy for congestive heart failure. JAMA. 1978;240:443-446. [pmid: 351232].
Franciosa J A, Weber K T, Levine T B, et al. Hydralazine in the long-term treatment of chronic heart failure: lack of difference from placebo. Am Heart J. 1982;104:587-594. [pmid: 7051796].
Franciosa J A, Wilen M M, Jordan R A. Effects of enalapril, a new angiotensin-converting enzyme inhibitor, in a controlled trial in heart failure. J Am Coll Cardiol. 1985;5(1):p101-7. [pmid: 2981088].
Francis C K. Report of the NHLBI working group on research in coronary heart disease in blacks: Issues and challenges. J Nat Med Assoc. 1995;87(suppl):597-603.
Francis C K. Heart failure in elderly African-Americans. Am J Geriatr Cardiol. 1997;6(5):50-68. [pmid: 11416429].
Fuchs W. Comparison of the safety and efficacy of delapril with captopril in outpatients with congestive heart failure. Am J Cardiol. 1995;75(18):29F-36F. [pmid: 7778531].
Funck-Brentano C, Lancar R, Le Heuzey J Y, Lardoux H, Soubrie C, Lechat P. Predictors of medical events in patients enrolled in the cardiac insufficiency bisoprolol study (CIBIS): a study of the interactions between beta-blocker therapy and occurrence of critical events using analysis of competitive risks. Am Heart J. 2000;139(2 Pt 1):p262-71. [pmid: 10650299].
Gallagher E J, Viscoli C M, Horwitz R i I. The relationship of treatment adherence to the risk of death after myocardial-infarction in women. JAMA. 1993;270(N6):742-744. [pmid: 8336377].
Gambassi G, Forman D E, Lapane K L, Mor V, Sgadari A, Lipsitz L A, et al. Management of heart failure among very old persons living in long-term care: has the voice of trials spread? The SAGE Study Group. Am Heart J. 2000;139(1 Pt 1):p85-93. [pmid: 10618567].
Gambassi G, Lapane K L, Sgadari A, Carbonin P, Gatsonis C, Lipsitz L A, et al. Effects of angiotensin-converting enzyme inhibitors and digoxin on health outcomes of very old patients with heart failure. SAGE Study Group. Systematic Assessment of Geriatric drug use via Epidemiology. Arch Intern Med. 2000;160(1):p53-60. [pmid: 10632305].
Garg R, Yusuf S. Overview of randomized trials of angiotensin-converting enzyme inhibitors on mortality and morbidity in patients with heart failure. JAMA. 1995;273(18):1450-1456. [pmid: 7654275].
Gattis W A, Hasselblad V, Whellan D J, O'Connor C M. Reduction in heart failure events by the addition of a clinical pharmacist to the heart failure management team: results of the Pharmacist in Heart Failure Assessment Recommendation and Monitoring (PHARM) Study. Arch Intern Med. 1999;159(16):1939-45. [pmid: 10493325].
Gattis W A, Larsen R L, Hasselblad V, Bart B A, O'Connor C M, et al. Is optimal angiotensin-converting enzyme inhibitor dosing neglected in elderly patients with heart failure?. Am Heart J. 1998;136(1):p43-8. [pmid: 9665217].
Gavazzi A, Marioni R, Campana C, Montemartini C. Comparative trial of quinapril versus captopril in mild to moderate congestive heart failure. Quinapril/Captopril Congestive Heart Failure Study Group. J Hypertens Suppl. 1994;12(4):S89-93. [pmid: 7965279].
Genth-Zotz S, Zotz R J, Sigmund M, Hanrath P, Hartmann D, Bohm M, et al. MIC trial: metoprolol in patients with mild to moderate heart failure: effects on ventricular function and cardiopulmonary exercise testing. Eur J Heart Fail. 2000;2(2):p175-81. [pmid: 10856731].
Geronimus A T, Bound J, Waidmann T A, et al. Excess mortality among blacks and whites in the United States. N Engl J Med. 1996;335:1552-8. [pmid: 8900087].
Gerstein H C, Yusuf S, Mann J F E, Hoogwerf B, Zinman B, Held C, et al. Effects of ramipril on cardiovascular and microvascular outcomes in people with diabetes mellitus: results of the hope study and micro-hope substudy. Lancet. 2000;355(N9200. JAN 22)::253-259. [pmid: 10675071].
Ghali J K, Kadakia S, Cooper R, et al. Precpitating factors leading to decompensation of heart failure: traits among urban blacks. Arch Intern Med. 1988;148:2013-6. [pmid: 3046541].
Ghali J K, Pina I L, Gottlieb S S, et al. Metoprolol CR/XL in female patients with heart failure: analysis of the experience in Metoprolol Extended-Release Randomized Intervention Trial in Heart Failure (MERIT-HF). Circulation. 2002;105(13):1585-91. [pmid: 11927527].
Gheorghiade M, Benatar D, Konstam M A, Stoukides C A, Bonow R O. Pharmacotherapy for systolic dysfunction: a review of randomized clinical trials. Am J Cardio. 1997;80(N8B,SI):H14-H27.
Ghose J C, Chakraborty S, Mondal M, Bhandari B. Effect of vasodilator therapy on mortality in chronic congestive heart failure. Journal of the Association of Physicians of India. 1993;41(5):p269-71. [pmid: 8300456].
Gilbert E M, Anderson J L, Deitchman D, Yanowitz F G, O'Connell J B, Renlund D G, et al. Long-term beta-blocker vasodilator therapy improves cardiac function in idiopathic dilated cardiomyopathy: a double-blind, randomized study of bucindolol versus placebo. Am J Med. 1990;88(3):p223-9. [pmid: 1968710].
Giles T D. Lisinopril Chronic Heart Failure Group. Lisinopril treatment of congestive heart failure-results of a placebo controlled trial. Circulation. 1990;82(suppl 4)::III-323.
Giles T D, Katz R, Sullivan J M, Wolfson P, Haugland M, Kirlin P, et al. Short- and long-acting angiotensin-converting enzyme inhibitors: a randomized trial of lisinopril versus captopril in the treatment of congestive heart failure. The Multicenter Lisinopril-Captopril Congestive Heart Failure Study Group. J Am Coll Cardiol. 1989;13(6):1240-7. [pmid: 2539403].
Gilligan D M, Chan W L, Joshi J, Clarke P, Fletcher A, Krikler S, et al. A double-blind, placebo-controlled crossover trial of nadolol and verapamil in mild and moderately symptomatic hypertrophic cardiomyopathy. J Am Coll Cardiol. 1993;21(7):1672-9. [pmid: 8496536].
Gillum R F. The epidemiology of cardiovascular disease in black Americans [editorial; comment]. N Engl J Med. 1996;335(21):1597-9. [pmid: 8900095].
Gillum R F. Coronary heart disease in black populations. I. Mortality and morbidity. Am Heart J. 1982;104:839-51. [pmid: 7124597].
Gillum R F. Epidemiology of hypertension in African American women. Am Heart J. 1986;131:385-95. [pmid: 8579038].
Gillum R F. Stroke in blacks. Stroke. 1988;19:1-9. [pmid: 3276035].
Gillum R F. Sudden coronary death in the United States. Circulation. 1989;79:756-65. [pmid: 2924409].
Gillum RF. Cardiovascular disease in the United States: an epidemiologic overview. Saunders E. (editor): Cardiovascular Diseases in Blacks. Philadelphia: F.A. Davis, 1991;3–16.
Gillum R F. Epidemiology of heart failure in the United States. Am Heart J. 1993;126:1042-1047. [pmid: 8213434].
Gillum R F. Trends in acute myocardial infarction and coronary heart disease death in the United States. J Am Coll Cardiol. 1994;23:1273-7. [pmid: 8176083].
Gillum R F, Ingram D I. The relation between residence in the Southeast region of the United States and stroke incidence and death: the NHANES I Epidemiologic Follow-up Study. Am J Epidemiol. 1996;144:665-73. [pmid: 8823063].
Goldstein S, Hjalmarson A. The mortality effect of metoprolol CR/XL in patients with heart failure: results of the MERIT-HF Trial. Clinical Cardiology. 1999;22(Suppl 5):pV30-5. [pmid: 10526701].
Gordon M. Evaluation of the Efficacy and Safety of Ramipril (HOE 498) in Patients with Congestive Heart Failure in a Placebo-controlled Trial.(unpublished report) 1991.
Gottlieb S S, McCarter R J, Vogel R A. Effect of beta-blockers on mortality among high risk and low risk patients after myocardial infarction. N Engl J Med. 1998;339:489-97. [pmid: 9709041].
Gretler D D, Fumo M T, Nelson K S, et al. Ethnic differences in circadian hemodynamic profile. Am J Hypertens. 1994;7:7-14. [pmid: 8136114].
Gundersen T, Wiklund I, Swedberg K, Amtorp O, Remes J, Nilsson B. Effects of 12 weeks of ramipril treatment on the quality of life in patients with moderate congestive heart failure: results of a placebo-controlled trial. Ramipril Study Group. Cardiovascular Drugs and Therapy. 1995;9(4):p589-94. [pmid: 8547209].
Gustafsson I, Torppedersen C, Kober L, Gustafsson F, Hildebrandt P. Effect of the angiotensin-converting enzyme inhibitor trandolapril on mortality and morbidity in diabetic patients with left ventricular dysfunction after acute myocardial infarction. J Am Coll Cardiol. 1999;34(N1. JUL)::83-89. [pmid: 10399995].
Habte B. The efficacy of hydrochlorothiazide, timolol and enalapril in Ethiopians with essential hypertension. Ethiop Med J. 1992;30(3):163-7. [pmid: 1396619].
Hager W D, Davis B R, Riba A, Moye L A, Wun C C, Rouleau J L, et al. Absence of a deleterious effect of calcium channel blockers in patients with left ventricular dysfunction after myocardial infarction: The SAVE Study Experience. SAVE Investigators. Survival and Ventricular Enlargement. Am Heart J. 1998;135(3):406-13. [pmid: 9506325].
Hahn B, Strauer B E. The influence of beta-adrenoceptor blockade on left ventricular function. Br J Clin Pharmacol. 1982;13(Suppl 2):305S-307S. [pmid: 6125181]. [pmcid: 1402147].
Haiat R, Piot O, Gallois H, Hanania G. Blood pressure response to the first 36 hours of heart failure therapy with perindopril versus captopril. French General Hospitals National College of Cardiologists. J Cardiovasc Pharmacol. 1999;33(6):953-9. [pmid: 10367600].
Hall A S, Murray G D, Ball S G. Follow-up study of patients randomly allocated ramipril or placebo for heart failure after acute myocardial infarction: AIRE Extension (AIREX) Study. Acute Infarction Ramipril Efficacy. Lancet. 1997;349(9064):1493-7. [pmid: 9167457].
Hall A S, Winter C, Bogle S M, et al. The Acute Infarction Ramipril Efficacy (AIRE) Study: rationale, design, organization, and outcome definitions. J Cardiovasc Pharmacol. 1991;18(Suppl 2):S105-S109. [pmid: 1725016].
Hall S A, Cigarroa C G, Marcoux L, Risser R C, Grayburn P A, Eichhorn E J. Time course of improvement in left ventricular function, mass and geometry in patients with congestive heart failure treated with beta-adrenergic blockade. J Am Coll Cardiol. 1995;25(5):1154-61. [pmid: 7897129].
Hall W D, Kusek J W, Kirk K A, Appel L J, Schulman G, Agodoa L Y, et al. Short-term effects of blood pressure control and antihypertensive drug regimen on glomerular filtration rate: the African-American study of kidney disease and hypertension pilot study. American Journal of Kidney Diseases. 1997;29(N5):720-728. [pmid: 9159306].
Hammond I W, Alderman M H, Devereux R B. Contrast in cardiac anatomy and function between black and white patients with hypertension. J Natl Med Assoc. 1984;76:247-255. [pmid: 6716499].
Hampton J R. Choosing the right beta-blocker. A guide to selection. Drugs. 1994;48(4):549-68. [pmid: 7528129].
Han Y L, Tong M, Jing Q m, Hu X L, Liu J Q. Combined therapy of captopril and spironolactone for refractory congestive-heart-failure. Chinese Medical Journal. 1994;107(N9. SEP)::688-692. [pmid: 7805462].
Hansen J F, Hagerup L, Sigurd B, Pedersen F, Mellemgaard K, Pedersen-Bjergaard O, et al. Cardiac event rates after acute myocardial infarction in patients treated with verapamil and trandolapril versus trandolapril alone. Danish Verapamil Infarction Trial (DAVIT) Study Group. Am J Cardiol. 1997;79(6):738-41. [pmid: 9070551].
Harper R W, Calzton H, Middlebrook K, et al. The acute and chronic haemodynamic effects of prazosin in severe congestive heart failure. Med J Aust. 1980;2(suppl):36-38. [pmid: 7421721].
Hasford J, Bussmann W D, Delius W, Kopcke W, Lehmann K, Weber E. Design and analysis of the HYPREN-trial: safety of enalapril and prazosin in the initial treatment phase of patients with congestive heart failure. Z Kardiol. 1991;80(Suppl 2):21-7. [pmid: 2024540].
Havranek E P, Abrams F, Stevens E, Parker K. Determinants of mortality in elderly patients with heart failure: the role of angiotensin-converting enzyme inhibitors. Arch Intern Med. 1998;158(18):2024-8. [pmid: 9778202].
Haywood I J. Coronary heart disease mortality/morbidity and risk in blacks. I. Clinical manifestations and diagnostic criteria: the experience with the Beta Blocker Heart Attack Trial. Am Heart J. 1984;108:787-93. [pmid: 6148005].
He J, Whelton P K. Epidemiology and prevention of hypertension. Med Clin North Am. 1997;81(5):1077-97. [pmid: 9308599].
Heidenreich P A, Lee T T, Massie B M. Effect of beta-blockade on mortality in patients with heart failure: a meta-analysis of randomized clinical trials. J Am Coll Cardiol. 1997;30:27-34. [pmid: 9207617].
Herholz H, Goff D C, Ramsey D J, Chan F A, Ortiz C, Labarthe D R, et al. Women and Mexican Americans receive fewer cardiovascular drugs following myocardial infarction than men and non-Hispanic whites: the Corpus Christi Heart Project, 1988-1990. J Clin Epidemiol. 1996;49(3):279-87. [pmid: 8676174].
Herlitz J. Comparison of lisinopril versus digoxin for congestive heart failure during maintenance diuretic therapy. The Lisinopril-Digoxin Study Group. Am J Cardiol. 1992;70(10):84C-90C. [pmid: 1329479].
Herlitz J, Waagstein F, Lindqvist J, Swedberg K, Hjalmarson A. Effect of metoprolol on the prognosis for patients with suspected acute myocardial infarction and indirect signs of congestive heart failure (a subgroup analysis of the Goteborg Metoprolol Trial). Am J Cardio. 1997;80(9B):p40J-44J.
Herrlin B, Nyquist O, Sylven C. Induction of a reduction in haemoglobin concentration by enalapril in stable, moderate heart failure: a double blind study. Br Heart J. 1991;66(3):199-205. [pmid: 1931347]. [pmcid: 1024644].
Herrlin B, Sylven C, Nyquist O, Edhag O. Short term haemodynamic effects of converting enzyme inhibition before and after eating in patients with moderate heart failure caused by dilated cardiomyopathy: a double blind study. Br Heart J. 1990;63(1):26-31. [pmid: 2178657]. [pmcid: 1024310].
Higginbotham M B, Morris K G, Bramlet D A, et al. Long-term ambulatory therapy with prazosin vs. placebo for chronic heart failure: relation between clinical response and left ventricular function at rest and during exercise. Am J Cardiol. 1983;52:782-788. [pmid: 6353898].
Hjalmarson A, Goldstein S, Fagerberg B, Wedel H, Waagstein F, Kjekshus J, et al. Effects of controlled-release metoprolol on total mortality, hospitalizations, and well-being in patients with heart failure: the Metoprolol CR/XL Randomized Intervention Trial in congestive heart failure (MERIT-HF). MERIT-HF Study Group. JAMA. 2000;283(10):1295-302. [pmid: 10714728].
Hjalmarson A, Goldstein S, Fagerberg B, Wedel H, Waagstein F, Kjekshus J, et al. Effect of metoprolol CR/XL in chronic heart failure: Metoprolol CR/XL Randomised Intervention Trial in Congestive Heart Failure (MERIT-HF). Lancet. 1999;353(9169):2001-2007. [pmid: 10376614].
Hobbs R E. Results of the ATLAS study. High or low doses of ACE inhibitors for heart failure?. Cleve Clin J Med. 1998;65(10):539-42. [pmid: 9830787].
Hood W B Jr, Youngblood M, Ghali J K, Reid M, Rogers W J, Howe D, et al. Initial blood pressure response to enalapril in hospitalized patients (Studies of Left Ventricular Dysfunction [SOLVD]). Am J Cardiol. 1991;68(15):1465-8. [pmid: 1746428].
The HOPE study investigators. The HOPE (Heart Outcomes Prevention Evaluation) Study: the design of a large, simple randomized trial of an angiotensin-converting enzyme inhibitor (ramipril) and vitamin E in patients at high risk of cardiovascular events. Can J Cardiol. 1996;12(2):127-37. [pmid: 8605634].
Houghton A R, Harrison M, Cowley A J. Haemodynamic, neurohumoral and exercise effects of losartan vs. captopril in chronic heart failure: results of an ELITE trial substudy. Evaluation of Losartan in the Elderly. Eur J Heart Fail. 1999;1(4):385-93. [pmid: 10937952].
Hughes C V, Wong M, Johnson G, Cohn J N. Influence of age on mechanisms and prognosis of heart failure. The V-HeFT VA Cooperative Studies Group. Circulation. 1993;87(6 Suppl)::VI111-7. [pmid: 8500242].
Hypertension detection and follow-up program cooperative group. Race, education, and prevalence of hypertension. Am J Epidemiol. 1977;106:351-361. [pmid: 920724].
The International Steering Committee. Rationale, design, and organization of the Metoprolol CR/XL Randomized Intervention Trial in Heart Failure (MERIT-HF). Am J Cardio. 1997;80(9B):p54J-58J.
Jansen R W, Gurwitz J H. Controversies surrounding the use of beta-blockers in older patients with cardiovascular-disease. Drugs & Aging. 1994;4(N3):175-183. [pmid: 7911042].
Jerie P, Kremer H J, Uhlir O, Widimsky J. [A Czech and Slovak interventional study of spirapril (the CASSIS study). A randomized, double-blind, multicenter, placebo-controlled study in chronic heart failure]: <Original> Ceska a slovenska intervencni studie se spiraprilem (studie CASSIS). Randomizovana, dvojiteslepa, multicentricka studie, kontrolovana aktivne i placebem chronickeho srdecniho selhani. Za resitele studie CASSIS. Vnitrni Lekarstvi. 1997;43(6):351-8. [pmid: 9601863].
Johnstone D, Limacher M, Rousseau M, Liang C S, Ekelund L, Herman M, et al. Clinical characteristics of patients in studies of left ventricular dysfunction (SOLVD). Am J Cardiol. 1992;70(9):894-900. [pmid: 1529944].
Joy M, Hubner P J, Thomas R D, et al. Long term use of enalapril in the treatment of patients with congestive heart failure. Int J Cardiol. 1987;16:137-44. [pmid: 3040605].
Just H, Drexler H, Taylor S H, Siegrist J, Schulgen G, Schumacher M. Captopril versus digoxin in patients with coronary artery disease and mild heart failure. A prospective, double-blind, placebo-controlled multicenter study. The CADS Study Group. Herz. 1993;18(Suppl 1):p436-43. [pmid: 8125424].
Kennedy H L, Brooks M M, Barker A H, Bergstrand R, Huther M L, Beanlands D S, et al. Beta-blocker therapy in the Cardiac Arrhythmia Suppression Trial. CAST Investigators. Am J Cardiol. 1994;74(7):674-80. [pmid: 7942525].
Keren G, Pardes A, Eschar Y, Koifman B, Scherez J, Geleranter I, et al. One-year clinical and echocardiographic follow-up of patients with congestive cardiomyopathy treated with captopril compared to placebo. Israel Journal of Medical Sciences. 1994;30(1):90-8. [pmid: 8138400].
Kjekshus J, Swedberg K. Enalapril for congestive heart failure. Am J Cardio. 1989;63(8):26D-32D.
Kleber FX, Laube A, Osterkorn K, et al. Captopril in mild to moderate heart failure after 18 months: effects on morbidity and mortality. JACC. 1987;9:42A (Abstr).
Kleber F X, Niemoller L, Doering W. Impact of converting enzyme inhibition on progression of chronic heart failure: results of the Munich Mild Heart Failure Trial. British Heart Journal. 1992;67(4):289-96. [pmid: 1389702]. [pmcid: 1024835].
Kleber F X, Reindl I, Wenzel M, Rodewyk P, Beil S, Kosloswki B, et al. Experiences with ACE inhibitors early after acute myocardial infarction. Rationale and design of the German Multicenter Study on the Effects of Captopril on Cardiopulmonary Exercise parameters post myocardial infarction (ECCE). Herz. 1993;18(Suppl 1):424-9. [pmid: 8125422].
Kleber F X, Sabin G V, Winter U J, Reindl I, Beil S, Wenzel M, et al. Angiotensin-converting enzyme inhibitors in preventing remodeling and development of heart failure after acute myocardial infarction: results of the German multicenter study of the effects of captopril on cardiopulmonary exercise parameters (ECCE). Am J Cardiol. 1997;80(3A):162A-167A. [pmid: 9293972].
Knight E L, Glynn R J, McIntyre K M, Mogun H, Avorn J. Predictors of decreased renal function in patients with heart failure during angiotensin-converting enzyme inhibitor therapy: results from the studies of left ventricular dysfunction (SOLVD). Am Heart J. 1999;138(5 Pt 1):849-55. [pmid: 10539815].
Kober L, Torp-Pedersen C, Carlsen J E, Bagger H, Eliasen P, Lyngborg K, et al. A clinical trial of the angiotensin-converting-enzyme inhibitor trandolapril in patients with left ventricular dysfunction after myocardial infarction. Trandolapril Cardiac Evaluation (TRACE) Study Group. N Engl J Med. 1995;333(25):1670-6. [pmid: 7477219].
Kober L, Torp-Pedersen C, Ottesen M, Burchardt H, Korup E, Lyngborg K. Influence of age on the prognostic importance of left ventricular dysfunction and congestive heart failure on long-term survival after acute myocardial infarction. TRACE Study Group. Am J Cardiol. 1996;78(2):158-62. [pmid: 8712136].
Konstam M A, Rousseau M F, Kronenberg M W, Udelson J E, Melin J, Stewart D, et al. Effects of the angiotensin converting enzyme inhibitor enalapril on the long-term progression of left ventricular dysfunction in patients with heart failure. SOLVD Investigators. Circulation. 1992;86(2):431-8. [pmid: 1638712].
Konstam V, Salem D, Pouleur H, Kostis J, Gorkin L, Shumaker S, et al. Baseline quality of life as a predictor of mortality and hospitalization in 5,025 patients with congestive heart failure. SOLVD Investigations. Studies of Left Ventricular Dysfunction Investigators. Am J Cardiol. 1996;78(8):890-5. [pmid: 8888661].
Kostis J B, Shelton B, Gosselin G, Goulet C, Hood W B Jr, Kohn R M, et al. Adverse effects of enalapril in the Studies of Left Ventricular Dysfunction (SOLVD). SOLVD Investigators. Am Heart J. 1996;131(2):350-5. [pmid: 8579032].
Kostis J B, Shelton B J, Yusuf S, Weiss M B, Capone R J, Pepine C J, et al. Tolerability of enalapril initiation by patients with left ventricular dysfunction: results of the medication challenge phase of the Studies of Left Ventricular Dysfunction. Am Heart J. 1994;128(2):358-64. [pmid: 8037104].
Krishnamoorthy V, Quintana H, Dali S, et al. Heart failure with preserved systolic function in African Americans: The role of diabetes mellitus and obesity. Circulation. 2000;102 (suppl 2)(18).
Krum H. Beta-blockers in heart failure. The new wave' of clinical trials. Drugs. 1999;58(2):203-10. [pmid: 10473016].
Krum H, Gu A, Wilshire-Clement M, Sackner-Bernstein J, Goldsmith R, Medina N, et al. Changes in plasma endothelin-1 levels reflect clinical response to beta-blockade in chronic heart failure. Am Heart J. 1996;131(2):337-41. [pmid: 8579030].
Krum H, Sackner-Bernstein J D, Goldsmith R L, Kukin M L, Schwartz B, Penn J, et al. Double-blind, placebo-controlled study of the long-term efficacy of carvedilol in patients with severe chronic heart failure. Circulation. 1995;92(6):1499-506. [pmid: 7664433].
Krum H, Shusterman N, MacMahon S, Sharpe N. Efficacy and safety of carvedilol in patients with chronic heart failure receiving concomitant amiodarone therapy. Australia/New Zealand Heart Failure Research Collaborative Group. J Card Fail. 1998;4(4):281-8. [pmid: 9924849].
Krum H, Tonkin A, Trotter A, Burton R, Garrett J, Lane G, et al. Effects of carvedilol, a vasodilator-beta-blocker, in patients with congestive heart failure due to ischemic heart disease. Circulation. 1995;92(2):212-218. [pmid: 7600653].
Krumholz H M, Wang Y, Parent E M, Mockalis J, Petrillo M, Radford M J. Quality of care for elderly patients hospitalized with heart failure. Arch Intern Med. 1997;157(19):2242-7. [pmid: 9343001].
Kukin M L, Mannino M M, Freudenberger R S, Kalman J, Buchholz-Varley C, Ocampo O. Hemodynamic comparison of twice daily metoprolol tartrate with once daily metoprolol succinate in congestive heart failure. J Am Coll Cardiol. 2000;35(1):45-50. [pmid: 10636257].
Kumanyika S. Improving our diet - still a long way to go. N Engl J Med. 1996;335:236-52. [pmid: 8703177].
Lang R M, Elkayam U, Yellen L G, Krauss D, McKelvie R S, Vaughan D E, et al. Comparative effects of losartan and enalapril on exercise capacity and clinical status in patients with heart failure. The Losartan Pilot Exercise Study Investigators. J Am Coll Cardiol. 1997;30(4):983-91. [pmid: 9316528].
Lanska D J, Peterson P M. Effects of interstate migration on the geographic distribution of stroke mortality in the United States. Stroke. 1995;26:554-61. [pmid: 7709396].
Lechat P, Escolano S, Golmard J L, Lardoux H, Witchitz S, Henneman J A, et al. Prognostic value of bisoprolol-induced hemodynamic effects in heart failure during the Cardiac Insufficiency BIsoprolol Study (CIBIS). Circulation. 1997;96(7):2197-205. [pmid: 9337190].
Lechat P, Garnham J, Desche P, et al. Efficacy and acceptability of preindopril in mild to moderate chronic congestive heart failure. Am Heart J. 1993;126:798-826. [pmid: 8166887].
Lechat P, Packer M, Chalon S, et al. Clinical effects of beta-adrenergic blockade in chronic heart failure: a meta-analysis of double-blind, placebo-controlled, randomized clinical trials. Circulation. 1998;98:1184-91. [pmid: 9743509].
Lee D K, Marantz P R, Devereux R B. Left ventricular hypertrophy in black and white hypertensives. Standard electrocardiographic criteria overestimate racial differences. J Am Med Assoc. 1992;267:3294-3299.
Leier C V, Huss P, Magorien R D, et al. Improved exercise capacity and differing arterial and venous tolerance during chronic isosorbide dinitrate therapy for congestive heart failure. Circulation. 1983;67:817-822. [pmid: 6337742].
Lemarie JC. Multicenter Double-Blind Placebo-Controlled Study of the Efficacy and Safety of Ramipril Administered Orally for 24 Weeks in the Treatment of Stable Chronic Congestive Cardiac Failure. (unpublished report) 1992.
Lewis B S, Rabinowitz B, Schlesinger Z, Caspi A, Markiewicz W, Rosenfeld T, et al. Effect of isosorbide-5-mononitrate on exercise performance and clinical status in patients with congestive heart failure. Results of the Nitrates in Congestive Heart Failure (NICE) Study. Cardiology. 1999;91(1):1-7. [pmid: 10393392].
Lewis G R. Lisinopril versus placebo in older congestive heart failure patients. Am J Med. 1988;85(3B):48-54. [pmid: 2844088].
Liao Y, Cooper R S, McGee D L. The relative effects of left ventricular hypertrophy, coronary artery disease, and ventricular dysfunction on survival among black adults. JAMA. 1995;273:1592-1597. [pmid: 7745772].
Lichstein E, Hager W D, Gregory J J, Fleiss J L, Rolnitzky L M, Bigger J T Jr. Relation between beta-adrenergic blocker use, various correlates of left ventricular function and the chance of developing congestive heart failure. The Multicenter Diltiazem Post-Infarction Research Group. J Am Coll Cardiol. 1990;16(6):1327-32. [pmid: 1977779].
Littler W A, Sheridan D J. Placebo controlled trial of felodipine in patients with mild to moderate heart failure. UK Study Group. Br Heart J. 1995;73(5):428-33. [pmid: 7786657]. [pmcid: 483858].
Livingston IL. Social status, stress, and health: black Americans at risk. Livingston IL (editor). Handbook of Black American Health. Westport, Conn: Greenwood Press, 1994:236–52.
Ljungman S, Kjekshus J, Swedberg K. Renal function in severe congestive heart failure during treatment with enalapril (the Cooperative North Scandinavian Enalapril Survival Study [CONSENSUS] Trial). Am J Cardio. 1992;70(4):479-87.
Lombardi W L, Litwin S E. Angiotensin-converting enzyme inhibitors: congestive heart failure and beyond. Coron Artery Dis. 1999;10(6):361-8. [pmid: 10474785].
Lubsen J, Chadha D R, Yotof Y T, Swedberg K. Meta-analysis of morbidity and mortality in five exercise capacity trials evaluating ramipril in chronic congestive cardiac failure. Am J Cardio. 1996;77(14):1191-1196.
Luparini R L, Celli V, Piccirillo G, Guidi V, Cacciafestam, Marigliano V. Carvedilol in elderly patients with chronic heart failure, a 12 weeks randomized, placebo controlled open trial. Archives of Gerontology and Geriatrics. 1999;29:275-282. [pmid: 15374060].
Maass L. Double-Blind Comparative Trial with Ramipril and Placebo in Patients with Heart Failure (NYHA Class III-IV) Stabilized on Digitalis and Furosemides. (unpublished report) 1991.
Maass L. Efficacy and Safety of Ramipril (HOE 498) in Patients with Congestive Heart Failure in a Double Blind Placebo Controlled Trial. (unpublished report) 1991.
Maass L. Evaluation of the Effect of Ramipril (HOE 498) on Exercise Duration, Invasive Cardiac Haemodynamics Profiles, and Safety in Patients with Congestive Heart Failure. (unpublished report) 1991.
MacFadyen R J, Lees K R, Reid J L. Differences in first dose response to angiotensin converting enzyme inhibition in congestive heart failure: a placebo controlled study. Br Heart J. 1991;66(3):206-11. [pmid: 1657084]. [pmcid: 1024645].
MacFadyen R J, Lees K R, Reid J L. Double blind controlled study of low dose intravenous perindoprilat or enalaprilat infusion in elderly patients with heart failure. Br Heart J. 1993;69(4):293-7. [pmid: 8387806]. [pmcid: 1025039].
Maggioni AP, Anand I, Masson S, et al. Non-ischemic congestive heart failure without renin-angiotensin-aldosterone and adrenergic systems activation in South African Blacks in Val-HeFT. Circulation. 2000;102(18).
Magnani B. Converting enzyme inhibition and heart failure. Am J Med. 1988;84(3A):87-91. [pmid: 3064604].
Magnani B, Magelli C. Captopril in mild heart failure: preliminary observations of a long-term, double-blind, placebo-controlled multicentre trial. Postgraduate Medical Journal. 1986;62(Suppl 1):153-8. [pmid: 3534852].
Magorien R D, Unverferth D V, Leier C V. Hydralazine therapy in chronic congestive heart failure. Am J Med. 1984;77:267-274. [pmid: 6431812].
Markham R V, Corbett J R, Gilmore A, et al. Efficacy of prazosin in the management of chronic congestive heart failure: a six-month randomized, double-blind, placebo-controlled study. Am J Cardiol. 1983;51:1346-1352. [pmid: 6342353].
Massie B, Bourassa M, DiBianco R, Hess M, Konstam M, Likoff M, et al. Long-term oral administration of amrinone for congestive heart failure: lack of efficacy in a multicenter controlled trial. Circulation. 1985;71(5):963-71. [pmid: 3886191].
Massie B M, Berk M R, Brozena S C, Elkayam U, Plehn J F, Kukin M L, et al. Can further benefit be achieved by adding flosequinan to patients with congestive heart failure who remain symptomatic on diuretic, digoxin, and an angiotensin converting enzyme inhibitor? Results of the flosequinan-ACE inhibitor trial (FACET). Circulation. 1993;88(2):492-501. [pmid: 8339411].
Massie B M, Cleland J G, Armstrong P W, Horowitz J D, Packer M, Poole-Wilson P A, et al. Regional differences in the characteristics and treatment of patients participating in an international heart failure trial. The Assessment of Treatment with Lisinopril and Survival (ATLAS) Trial Investigators [published erratum appears in J Card Fail 1998 Jun;4(2):153]. J Card Fail. 1998;4(1):3-8. [pmid: 9573498].
Mathew J, Davidson S, Narra L. Etiology and characteristics of congestive heart failure in blacks. Am J Cardiol. 1996;78:1447-1450. [pmid: 8970426].
Mayet J, Shahi M, Foale R A. Racial differences in cardiac structure and function in essential hypertension. Br Med J. 1994;308:1011-1014. [pmid: 8068083].
McGarry R. Randomized, Double-Blind, Multicenter Study Comparing Benazepril to Digoxin and to Placebo as Add On Therapy to Diuretic in Patients with CHF, NYHA Class II-III During a 12-Week Treatment Period, GHBA-194. (unpublished report) 1991.
McGrath B P, Arnolda L, Matthews P G, Jackson B, Jennings G, Kiat H, et al. Controlled trial of enalapril in congestive cardiac failure. British Heart Journal. 1985;54(4):405-14. [pmid: 2996575]. [pmcid: 481919].
McKelvie R S, Yusuf S, Pericak D, Avezum A, Burns R J, Probstfield J, et al. Comparison of candesartan, enalapril, and their combination in congestive heart failure: randomized evaluation of strategies for left ventricular dysfunction (RESOLVD) pilot study. The RESOLVD Pilot Study Investigators. Circulation. 1999;100(10):1056-64. [pmid: 10477530].
McMurray J J. Major beta blocker mortality trials in chronic heart failure: a critical review. Heart. 1999;82(Suppl 4)::IV14-22. [pmid: 10574906].
Meade T W, Brosovic M, Chakraborti R. Ethnic group comparisons of variables associated with ischemic heart disease. Br Heart J. 1978;40:789-795. [pmid: 687476]. [pmcid: 483485].
Metra M, Nodari S, Daloia A, Bontempi L, Boldi E, Deicas L. A rationale for the use of beta-blockers as standard treatment for heart failure. Am Heart J. 2000;139(N3. MAR)::511-521. [pmid: 10689267].
Moorman PG, Hames CG, Tyroler HA. Socioeconomic status and morbidity and mortality in hypertensive blacks. Saunders E. (editor) Cardiovascular Diseases in Blacks. Philadelphia: F.A. Davis, 1991:179–94.
Mortality from congestive heart failure: United States. Morb Mortal Wkly Rep. 1994;43:77–81.
Moye L A, Pfeffer M A, Wun C C, Davis B R, Geltman E, Hayes D, et al. Uniformity of captopril benefit in the SAVE study: Subgroup analysis. Eur Heart J. 1994;15(SUPPL. B)::2-8. [pmid: 8076658].
Mulligan I P, Fraser A G, Tirlapur V, Lewis M J, Newcombe R G, Henderson A H. A randomized cross-over study of enalapril in congestive heart failure: haemodynamic and hormonal effects during rest and exercise. Eur J Clin Pharmacol. 1988;34(4):323-31. [pmid: 2841136].
Mulrow C D, Mulrow J P, Linn W D, Aguilar C, Ramirez G, et al. Relative efficacy of vasodilator therapy in chronic congestive heart-failure - implications of randomized trials. JAMA. 1988;259(N23):3422-3426. [pmid: 3286914].
Mylona P, Cleland J G. Update of REACH-1 and MERIT-HF clinical trials in heart failure. Cardio.net Editorial Team. Eur J Heart Fail. 1999;1(2):197-200. [pmid: 10937931].
National Heart Lung and Blood Institute National Institutes of Health. Report of the Working Group on Research in Coronary Heart Disease in Blacks. Bethesda, MD: National Institutes of Health, 1994:1–94.
The NETWORK Investigators, Clinical outcome with enalapril in symptomatic chronic heart failure; a dose comparison. Eur Heart J. 1998;19(3):481–9.
Newman T J, Maskin C S, Dennick L G, Meyer J H, Hallows B G, Cooper W H. Effects of captopril on survival in patients with heart failure. Am J Med. 1988;84(3A):140-4. [pmid: 3064591].
Nony P, Boissel J P, Girard P, Leizorovicz A, Lievre M, Chifflet R. Relative efficacy of angiotensin converting enzyme-inhibitors on mortality of patients with congestive-heart-failure: implications of randomized trials and role of the etiology (ischemic or nonischemic) of heart-failure. Eur Heart J. 1992;13(N8):1101-1108. [pmid: 1387085].
Northridge D B, Currie P F, Newby D E, McMurray J J, Ford M, Boon N A, et al. Placebo-controlled comparison of candoxatril, an orally active neutral endopeptidase inhibitor, and captopril in patients with chronic heart failure. Eur J Heart Fail. 1999;1(1):67-72. [pmid: 10937982].
Northridge D B, Rose E, Raftery E D, Lahiri A, Elder A T, Shaw T R, et al. A multicentre, double-blind, placebo-controlled trial of quinapril in mild, chronic heart failure. Eur Heart J. 1993;14(3):403-9. [pmid: 8458362].
Nussberger J, Fleck E, Bahrmann H, Delius W, Schultheiss H P, Brunner H R. Dose-related effects of ACE inhibition in man: quinapril in patients with moderate congestive heart failure. The Study Group on Neurohormonal Regulation in Congestive Heart Failure: Lausanne, Switzerland; Berlin, Dusseldorf, Munich, Germany. Eur Heart J. 1994;15(Suppl D):113-22. [pmid: 7713100].
O'Connor C M, Gattis W A, Zannad F, McNulty S E, Gheorghiade M, Adams K F, et al. Beta-blocker therapy in advanced heart failure: clinical characteristics and long-term outcomes. Eur J Heart Fail. 1999;1(1):81-8. [pmid: 10937984].
Olsen S L, Gilbert E M, Renlund D G, Taylor D O, Yanowitz F D, Bristow M R. Carvedilol improves left ventricular function and symptoms in chronic heart failure: a double-blind randomized study. J Am Coll Cardiol. 1995;25(6):1225-31. [pmid: 7722114].
Oparil S, Bakir S E. Calcium antagonists in cardiovascular disease: clinical evidence from morbidity and mortality trials. Drugs. 2000;59(2):25-37. [pmid: 11002856].
Packer M, Bristow M R, Cohn J N, Colucci W S, Fowler M B, Gilbert E M, Shusterman N H. The effect of carvedilol on morbidity and mortality in patients with chronic heart failure. U.S. Carvedilol Heart Failure Study Group. N Engl J Med. 1996;334(21):1349-55. [pmid: 8614419].
Packer M, Coats A J S, Fowler M B, Katus H A, Krum H, Mohacsi P, et al. Effect of carvedilol on survival in severe chronic heart failure. N Engl J Med. 2001;344(22):1651-8. [pmid: 11386263].
Packer M, Colucci W S, Sackner-Bernstein J D, Liang C S, Goldscher D A, Freeman I, et al. Double-blind, placebo-controlled study of the effects of carvedilol in patients with moderate to severe heart failure. The PRECISE Trial. Prospective Randomized Evaluation of Carvedilol on Symptoms and Exercise. Circulation. 1996;94(11):2793-9. [pmid: 8941104].
Packer M, Gheorghiade M, Young J B, Costantini P J, Adams K F, Cody R J, et al. Withdrawal of digoxin from patients with chronic heart failure treated with angiotensin-converting-enzyme inhibitors. RADIANCE Study. N Engl J Med. 1993;329(1):1-7. [pmid: 8505940].
Packer M, Poole-Wilson P A, Armstrong P W, Cleland J G, Horowitz J D, Massie B M, et al. Comparative effects of low and high doses of the angiotensin-converting enzyme inhibitor, lisinopril, on morbidity and mortality in chronic heart failure. ATLAS Study Group. Circulation. 1999;100(23):2312-8. [pmid: 10587334].
Pahor M, Guralnik J M, Gambassi G, Bernabei R, Carosella L, Carbonin P. The impact of age on risk of adverse drug-reactions to digoxin. J Clin Epidemiol. 1993;46(N11):1305-1314. [pmid: 8229108].
Paolisso G, Gambardella A, Marrazzo G, Verza M, Teasuro P, Varricchio M, et al. Metabolic and cardiovascular benefits deriving from beta-adrenergic blockade in chronic congestive heart failure. Am Heart J. 1992;123(1):103-10. [pmid: 1729814].
Pappas G, Queen S, Hadden W, et al. The increasing disparity in mortality between socioeconomic groups in the United States, 1960 and 1986. N Engl J Med. 1993;329:103-9. [pmid: 8510686].
Parker A B, Azevedo E R, Baird M G, Smith S J, Arnold J M, Humen D P, et al. ARCTIC: assessment of haemodynamic response in patients with congestive heart failure to telmisartan: a multicentre dose-ranging study in Canada. Am Heart J. 1999;138(5 Pt 1):843-8. [pmid: 10539814].
Pennell D J, Ray S G, Davies G, Burgess M, Webster J, Slomka P, et al. The carvedilol hibernation reversible ischaemia trial, marker of success (CHRISTMAS) study. Methodology of a randomised, placebo controlled, multicentre study of carvedilol in hibernation and heart failure. Int J Cardiol. 2000;72(3):265-74. [pmid: 10716137].
Persson H, Rythe'n-Alder E, Melcher A, Erhardt L. Effects of beta receptor antagonists in patients with clinical evidence of heart failure after myocardial infarction: double blind comparison of metoprolol and xamoterol. Br Heart J. 1995;74(2):140-8. [pmid: 7546992]. [pmcid: 483989].
Pfeffer M A, Braunwald E, Moye L A, Basta L, Brown E J Jr, Cuddy T E, et al. Effect of captopril on mortality and morbidity in patients with left ventricular dysfunction after myocardial infarction. Results of the survival and ventricular enlargement trial. The SAVE Investigators. N Engl J Med. 1992;327(10):669-77. [pmid: 1386652].
Pfeffer M A, Lamas G A, Vaughan D F, et al. Effect of captopril on progressive ventricular dilatation after anterior myocardial infarction. N Engl J Med. 1988;319:80-100. [pmid: 2967917].
Pflugfelder P W, Baird M G, Tonkon M J, DiBianco R, Pitt B. Clinical consequences of angiotensin-converting enzyme inhibitor withdrawal in chronic heart failure: a double-blind, placebo-controlled study of quinapril. The Quinapril Heart Failure Trial Investigators. J Am Coll Cardiol. 1993;22(6):1557-63. [pmid: 8227822].
Philbin E F, DiSalvo T G. Influence of race and gender on care process, resource use, and hospital-based outcomes in congestive heart failure. Am J Cardiol. 1998;82:76-81. [pmid: 9671013].
Philbin E F, Santella R N, Rocco T A Jr. Angiotensin-converting enzyme inhibitor use in older patients with heart failure and renal dysfunction. JAGS. 1999;47(3):302-308.
Pitt B, Poole-Wilson P, Segal R, Martinez F A, Dickstein K, Camm A J, et al. Effects of losartan versus captopril on mortality in patients with symptomatic heart failure: rationale, design, and baseline characteristics of patients in the Losartan Heart Failure Survival Study--ELITE II. J Card Fail. 1999;5(2):146-54. [pmid: 10404354].
Pitt B, Poole-Wilson P A, Segal R, Martinez F A, Dickstein K, Camm A J, et al. Effect of losartan compared with captopril on mortality in patients with symptomatic heart failure: randomised trial—the Losartan Heart Failure Survival Study ELITE II. Lancet. 2000;355(9215):1582-7. [pmid: 10821361].
Pitt B, Segal R, Martinez F A, Meurers G, Cowley A J, Thomas I, et al. Randomised trial of losartan versus captopril in patients over 65 with heart failure (Evaluation of Losartan in the Elderly Study, ELITE). Lancet. 1997;349(9054):747-52. [pmid: 9074572].
Pitt B, Yusuf S, the SOLVD Investigators. Studies of left ventricular dysfunction (SOLVD) subgroup results. J Am Coll Cardiol. 1992;19:215A.
Pitt B, Zannad F, Remme W J, Cody R, Castaigne A, Perez A, et al. The effect of spironolactone on morbidity and mortality in patients with severe heart failure. Randomized Aldactone Evaluation Study Investigators. N Engl J Med. 1999;341(10):709-17. [pmid: 10471456].
Plehn JF, Krause-Steinrauf H, Anand IS, et al. Effect of race on cause-specific cardiovascular mortality in BEST. Circulation. 2000;102 (suppl 2)(18).
Pollock S G, Lystash J, Tedesco C, Craddock G, Smucker M L. Usefulness of bucindolol in congestive heart failure. Am J Cardiol. 1990;66(5):603-7. [pmid: 1975473].
Pouleur H. Results of the treatment trial of the studies of left ventricular dysfunction (SOLVD). The SOLVD Investigators. Am J Cardio. 1992;70(10):135C-136C.
Pouleur H, Rousseau M F, Melin J, Marchandise B, Schroeder E, Ahn S, et al. Studies of left ventricular dysfunction (SOLVD) - rationale, design and methods: two trials that evaluate the effect of enalapril in patients with reduced ejection fraction. Am J Cardio. 1990;66(3):315-322.
Pouleur H, Rousseau M F, Oakley C, Ryden L. Difference in mortality between patients treated with captopril or enalapril in the Xamoterol in Severe Heart Failure Study. Am J Cardiol. 1991;68(1):71-4. [pmid: 1676239].
Pouleur H G, Konstam M A, Udelson J E, Rousseau M F. Changes in ventricular volume, wall thickness and wall stress during progression of left ventricular dysfunction. The SOLVD Investigators. J Am Coll Cardiol. 1993;22(4 Suppl A):43A-48A. [pmid: 8376696].
Pousset F, Copie X, Lechat P, Jaillon P, Boissel J P, Hetzel M, et al. Effects of bisoprolol on heart rate variability in heart failure. Am J Cardiol. 1996;77(8):612-7. [pmid: 8610612].
Powers E R, Chiaramida A, DeMaria A N, Giles T D, Hackshaw B, Hart W, et al. A double-blind comparison of lisinopril with captopril in patients with symptomatic congestive heart failure. J Cardiovasc Pharmacol. 1987;9(Suppl 3):S82-8. [pmid: 2442559].
The Randomized Aldactone Evaluation Study (RALES) Effectiveness of spironolactone added to an angiotensin-converting enzyme inhibitor and a loop diuretic for severe chronic congestive heart failure Am J Cardio. 1996;78(8) p902–7.
Regitz-Zagrosek V, Leuchs B, Krulls-Munch J, Fleck E. Angiotensin-converting enzyme inhibitors and beta-blockers in long-term treatment of dilated cardiomyopathy. Am Heart J. 1995;129(4):754-61. [pmid: 7900628].
Remes J, Nikander P, Rehnberg S, Halinen M O, Kuikka J, Lansimies E, et al. Enalapril in chronic heart failure, a double-blind placebo-controlled study. Annals of Clinical Research. 1986;18(3):124-8. [pmid: 3017174].
Remme W J, Krayenbuhl H P, Baumann G, Frick M H, Haehl M, Nehmiz G, et al. Long-term efficacy and safety of pimobendan in moderate heart failure. A double-blind parallel 6-month comparison with enalapril. The Pimobendan-Enalapril Study Group. Eur Heart J. 1994;15(7):947-56. [pmid: 7925517].
The RESOLVD Investigators. Effects of metoprolol CR in patients with ischemic and dilated cardiomyopathy: the randomized evaluation of strategies for left ventricular dysfunction pilot study. Circulation. 2000;101(4):378-84. [pmid: 10653828].
Richardson A, Bayliss J, Scriven A J, Parameshwar J, Poole-Wilson P A, Sutton G C. Double-blind comparison of captopril alone against frusemide plus amiloride in mild heart failure. Lancet. 1987;2(8561):709-11. [pmid: 2888942].
Riegger G A. The effects of ACE inhibitors on exercise capacity in the treatment of congestive heart failure. J Cardiovasc Pharmacol. 1990;15(Suppl 2):S41-6. [pmid: 1691406].
Risler T, Braun U, Klarner H G, Muller-Schauenburg W, Heitkamp H C, Brilla G G, et al. [Comparison of lisinopril and captopril in treatment of severe heart failure (NYHA III-IV) in high risk patients. Preliminary results of the trial]. Z Kardiol. 1991;80(Suppl 2):40-3. [pmid: 1850942].
Rochon P A, Tu J V, Anderson G M, Gurwitz J H, Clark J P, Lau P, et al. Rate of heart failure and 1-year survival for older people receiving low-dose beta-blocker therapy after myocardial infarction. Lancet. 2000;356(N9230. AUG 19)::639-644. [pmid: 10968437].
Rogers W J, Johnstone D E, Yusuf S, Weiner D H, Gallagher P, Bittner V A, et al. Quality of life among 5,025 patients with left ventricular dysfunction randomized between placebo and enalapril: the Studies of Left Ventricular Dysfunction. The SOLVD Investigators. J Am Coll Cardiol. 1994;23(2):393-400. [pmid: 8294693].
Rouleau J L, Pfeffer M A, Stewart D J, Isaac D, Sestier F, Kerut E K, et al. Comparison of vasopeptidase inhibitor, omapatrilat, and lisinopril on exercise tolerance and morbidity in patients with heart failure: IMPRESS randomised trial. Lancet. 2000;356(9230):615-20. [pmid: 10968433].
Rucinska EJ. A Double Blind Placebo Controlled Study to Evaluate the Effects of Enalapril in Patients with Chronic Heart Failure. (unpublished report) 1991.
Rucinska EJ. Enalapril vs. Placebo in Previously Untreated Patients with CHF. 1991.
Rucinska EJ. Lisinopril First-Line Therapy in CHF. (unpublished report) 1991.
Rucinska E J, Small R, Irvin J. High-risk patients treated with enalapril maleate: safety considerations. Int J Cardiol (unpublished report). 1989;22(2):249-59.
Rutherford J D, Pfeffer M A, Moye L A, Davis B R, Flaker G C, Kowey P R, et al. Effects of captopril on ischemic events after myocardial infarction: Results of the survival and ventricular enlargement trial. Circulation. 1994;90(4 I):1731-1738. [pmid: 7923656].
Ryden L, Malmberg K. Benefits of ace inhibitors: what remains to be proven?. Eur Heart J Supplements. 2000;2(NI. AUG)::L3-L7.
Sanderson J E, Chan S K, Yip G, Yeung L Y, Chan K W, Raymond K, et al. Beta-blockade in heart failure: a comparison of carvedilol with metoprolol. J Am Coll Cardiol. 1999;34(5):1522-8. [pmid: 10551702].
Sanderson J E, Chan S K, Yu C M, Yeung L Y, Chan W M, Raymond K, et al. Beta blockers in heart failure: a comparison of a vasodilating beta blocker with metoprolol. Heart. 1998;79(1):86-92. [pmid: 9505927]. [pmcid: 1728575].
Sanderson J E, Chan W W, Hung Y T, Chan S K, Shum I O, Raymond K, et al. Effect of low dose beta blockers on atrial and ventricular (B type) natriuretic factor in heart failure: a double blind, randomised comparison of metoprolol and a third generation vasodilating beta blocker. Br Heart J. 1995;74(5):502-7. [pmid: 8562234]. [pmcid: 484069].
Schofer J, Hobuss M, Aschenberg W, Tews A. Acute and long-term haemodynamic and neurohumoral response to nisoldipine vs. captopril in patients with heart failure: a randomized double-blind study. Eur Heart J. 1990;11(8):712-21. [pmid: 1975780].
Schofield P M, Brooks N H, Lawrence G P, Testa H J, Ward C. Which vasodilator drug in patients with chronic heart failure? A randomised comparison of captopril and hydralazine. Br J Clin Pharmacol. 1991;31(1):25-32. [pmid: 2015167]. [pmcid: 1368408].
Schwartz R S. Racial profiling in medical research. N Engl J Med. 2001;344(18):1392-3. [pmid: 11333999].
Scriven A J, Lipkin D P, Anand I S, Sutton G C, Poole-Wilson P A. A comparison of hemodynamic effects of one-month oral captopril and enoximone treatment for severe congestive heart failure. Am J Cardiol. 1987;60(5):68C-71C. [pmid: 2956872].
Scriven A J, Lipkin D P, Anand I S, Sutton G C, Poole-Wilson P A. Double-blind, randomised, cross-over comparison of oral captopril and enoximone added to diuretic treatment in patients with severe heart failure. J Cardiovasc Pharmacol. 1988;11(1):45-50. [pmid: 2450255].
Seedat Y K. Is the pathogenesis of hypertension different in black patients?. J Hum Hypertens. 1996;10(Suppl 3):S35-7. [pmid: 8872823].
Seedat Y K. Ethnicity, hypertension, coronary heart disease and renal diseases in South Africa. Ethn Health. 1996;1(4):349-57. [pmid: 9395579].
Seedat Y K. The prevalence of hypertension and the status of cardiovascular health in South Africa. Ethn Dis. 1998;8(3):394-7. [pmid: 9926910].
Seedat Y K. Hypertension in black South Africans. J Hum Hypertens. 1999;13(2):96-103. [pmid: 10100057].
Seedat Y K. Hypertension in developing nations in sub-Saharan Africa. J Hum Hypertens. 2000;14(1011):739-47. [pmid: 11095164].
Seneviratne B, Moore G A, West P D. Effect of captopril on functional mitral regurgitation in dilated heart failure: a randomised double blind placebo controlled trial. Br Heart J. 1994;72(1):63-8. [pmid: 8068472]. [pmcid: 1025427].
Shanes J G, Wolfkiel C, Ghali J, Dierenfeldt B J, Kondos G T, Bauman J L. Acute hemodynamic effects of pindolol and propranolol in patients with dilated cardiomyopathy: relevance of intrinsic sympathomimetic activity. Am Heart J. 1988;116(5 Pt 1):1268-75. [pmid: 3189143].
Sharpe D N, Murphy J, Coxon R, et al. Enalapril in patients with chronic heart failure: a placebo controlled randomized double-blind study. Circulation. 1984;70:271-8. [pmid: 6329547].
Sharpe DN, Murphy J, Smith H, et al. Treatment of patients with symptomless left ventricular dysfunction after myocardial infarction. Lancet. 1988:255–9.
Shindler D M, Kostis J B, Yusuf S, Quinones M A, Pitt B, Stewart D, et al. Diabetes mellitus, a predictor of morbidity and mortality in the Studies of Left Ventricular Dysfunction (SOLVD) Trials and Registry. Am J Cardio. 1996;77(11):1017-20.
Sigurdsson A, Amtorp O, Gundersen T, Nilsson B, Remes J, Swedberg K. Neurohormonal activation in patients with mild or moderately severe congestive heart failure and effects of ramipril. The Ramipril Trial Study Group. Br Heart J. 1994;72(5):422-7. [pmid: 7818958]. [pmcid: 1025608].
Silke B, Tennet H, Fischer-Hansen J, Keller N, Heikkila J, Salminen K. A double-blind, parallel-group comparison of flosequinan and enalapril in the treatment of chronic heart failure. Eur Heart J. 1992;13(8):1092-100. [pmid: 1505560].
Simarro E, Rodriguez M A, Bayon J, Lastra J A, Prieto P, Suarez G, et al. [The effect of gallopamil and propranolol in patients with ischemic cardiopathy and moderate depression of ventricular function]. Rev Esp Cardiol. 1995;48(11):741-5. [pmid: 8532943].
Simpson K, Jarvis B. Lisinopril: a review of its use in congestive heart failure. Drugs. 2000;59(5)::1149-67. [pmid: 10983738].
Singh V, Christiana J, Frishman W H. How to use calcium antagonists in hypertension: putting the JNC-VI guidelines into practice. Joint National Committee for the Prevention, Detection, Evaluation and Treatment of High Blood Pressure. Drugs. 1999;58(4):579-87. [pmid: 10551431].
The SOLVD Investigators. Studies of left ventricula dysfunction (SOLVD) rationale, design and methods: two trials that evaluate the effect of enalapril in patients with reduced ejection fraction. Am J Cardiol. 1990;66:315-22. [pmid: 2195865].
The SOLVD Investigators. Effect of enalapril on survival in patients with reduced left ventricular ejection fractions and congestive heart failure. N Engl J Med. 1991;325(5):293-302. [pmid: 2057034].
Spargias K S, Hall A S, Greenwood D C, Ball S G. beta blocker treatment and other prognostic variables in patients with clinical evidence of heart failure after acute myocardial infarction: evidence from the AIRE study. Heart. 1999;81(1):25-32. [pmid: 10220541]. [pmcid: 1728912].
Stamler J, Rhomberg P, Schonberger J A. Multivariate analysis of the relationship of the seven variables to blood pressure. J Chron Dis. 1975;28:527-548. [pmid: 1081548].
Suwa M, Ito T, Otake Y, Moriguchi A, Hirota Y, Kawamura K. Comparison of the therapeutic effects of the beta-blocking agent bisoprolol and the calcium-blocking agent diltiazem in patients with heart failure due to dilated cardiomyopathy. Jpn Circ J. 1996;60(10):767-73. [pmid: 8933239].
Swedberg K. Effects of ace-inhibition on renal-function in severe congestive-heart-failure. Zeitschrift Fur Kardiologie. 1991;80(S2):50-54. [pmid: 2024543].
Swedberg K, Amtorp O, Gundersen T, et al. Is maximal exercise testing a useful method to evaluate treatment of moderate heart failure?. Circulation. 1991;57:226.
Swedberg K, Eneroth P, Kjekshus J, Wilhelmsen L. Hormones regulating cardiovascular function in patients with severe congestive heart failure and their relation to mortality. CONSENSUS Trial Study Group. Circulation. 1990;82(5):1730-6. [pmid: 2225374].
Swedberg K, Held P, Kjekshus J, Rasmussen K, Ryden L, Wedel H. Effects of the early administration of enalapril on mortality in patients with acute myocardial infarction. Results of the Cooperative New Scandinavian Enalapril Survival Study II (CONSENSUS II). N Engl J Med. 1992;327(10):678-84. [pmid: 1495520].
Swedberg K, Kjekshus J. Effects of enalapril on mortality in severe congestive heart failure: results of the Cooperative North Scandinavian Enalapril Survival Study (CONSENSUS). Am J Cardio. 1988;62(2):60A-66A.
Swedberg K, Kjekshus J, Snapinn S. Long-term survival in severe heart failure in patients treated with enalapril. Ten year follow-up of CONSENSUS I. Eur Heart J. 1999;20(2):136-9. [pmid: 10099910].
Texter M, Lees R S, Pitt B, Dinsmore R E, Uprichard A C. The QUinapril Ischemic Event Trial (QUIET) design and methods: evaluation of chronic ACE inhibitor therapy after coronary artery intervention. Cardiovasc Drugs Ther. 1993;7(2):273-82. [pmid: 8357782].
Timmis A D, Bojanowski L M, Najm Y C, Nelson D J, Gosling R G. Captopril versus placebo in congestive heart failure: effects on oxygen delivery to exercising skeletal muscle. Eur Heart J. 1987;8(12):1295-304. [pmid: 3325289].
Tonkon M, Awan N, Niazi I, Hanley P, Baruch L, Wolf RA, et al. A study of the efficacy and safety of irbesartan in combination with conventional therapy, including ACE inhibitors, in heart failure. Irbesartan Heart Failure Group. Int J Clin Pract. 2000;54(1):11–4, 16–8.
Torp-Pedersen C, Kober L, Carlsen J. Angio-converting enzyme inhibition after myocardial infarction: the Trandolapril Cardiac Evaluation Study. Am Heart J. 1996;132(1 Pt 2 Su):235-43. [pmid: 8677862].
Tsuyuki R T, McAlister F A, Teo K K. Beta-blockers for congestive heart failure: what is the current consensus?. Drugs Aging. 2000;16(1):1-7. [pmid: 10733260].
Uhlir O, Dvorak I, Gregor P, Malek I, Spinarova L, Vojacek J, et al. Nebivolol in the treatment of cardiac failure: a double-blind controlled clinical trial. J Card Fail. 1997;3(4):271-6. [pmid: 9547441].
Uprichard A. A 12-Week Double Blind, Placebo Controlled Study to Determine the Efficacy and Safety of Orally Administered Quinapril Hydrochloride in Patients with Congestive Heart Failure (unpublished report) 1994.
Uprichard A. A 16-week Double Blind, Placebo-Randomized Placebo Controlled Multicenter Trial to Evaluate the Effects of Withdrawal of Quinapril Hydrochloride on Exercise Tolerance in Patients with Mild to Moderate Congestive Heart Failure. (unpublished report) 1994.
Uprichard A. An 18-Week Double Blind, Optional Titration, Multicenter Study to Compare the Efficacy and Safety of Orally Administered Quinapril Hydrochloride with Captopril and Placebo in Patients with Congestive Heart Failure. (unpublished report) 1994.
Van den Heuvel A F, Van Gilst W H, Van Veldhuisen D J, De Vries R J M, Dunselman P H J M, Kingma J H. Long-term anti-ischemic effects of angiotensin-converting enzyme inhibition in patients after myocardial infarction. J Am Coll Cardiol. 1997;30(2):400-405. [pmid: 9247511].
van der Does R, Hauf-Zachariou U, Pfarr E, Holtbrugge W, Konig S, Griffiths M, et al. Comparison of safety and efficacy of carvedilol and metoprolol in stable angina pectoris. Am J Cardiol. 1999;83(5):643-9. [pmid: 10080412].
van Veldhuisen D J, Genth-Zotz S, Brouwer J, Boomsma F, Netzer T, Man, Veld A J, et al. High- versus low-dose ACE inhibition in chronic heart failure: a double-blind, placebo-controlled study of imidapril. J Am Coll Cardiol. 1998;32(7):1811-8. [pmid: 9857856].
Vedin A, Wikstrand J, Wilhelmsson C, Wallentin I. Left ventricular function and beta-blockade in chronic ischaemic heart failure. Double-blind, cross-over study of propranolol and penbutolol using non-invasive techniques. Br Heart J. 1980;44(1):101-7. [pmid: 7000099]. [pmcid: 482367].
Viscoli C M, Horwitz R I, Singer B H. Beta-blockers after myocardial infarction: Influence of first-year clinical course on long-term effectiveness. Ann Intern Med. 1992;118(2):99-105. [pmid: 8416325].
Vitovec J, Spinar J. First-dose hypotension after angiotensin-converting enzyme (ACE) inhibitors in chronic heart failure: a comparison of enalapril and perindopril. Slovak Investigator Group. Eur J Heart Fail. 2000;2(3):299-304. [pmid: 10938492].
Waagstein F, Bristow M R, Swedberg K, Camerini F, Fowler M B, Silver M A, et al. Beneficial effects of metoprolol in idiopathic dilated cardiomyopathy. Metoprolol in Dilated Cardiomyopathy (MDC) Trial Study Group. Lancet. 1993;342(8885):1441-6. [pmid: 7902479].
Watanabe H, Kakihana M, Ohtsuka S, Sugishita Y. Randomized, double-blind, placebo-controlled study of carvedilol on the prevention of nitrate tolerance in patients with chronic heart failure. J Am Coll Cardiol. 1998;32(5):1194-200. [pmid: 9809925].
Weber K T, Kinasewitz G T, West J S, et al. Long-term vasodilator therapy with trimazosin in chronic cardiac failure. N Engl J Med. 1980;303:242-250. [pmid: 6104295].
Webster M W I, Fitzpatrick M A, Hamilton E J, et al. Effects of Enalapril on clinical status, biochemistry, exercise performance and haemodynamics in heart failure. Drugs. 1985;30(Suppl 1):74-81. [pmid: 2994990].
Wedel H, DeMets D, Deedwania P, et al. Challenges of subgroup analyses in multinational clinical trials: Experiences from the MERIT-HR trial. Am Heart J. 2001;142:502-11. [pmid: 11526365].
Weedle P B, Poston J W, Parish P A. The use of digoxin in 55 residential homes for elderly people. Postgraduate Medical Journal. 1988;64(N750):292-296. [pmid: 3186572].
Weir M R, Gray J M, Paster R. Differing mechanisms of action in angiotensin-converting enzyme inhibition in black and white hypertensive patients. Hypertension. 1995;25:124-30. [pmid: 7843743].
Widimsky J, Kremer H J, Jerie P, Uhlir O. Czech and Slovak spirapril intervention study (CASSIS). A randomized, placebo and active-controlled, double-blind multicentre trial in patients with congestive heart failure. European J Clin Pharm. 1995;49(12):95-102.
Wiklund I, Swedberg K. Some methodological problems in analyzing quality of life data in severe congestive heart failure patients. JCRP. 1991;5(3):265-273.
Wiklund I, Waagstein F, Swedberg K, Hjalmarsson A. Quality of life on treatment with metoprolol in dilated cardiomyopathy: results from the MDC trial. Metoprolol in Dilated Cardiomyopathy trial. Cardiovasc Drugs Ther. 1996;10(3):361-8. [pmid: 8877080].
Williams D R. Socioeconomic differentials in health: a review and redirection. Soc Psychol Q. 1990;53:81-99.
Wisenbaugh T, Katz I, Davis J, Essop R, Skoularigis J, Middlemost S, et al. Long-term (3-month) effects of a new beta-blocker (nebivolol) on cardiac performance in dilated cardiomyopathy. J Am Coll Cardiol. 1993;21(5):1094-100. [pmid: 8096228].
Witchitz S, Cohen-Solal A, Dartois N, Weisslinger N, Juste K, Darmon J Y. Treatment of heart failure with celiprolol, a cardioselective beta blocker with beta-2 agonist vasodilatory properties. The CELICARD Group. Am J Cardio. 2000;85(12):1467-71.
Wood A J J. Racial differences in the response to drugs - pointers to genetic differences. N Eng J Med. 2001;344(18):1393-6.
Woodley S L, Gilbert E M, Anderson J L, O'Connell J B, Deitchman D, Yanowitz F G, et al. Beta-blockade with bucindolol in heart failure caused by ischemic versus idiopathic dilated cardiomyopathy. Circulation. 1991;84(6):2426-41. [pmid: 1683602].
Wright J T Jr, Kusek J W, Toto R D, Lee J Y, Agodoa L Y, Kirk K A, et al. Design and baseline characteristics of participants in the African American Study of Kidney Disease and Hypertension (AASK) Pilot Study. Control Clin Trials. 1996;17(4 Suppl):3S-16S. [pmid: 8889350].
Xu C, Weifeng S, Mingzhou L, Lansheng G. Beneficial effects of captopril on prognosis in elderly patients with acute myocardial infarction. Chin Med Sci J. 1998;13(2):107-111.
Xu H, Sun M, Zhou H. [Changes of plasma endothelin-1 in patients with congestive heart failure and the influence of metoprolol]. Hunan I Ko Ta Hsueh Hsueh Pao. 1998;23(5):467-9. [pmid: 10682563].
Yancy C W, Fowler M B, Colucci W S, Gilbert E M, Bristow M R, Cohn J N, et al. Race and the response to adrenergic blockade with carvedilol in patients with chronic heart failure. N Engl J Med. 2001;344(18):1358-65. [pmid: 11333992].
Yancy C W, Fowler M B, Colucci W S, Gilbert E M, Lukas M A, Young S T. Response of black heart failure patients to carvedilol [abstract]. J Am Coll Cardiol. 1997;29:284A.
Young J B, Gheorghiade M, Uretsky B F, Patterson J H, Adams K F Jr. Superiority of “triple” drug therapy in heart failure: insights from the PROVED and RADIANCE trials. Prospective Randomized Study of Ventricular Function and Efficacy of Digoxin. Randomized Assessment of Digoxin and Inhibitors of Angiotensin-Converting Enzyme. J Am Coll Cardiol. 1998;32(3):686-92. [pmid: 9741512].
Yusuf S. Reduced mortality and morbidity with the use of angiotensin-converting enzyme inhibitors in patients with left ventricular dysfunction and congestive heart failure. Herz. 1993;18(Suppl 1):444-8. [pmid: 8125425].
Yusuf S. Phase I results of the randomized evaluation of left ventricular dysfunction (RESOLVD) trial. Am J Managed Care. 1998;4(7 SUPPL.)::S380-S383.
Yusuf S, Garg R, Mcconachie D. Effect of angiotensin-converting enzyme-inhibitors in left-ventricular dysfunction - results of the studies of left-ventricular dysfunction in the context of other similar trials. J Cardiovasc Pharmacol. 1993;22(S9):S28-S35. [pmid: 7514238].
Yusuf S, Lonn E, Bosch J, Gerstein H. Summary of randomized trials of angiotensin converting enzyme inhibitors. Clinical and Experimental Hypertension. 1999;21(N56. JUL-AUG)::835-845. [pmid: 10423106].
Yusuf S, Nicklas J M, Timmis G, Breneman G, Jafri S M, Duvernoy W F C, et al. Effect of enalapril on mortality and the development of heart failure in asymptomatic patients with reduced left ventricular ejection fractions. The SOLVD Investigators. N Engl J Med. 1992;327(10):685-691. [pmid: 1463530].
Yusuf S, Peto R, Lewis J, et al. Beta-blockade during and after myocardial infarction: an overview of the randomized trials. Prog Cardiovasc Dis. 1985;27:335-71. [pmid: 2858114].
Yusuf S, Phil D, Sleight P, Pogue J, Bosch J, Davies R, et al. Effects of an angiotensin-converting-enzyme inhibitor, ramipril, on cardiovascular events in high-risk patients. N Engl J Med. 2000;342(N3. JAN 20)::145-153. [pmid: 10896545].
Zannad F, Chati Z, Guest M, Plat F. Differential effects of fosinopril and enalapril in patients with mild to moderate chronic heart failure. Fosinopril in Heart Failure Study Investigators. Am Heart J. 1998;136(4 Pt 1):672-80. [pmid: 9778071].
Ziesche S, Rector T S, Cohn J N. Interobserver discordance in the classification of mechanisms of death in studies of heart failure. J Cardiac Failure. 1995;1(2):127-132.
Zwehl W, Rucinska E, for Lisinopril Chronic Heart Failure Investigators. Long-term effects of lisinopril in patients with chronic heart failure: a multicenter, placebo-controlled trial. Nicholls MG (ed). A Focus on the Clinical Effects of a Long Acting ACE-Inhibitors/Heart Failure. New York, NY: Raven Press, 1990:31–40.S