# References

1 American Heart Association. 1998 Heart and stroke statistical update. Dallas: American Heart Association; 1997.
2 Materson B J, Reda D G, Cushman W C, et al. Single-drug therapy for hypertension in men: a comparison of six antihypertensive agents with placebo. N Engl J Med. 1993;328:914. [pmid: 8446138].
3 Yusuf S, Nicklas J M, Timmis G, et al. Effect of enalapril on mortality and the development of heart failure in asymptomatic patients with reduced left ventricular ejection fractions. The SOLVD Investigators. N Engl J Med. 1992;327:685-691. [pmid: 1463530].
4 Limacher MC, Yusuf S. Cardiovascular health and disease in women. In: Wenger, Speroff, Packard (eds): Proceedings of an NHLBI Conference. Darien:LeJacq; 1993.
5 Rothman KJ, Greenland S. Modern epidemiology. Philadelphia: Lippincott-Raven Publishers; 1998.
6 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-188. [pmid: 3802833].
7 Hedges LV, Olkin I. Statistical methods for meta-analysis. San Diego: Academic Press, Inc.; 1985.
8 Stata Corporation. Stata Statistical Software. Release 7.0. College Station: Stata Corporation; 2001.
9 Parmar M K, Torri V, Stewart L. Extracting summary statistics to perform meta-analyses of the published literature for survival endpoints. Stat Med. 1998;17:2815-2834. [pmid: 9921604].
10 SAS Institute, Inc. SAS/STAT. Cary, NC: SAS Institute, Inc.; 1999.
11 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315:629-634. [pmid: 9310563]. [pmcid: 2127453].
12 Begg C B, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1994;50:1088-1101. [pmid: 7786990].
13 Fryback D G, Dasbach E J, Klein R, et al. The Beaver Dam Health Outcomes Study: initial catalog of health-state quality factors. Med Decis Making. 1993;13:89-102. [pmid: 8483408].
14 U.S. Bureau of the Census. Statistical abstract of the United States. U.S. Census Bureau: Washington;2000.
15 Bureau of Labor Statistics. Consumer price index. http://www.bls.gov/cpi/home.htm.
16 AAUP policy documents and reports (The Redbook). Baltimore: Johns Hopkins University Press; 2001.
17 Paul S D, Kuntz K M, Eagle K A, Weinstein M C. Costs and effectiveness of angiotensin converting enzyme inhibition in patients with congestive heart failure. Arch Intern Med. 1994;154:1143-9. [pmid: 8185426].
18 Gold M, Siegel J, Russel L, Weinstein M (eds.). Cost Effectiveness in Health and Medicine. New York: Oxford University Press; 1996.
19 National Center for Health Statistics. United States life tables, 1998 (PHS 2000-1120). Atlanta: Centers for Disease Control and Prevention; 2000.
20 McDonagh T A, Robb S D, Murdoch D R, Morton J J, Ford I, Morrison C E, Tunstall-Pedoe H, McMurray J J V, Dargie H J. N Biochemical detection of left-ventricular systolic dysfunction. Lancet. 1998;351:9-13. [pmid: 9433422].
21 McDonagh T A, Morrison C E, Lawrence A, et al. Symptomatic and asymptomatic left-ventricular systolic dysfunction in an urban population. Lancet. 1997;350:829-33. [pmid: 9310600].
22 Naik M M, Diamond G A, Pai T, et al. Correspondence of left ventricular ejection fraction determinations from two-dimensional echocardiography, radionuclide angiography and contrast cineangiography. J Am Coll Cardiol. 1995;25:937-42. [pmid: 7884101].
23 Schiller N B, Acquatella H, Ports T A, et al. Left ventricular volume from paired biplane two-dimensional echocardiography. Circulation. 1979;60:547-55. [pmid: 455617].
24 The SOLVD Investigators. Effect of enalapril on survival in patients with reduced left ventricular ejection fractions and congestive heart failure. N Engl J Med. 1991;325:293-302. [pmid: 2057034].
25 National Center for Health Statistics. Vital Statistics of the United States: Mortality. Atlanta: Centers for Disease Control and Prevention; 1991.
26 American Heart Association. Heart and stroke statistical update. Dallas: American Heart Association; 2000.
27 Glick H, Cook J, Kinosian B, et al. Costs and effects of enalapril therapy in patients with symptomatic heart failure: an economic analysis of the Studies of Left Ventricular Dysfunction (SOLVD) treatment trial. J Cardiac Failure. 1995;1:371-380.
28 Cook J R, Glick H A, Gerth W, et al. The cost and cardioprotective effects of enalapril in hypertensive patients with left ventricular dysfunction. Am J Hypertens. 1998;11:1433-41. [pmid: 9880125].
29 Ball S G, Hall A S, Mackintosh A F, et al. Effect of ramipril on mortality and morbidity of survivors of acute myocardial infarction with clinical evidence of heart failure. the Acute Infarction Ramipril Efficacy (AIRE) Study Investigators. Lancet. 1993;342(8875):821-8. [pmid: 8104270].
30 The CONSENSUS Trial Study Group. Effects of enalapril on mortality in severe congestive heart failure. Results of the Cooperative North Scandinavian Enalapril Survival Study (CONSENSUS). N Engl J Med. 1987;316:1429-35. [pmid: 2883575].
31 Pfeffer M A, Braunwald E, Moye L A, et al. Effect of captopril on mortality and morbidity in patients with left ventricular dysfunction after myocardial infarction: results of the survival and ventricular enlargement trial. The SAVE Investigators. N Engl J Med. 1992;327(10):669-77. [pmid: 1386652].
32 Moye L A, Pfeffer M A, Wun C C, et al. Uniformity of captopril benefit in the SAVE study: subgroup analysis. Eur Heart J. 1994;15:2-8. [pmid: 8076658].
33 Ambrosioni E, Borghi C, Magnani B. The effect of the angiotensin-converting-enzyme inhibitor zofenopril on mortality and morbidity after anterior myocardial infarction. N Engl J Med. 1995;332:80-85. [pmid: 7990904].
34 Exner D V, Dries D L, Domanski M J, Cohn J N. Lesser response to angiotensin-converting-enzyme inhibitor therapy in black as compared with white patients with left ventricular dysfunction. N Eng J Med. 2001;344:1351-7.
35 Kober L, Torp-Pedersen C, Carlsen J E, et al. A clinical trial of the angiotensin-converting-enzyme inhibitor trandolapril in patients with left ventricular dysfunction after myocardial infarction. Trandolapril Cardiac Evaluation (TRACE) Study Group. N Engl J Med. 1995;333(25):1670-6. [pmid: 7477219].
36 The Beta-Blocker Evaluation of Survival Trial Investigators (BEST): a trial of the beta-blocker bucindolol in patients with advanced chronic heart failure. N Engl J Med 2001;344:1659–67.
37 Eichhorn E J, Domanski M J, Adams K, et al. Effect of beta-blockade on mortality in African-Americans: the beta-blocker evaluation of survival trial. Circulation. 2000;102(suppl 2):18.
38 Plehn J F, Krause-Steinrauf H, Anand I S, et al. Effect of race on cause-specific cardiovascular mortality in BEST. Circulation. 2000;102(suppl 2):18.
39 The Cardiac Insufficiency Bisoprolol Study II (CIBIS-II): a randomised trial. Lancet 1999;353:9–13.
40 Erdmann E, Lechat P, Verkenne P, Wiemann H. Results from post-hoc analyses of the CIBIS II trial: effect of bisoprolol in high-risk patient groups with chronic heart failure. Euro J Heart Failure. 2001;3:469-479.
41 Packer M, Coats A J S, Fowler M B, et al. Effect of carvedilol on survival in severe chronic heart failure. N Engl J Med. 2001;344:1651-8. [pmid: 11386263].
42 Hjalmarson A, Goldstein S, Fagerberg B, et al. Effect of metoprolol CR/XL in chronic heart failure: Metoprolol CR/XL Randomised Intervention Trial in Congestive Heart Failure (MERIT-HF). Lancet. 1999;353:2001-2007. [pmid: 10376614].
43 Wedel H, DeMets D, Deedwania P, et al. Challenges of subgroup analyses in multinational clinical trials: experiences from the MERIT-HR trial. Am Heart J. 2001;142:502-11. [pmid: 11526365].
44 Ghali J K, Pina I L, Gottlieb S S, et al. Metoprolol CR/XL in female patients with heart failure: analysis of the experience in Metoprolol Extended-Release Randomized Intervention Trial in Heart Failure (MERIT-HF). Circulation. 2002;105:1585-91. [pmid: 11927527].
45 Packer M, Bristow M R, Cohn J N, et al. The effect of carvedilol on morbidity and mortality in patients with chronic heart failure. U.S. Carvedilol Heart Failure Study Group. N Engl J Med. 1996;334:1349-55. [pmid: 8614419].
46 Yancy C W, Fowler M B, Colucci W S, et al. Race and the response to adrenergic blockade with carvedilol in patients with chronic heart failure. N Engl J Med. 2001;344:1358-65. [pmid: 11333992].