# Appendix A

Date

REF # 0098/238/171/306

Name

Address

Address

Dear XX,,

The US Agency for Healthcare Research and Quality (AHRQ) has commissioned us to perform a meta-analysis on the treatment of systolic heart failure with ace-inhibitors in particular subgroups. The participating investigators on this project are, in addition to myself:

- Dr. Michael Barrett
- Dr. Greg Fonarow
- Dr. Barry Greenberg
- Dr. Paul Heidenreich
- Dr. Tom Knabel
- Dr. Marvin Konstam
- Dr. Michael W. Rich
- Dr. Anthony Steimle
- Dr. Lynne Warner Stevenson

We read with interest your articles

“Effect of ramipril on mortality and morbidity of survivors of acute myocardial infarction with clinical evidence of heart failure. The Acute Infarction Ramipril Efficacy (AIRE) Study Investigators” in [underlined: Lancet],

“Effect of ramipril on morbidity and mode of death among survivors of acute myocardial infarction with clinical evidence of heart failure. A report from the AIRE Study Investigators” in [underlined: European Heart Journal],

“Angiotensin-converting enzyme-inhibitors, left-ventricular dysfunction, and early heart-failure” in [underlined: American Journal of Cardiology], and

“Captopril in heart failure: a double-blind study of the effects on renal function” in [underlined: Journal of Cardiovascular Pharmacology].

We would be very appreciative if you could assist us by providing data from your study specific to women, persons of African descent (Blacks), diabetics, renal insufficiency, or persons 80 years of age or older.

Name

Date

If such subgroup data are not available, we would also appreciate that information. If you have any questions regarding this request, please call me at 310-393-0411 ext. 6669 or send email to shekelle@rand.org Thank you very much for your assistance.

Sincerely,

Paul Shekelle, MD, PhD

Director