# Evidence Tables

Evidence Table 1. Diagnostic Testing: Characteristics of studies of exercise myocardial perfusion imaging

Reference | Total N (% women) | Mean age (years) | Prior MIN (% women) | Radionuclide | Definition of abnormal test | Definition of CHD^a^ (%) | Exercise | Quality^b^
Kiat et al, 1990^23^ | 53 (26) | 56 | 24 (NA) | MIBI | Fixed or reversible PD | 50 | Treadmill | Fair
Van Train et al, 1990^41^ | 371 (14) | NA | 130 (NA) | TI | PD at rest or after exercise | 50 | Treadmill | Fair
Gupta et al, 1992^17^ | 93 (17) | 58 | 37 (NA) | TI | Fixed or reversible PD | 50 | Treadmilll | Fair
Sciammarella et al, 1992^47^ | 56 (20) | 55 | 42 (45) | MIBI | Fixed or reversible PD | 50 | Treadmill | Good
Chae et al, 1993^44^ | 243 (100) | 62 | 102 (42) | TI | PD at rest or after exercise | 50 | Treadmill | Good
Mak et al, 1995^48^91 | 139 (18) | 51 | 90 (NA) | MIBI | Fixed or reversible PD | 50 | Treadmill | Good
Hambye et al, 1996^18^ | 123 (31) | | 0 (0) | MIBI | Fixed or reversible PD | 50 | Bicycle | Fair
Laurienzo et al, 1997^45^ | 82 (100) | 51 | NA (NA) | TI | Fixed or reversible PD | 70 or 50 LM | Treadmill | Good
Taillefer et al, 1997^6^ | 48 (100) | 58 | 8 (17) | TI & MIBI | Decreased uptake at rest or after exercise | 50 | Treadmill | Fair
Astarita et al, 1998^46^ | 41 (48) | 59 | 0 (0) | TI | Reversible uptake defects in [underlined: >] 2/22 segments | 50 | Bicycle | Fair

N, number; MI, myocardial infarction; CHD, coronary heart disease; NA, not available; TI, thallous chloride TI 201 (thallium) ; PD, perfusion defect; MIBI, technetium Tc 99m sestamibi; LM, left main coronary artery

a Percent stenosis of any one major coronary artery at or above this cut-off used to define angiographic evidence of coronary disease.

b Quality classification described in section on quality assessment.

Note: Superscripted numbers correspond with citations on reference list for Chapter 2.

Evidence Table 2. Diagnostic Testing: Characteristics of studies of exercise echocardiography

Reference | Total N (% women) | Mean age (years) | Prior MIN (% women) | Definition of abnormal test | Definition of CHD (%) ^a^ | Exercise Used | Quality^b^
Williams et al, 1994^49^ | 70 (100) | 60 | 0 (0) | New or worse RWMA after exercise | 50 | Bicycle | Good
Marwick et al, 1995^2^ | 161 (100) | 60 | 0 (0) | RWMA at rest or after exercise | 50 | Treadmill & bicycle | Fair
Luotolahti et al, 1996^24^ | 118 (15) | 55 | 57 (39) | New or worse RWMA after exercise | 50 | Bicycle | Fair
Roger et al, 1997^50^ | 340 (28) | 66 | 0 (0) | RWMA at rest or after exercise | 50 | Treadmill | Good

N, number; MI, myocardial infarction; CHD, coronary heart disease; RWMA, regional wall motion abnormality

a Percent stenosis of any one major coronary artery at or above this cut-off used to define angiographic evidence of coronary disease.

b Quality classification described in section on quality assessment.

Note: Superscripted numbers correspond with citations on reference list for Chapter 2.

Evidence Table 3. Diagnostic Testing: Findings of studies of exercise myocardial perfusion imaging and summary estimates of accuracy

| Women | | | | Men
Reference | Sensitivity (95% CI) | Specificity (95% CI) | LR+ (95% CI) | LR- (95% CI) | Sensitivity (95% CI) | Specificity (95% CI) | LR+ (95% CI) | LR- (95% CI)
Kiat et al, 1990^23^ | 1.00 (0.72-1.00) | 0.67 (0.09-0.99) | 3.00 (0.82-11.00) | ^a^ | 0.92 (0.78-0.98) | 0.50 (0.01-0.99) | 1.84 (0.58-5.86) | 0.16 (0.03-0.75)
Van Train et al, 1990^41^ | 0.95 (0.83-1.00) | 0.62 (0.32-0.87) | 2.47 (1.27-4.82) | 0.08 (0.02-0.30) | 0.95 (0.92-0.97) | 0.43 (0.29-0.58) | 1.67 (1.31-2.13) | 0.12 (0.06-0.22)
Gupta et al, 1992^17^ | 0.85 (0.55-0.99) | 0.67 (0.09-0.99) | 2.54 (0.68-9.46) | 0.23 (0.06-0.92) | 0.81 (0.69-0.90) | 0.86 (0.57-0.99) | 5.67 (1.78-18.1) | 0.22 (0.12-0.39)
Sciammarella et al, 1992^47^ | 1.00 (0.54-1.00) | 0.40 (0.05-0.96) | 1.67 (0.81-3.43) | ^a^ | 0.95 (0.83-1.00) | 0.33 (0.04-0.78) | 1.42 (0.80-2.51) | 0.15 (0.03-0.75)
Chae et al, 1993^44^ | 0.71 (0.63-0.78) | 0.65 (0.54-0.75) | 2.03 (1.47-2.79) | 0.44 (0.33-0.59) | ^b^ | ^b^ | ^b^ | ^b^
Mak et al, 1995^48^ | 0.83 (0.62-0.95) | 1.00 (0.02-1.00) | | 0.17 (0.05-0.55) | ^b^ | ^b^ | ^b^ | ^b^
Hambye et al, 1996^18^ | 0.61 (0.39-0.80) | 0.67 (0.39-0.89) | 1.83 (0.85-3.93) | 0.59 (0.30-1.10) | 0.94 (0.85-0.99) | 0.82 (0.60-0.95) | 5.15 (2.20-12.0) | 0.08 (0.03-0.20)
Laurienzo et al, 1997^45^ | 0.86 (0.65-0.97) | 0.80 (0.68-0.89) | 4.32 (2.53-7.37) | 0.17 (0.06-0.46) | ^b^ | ^b^ | ^b^ | ^b^
Taillefer et al, 1997^6^ (using sestamibi) | 0.72 (0.53-0.86) | 0.81 (0.54-0.96) | 3.83 (1.44-10.2) | 0.35 (0.19-0.64) | ^b^ | ^b^ | ^b^ | ^b^
(using thallium) | 0.75 (0.57-0.89) | 0.50 (0.25-0.50) | 1.50 (0.89-2.54) | 0.50 (0.23-1.07) | ^b^ | ^b^ | ^b^ | ^b^
Astarita et al, 1998^46^ | 1.00 (0.29-1.00) | 0.47 (0.23-0.72) | 1.89 (1.05-3.39) | ^a^ | 1.00 (0.77-1.00) | 0.50 (0.16-0.84) | 2.00 (1.02-3.92) | ^a^
SUMMARY
All eligible studies^c^ | 0.77 (0.72-0.83) | 0.69 (0.62-0.75) | 2.46 (2.00-3.04) | 0.33 (0.26-0.41) | 0.93 (0.90-0.95) | 0.57 (0.47-0.67) | 2.17 (1.73-2.73) | 0.13 (0.09-0.19)
Good quality studies | 0.75 (0.69-0.81) | 0.71 (0.69-0.78) | 2.54 (1.95-3.32) | 0.36 (0.28-0.46) | ^d^ | ^d^ | ^d^ | ^d^
Studies including men and women | 0.86 (0.77-0.92) | 0.57 (0.43-0.70) | 2.01 (1.46-2.76) | 0.24 (0.14-0.42) | 0.93 (0.90-0.95) | 0.57 (0.47-0.67) | 2.17 (1.73-2.37) | 0.13 (0.09-0.19)

CI, confidence interval; LR+, likelihood ratio for a positive test; LR- likelihood ratio for a negative test

a Estimates not calculable because sensitivity or specificity = 100%.

b Estimates not available because these studies did not include men.

6 Includes results from the study by Taillefer for sestamibi.

d Estimates not available because only one good quality study included men.

Note: Superscripted numbers correspond with citations on reference list for Chapter 2.

Evidence Table 4. Diagnostic Testing: Summary estimates of accuracy of myocardial perfusion imaging from studies using sestamibi compared to studies using thallium

Radionuclide | Sensitivity (95% CI) | Specificity (95% CI) | LR+ (95% CI) | LR- (95% CI) | Sensitivity (95% CI) | Specificity (95% CI) | LR+ (95% CI) | LR- (95% CI)
Sestamibi^6, 18, 23, 47, 48^ | 0.77 (0.67-0.85) | 0.70 (0.53-0.83) | 2.57 (1.58-4.17) | 0.33 (0.22-0.50) | 0.94 (0.89-0.97) | 0.70 (0.51-0.85) | 3.12 (1.82-5.37) | 0.09 (0.05-0.18)
Thallium^6, 17, 41, 44-46^ | 0.77 (0.72-0.82) | 0.67 (0.60-0.74) | 2.32 (1.87-2.88) | 0.34 (0.27-0.44) | 0.92 (0.89-0.95) | 0.52 (0.40-0.64) | 1.93 (1.51-2.46) | 0.14 (0.09-0.22)

CI, confidence interval; LR+ = likelihood ratio for a positive test; LR- = likelihood ratio for a negative test

Note: Superscripted numbers correspond with citations on reference list for Chapter 2.

Evidence Table 5. Diagnostic Testing: Findings of studies of exercise echocardiography and summary estimates of accuracy

Reference | Sensitivity (95% CI) | Specificity (95% CI) | LR+ (95% CI) | LR- (95% CI) | Sensitivity (95% CI) | Specificity (95% CI) | LR+ (95% CI) | LR- (95% CI)
Williams et al, 1994^49^ | 0.88 (0.72-0.97) | 0.84 (0.68-0.94) | 5.42 (2.62-11.2) | 0.14 (0.06-0.35) | ^a^ | ^a^ | ^a^ | ^a^
Marwick et al, 1995^2^ | 0.80 (0.68-0.89) | 0.81 (0.72-0.88) | 4.28 (2.79-6.57) | 0.25 (0.15-0.42) | ^a^ | ^a^ | ^a^ | ^a^
Luotolahti et al, 1996^24^ | 0.77 (0.46-0.95) | 0.80 (0.28-0.99) | 3.85 (0.91-16.4) | 0.29 (0.10-0.82) | 0.96 (0.90-0.99) | 0.60 (0.14-0.95) | 2.39 (0.91-6.29) | 0.07 (0.02-0.22)
Roger et al, 1997^50^ | 0.79 (0.66-0.89) | 0.37 (0.22-0.54) | 1.26 (0.95-1.67) | 0.56 (0.32-1.08) | 0.78 (0.71-0.84) | 0.44 (0.30-0.59) | 1.39 (1.07-1.80) | 0.500.33-0.76)
SUMMARY
All eligible studies | 0.81 (0.74-0.87) | 0.73 (0.66-0.79) | 2.95 (2.28-3.79) | 0.26 (0.19-0.36) | 0.84 (0.79-0.88) | 0.45 (0.32-0.59) | 1.54 (1.20-1.98) | 0.36 (0.24-0.53)
Good quality studies | 0.82 (0.73-0.89) | 0.60 (0.48-0.71) | 2.06 (1.53-2.77) | 0.29 (0.18-0.47) | ^b^ | ^b^ | ^b^ | ^b^
Studies including men and women | 0.79 (0.68-0.88) | 0.42 (0.27-0.58) | 1.36 (1.02-1.81) | 0.50 (0.28-0.89) | 0.84 (0.79-0.88) | 0.45 (0.32-0.59) | 1.54 (1.20-1.98) | 0.36 (0.24-0.53)

CI, confidence interval; LR+ = likelihood ratio for a positive test; LR- = likelihood ratio for a negative test

a Estimates not available because these studies did not include men.

b Estimates not available because only one good quality study included men and women.

Note: Superscripted numbers correspond with citations on reference list for Chapter 2.

Evidence Table 6. Lipids: Characteristics of Included Clinical Trials

Study Name,Year | N Women/Total (% Women) | Mean Ageof Women | Percentwith CHD^a^ | Lipid Entry Criterion | Intervention | Mean Follow Up (years) | Outcomesin Women | QualityRating^b^
Scottish Society of Physicians,1971^29^ | 124/717 (17) | 54 | 100% | None | Clofibrate | 6 | CHD mortality nonfatal MI | Fair
Newcastle Upon Tyne, 1971^30^ | 97/497 (20) | 54 | 100% | None | Clofibrate | 5 | CHD mortality nonfatal MI | Fair
Colestipol Study,1978^31^ | 1184/2278 (52) | 57 | 20% | TC >250 mg/dl | Colestipol | 3 | total mortality CHD mortality | Fair
4S, 1994^7, 32, 33^ | 827/4444 (19) | 61 | 100% | TC 213-309 mg/dl | Simvastatin | 5.4 | total mortality CHD mortality nonfatal MI revascularization CHD events^c^ | Good
ACAPS, 1994^25, 26^ | 441/919 (48) | 61 | 0% | LDL 130-159 mg/dl with any number of risk factors; LDL 160-189 mg/dl with no or one risk factor | Lovastatin | 2.8 | total mortality CHD mortality nonfatal MI | Good
PLAC II, 1994^16^ | 22/151 (15) | NA | 100% | LDL in 60-90^th^ percentile for age and gender | Pravastatin | 3 | total mortality CHD mortality nonfatal MI | Good
CARE, 1998^8, 34, 35^ | 576/4159 (14) | 61 | 100% | TC <240 mg/dl and LDL-C 115-174 mg/dl | Pravastatin | 5 | total mortality CHD mortality nonfatal MI revascularization CHD events^c^ | Good
LIPID, 1998^27, 36, 37^ | 1516/9014 (17) | 62 | 100% | TC 155-271 mg/dl | Pravastatin | 6.1 | CHD events^c^ | Good
AFCAPS/TEXCAPS, 1998^9, 38^ | 997/6605 (15) | 62 | 0% | TC 180-264 mg/dl LDL 130-190 mg/dl and HDL <47 mg/dl | Lovastatin | 5.2 | total mortality CHD mortality nonfatal MI revascularization CHD events^c^4) Re | Good
HPS, 2002^11^ | 5082/20,536 (25) | NA | 65% | TC >135 mg/dl | Simvastatin | 5 | CHD events^c^ | Good
ALLHAT, 2002^39^ | 5051/10,355 (49) | NA | 14% | LDL 100-189 mg/dl | Pravastatin | 4.8 | total mortality CHD events^c^ | Fair

4S, Scandinavian Simvastatin Survival Study; ACAPS, Asymptomatic Carotid Artery Progression Study; PLAC II, Pravastatin, Lipids and Atherosclerosis in the Carotid Arteries; CARE, Cholesterol and Recurrent Events trial; LIPID, Long-term Intervention with Pravastatin in Ischaemic Disease; AFCAPS/TEXCAPS, Air Force/Texas Coronary Atherosclerosis Prevention Study; HPS, Heart Protection Study; ALLHAT, Antihypertensive and Lipid-Lowering Treatment to Prevent heart Attack Trial.

N, number; CHD, coronary heart disease; mg/dl, milligrams per deciliter; MI, myocardial infarction; NA, not available; CVD, cardiovascular disease; TC total cholesterol; LDL, low density lipoprotein

a CHD defined as history of myocardial infarction or angina.

b see Quality Assessment section in text.

c CHD events in, CARE, LIPID and ALLHAT defined as CHD mortality or nonfatal MI; in 4S as CHD mortality, non fatal MI or resuscitated cardiac arrest and in AFCAPS as CHD mortality, nonfatal MI or unstable angina or sudden cardiac death; in HPS as CHD mortality, nonfatal MI, stroke or revascularization.

Note: Superscripted numbers correspond with citations on reference list for Chapter 3

Evidence Table 7. Lipids: Outcomes of Eligible Studies

Outcome | Study | RR (95% CI)
Secondary Prevention
Total Mortality | 4S^7, 32, 33^ PLAC II^16^ | 1.11 1.18 | (0.66, 1.5) (0.03, 54.81)
CHD Mortality | Scottish Society of Physicians^29^ Newcastle Upon Tyne^30^ 4S^7, 32, 33^ PLAC II^16^ CARE^8, 34, 35^ | 0.17 0.20 0.79 1.18 0.80 | (0.02, 1.34) (0.04, 1.13) (0.39, 1.6) (0.03, 54.81) (0.61, 1.05)
Nonfatal MI | Scottish Society of Physicians^29^ Newcastle Upon Tyne^30^ 4S^7, 32, 33^ PLAC II^16^ CARE^8, 34, 35^ | 0.75 0.43 0.66 1.18 0.51 | (0.42, 1.33) (0.08, 2.25) (0.48, 0.90) (0.48, 54.81) (0.27, 0.94)
CHD events^a^ | 4S^7, 32, 33^ CARE^8, 34, 35^ LIPID^27, 36, 37^ HPS^11^ | 0.68 0.60 0.87 0.81 | (0.51, 0.91) (0.37, 0.97) (0.67, 1.13) (0.72, 0.92)
Revascularizaion | 4S^7, 32, 33^ CARE^8, 34, 35^ | 0.52 0.82 | (0.31, 0.86) (0.64, 1.20)
Primary Prevention
Total Mortality | Colestipol^31^ ACAPS^25, 26^ AFCAPS/TEXCAPS^9, 38^ ALLHAT^39^ | 0.92 0.09 1.53 0.98 | (0.51, 1.69) (0.01, 1.7) (0.62, 3.81) (0.83, 1.17)
CHD Mortality | Colestipol^31^ ACAPS^25, 26^ AFCAPS/TEXCAPS^9, 38^ | 1.08 0.35 2.99 | (0.44, 2.63) (0.01, 8.47) (0.12, 73.3)
Nonfatal MI | ACAPS^25, 26^ AFCAPS/TEXCAPS^9, 38^ | 0.35 0.69 | (0.04, 3.31) (0.21, 2.28)
CHD events^a^ | AFCAPS/TEXCAPS^9, 38^ ALLHAT^39^ | 0.54 1.02 | (0.22, 1.34) (0.81, 1.28)
Revascularization | AFCAPS/TEXCAPS^9, 38^ | 0.87 | (0.33,2.31)

CHD, coronary heart disease; CI, confidence interval; MI, myocardial infarction; NA not available; RR, relative risk; 4S, Scandinavian Simvastatin Survival Study; ACAPS, Asymptomatic Carotid Artery Progression Study; PLAC II, Pravastatin, Lipids and Atherosclerosis in the Carotid Arteries; CARE, Cholesterol and Recurrent Events trial; LIPID, Long-term Intervention with Pravastatin in Ischaemic Disease; AFCAPS/TEXCAPS, Air Force/Texas Coronary Atherosclerosis Prevention Study; HPS, Heart Protection Study; ALLHAT, Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial.

a CHD events in CARE, LIPID and ALLHAT defined as CHD mortality or nonfatal MI; in 4S as CHD mortality, non fatal MI or resuscitated cardiac arrest; in AFCAPS as CHD mortality, nonfatal MI, unstable angina or sudden cardiac death, and in HPS as CHD mortality, nonfatal MI, stroke or revascularization.

Note: Superscripted numbers correspond with citations on reference list for Chapter 3.

Evidence Table 8. Lipids: Summary Results

| Secondary Prevention | | Primary Prevention
Outcome | References | RR (95% CI) | References | RR (95% CI)
Total mortality
All studies | ^7, 16, 32, 33^ | 1.11 (0.66 1.87) | ^9, 25, 26, 31, 38, 39^ | 0.95 (0.62, 1.46)
Statin drugs | ^7, 16, 32, 33^ | 1.11 (0.66 1.87) | ^9, 25, 26, 38, 39^ | 0.87 (0.37, 2.00) ^a^
Good quality | ^7, 16, 32, 33^ | 1.11 (0.66 1.87) | ^9, 25, 26, 38^ | 0.45 (0.03, 7.00) ^a^
CHD mortality
All studies | ^7, 8, 16, 29, 30, 32-35^ | 0.74 (0.57, 0.96) | ^7, 16, 32, 33^ | 1.07 (0.47, 2.40)
Statin drugs | ^7, 8, 16, 32-35^ | 0.78 (0.60, 1.01) | ^7, 16, 32, 33^ | 1.02 (0.11, 9.76)
Good quality | ^7, 8, 16, 32-35^ | 0.78 (0.60, 1.01) | ^7, 16, 32, 33^ | 1.02 (0.11, 9.76)
Nonfatal MI
All studies | ^7, 8, 16, 29, 30, 32-35^ | 0.64 (0.50, 0.82) | ^9, 25, 26, 38^ | 0.61 (0.22, 1.68)
Statin drugs | ^7, 8, 16, 32-35^ | 0.63 (0.48, 0.83) | ^9, 25, 26, 38^ | 0.61 (0.22, 1.68)
Good quality | ^7, 8, 16, 32-35^ | 0.63 (0.48, 0.83) | ^9, 25, 26, 38^ | 0.61 (0.22, 1.68)
CHD events ^b^
All studies | ^7, 8, 11, 27, 32-37^ | 0.79 (0.72, 0.88) | ^9, 38, 39^ | 0.87 (0.50, 1.49)
Statin drugs | ^7, 8, 11, 27, 32-37^ | 0.79 (0.72, 0.88) | ^9, 38, 39^ | 0.87 (0.50, 1.49)
Good quality | ^7, 8, 11, 27, 32-37^ | 0.79 (0.72, 0.88) | ^9, 38^ | 0.54 (0.22, 1.30)
Revascularization
All studies | ^7, 8, 32-35^ | 0.70 (0.42, 1.16) ^a^ | ^9, 38^ | 0.87 (0.33,2.31) ^c^
Statin drugs | ^7, 8, 32-35^ | 0.70 (0.42, 1.16) ^a^ | ^9, 38^ | 0.87 (0.33,2.31) ^c^
Good quality | ^7, 8, 32-35^ | 0.70 (0.42, 1.16) ^a^ | ^9, 38^ | 0.87 (0.33,2.31) ^c^

RR, relative risk; CI, confidence interval; CHD, coronary heart disease; MI, myocardial infarction; statin drugs included lovastatin, pravastatin or simvastatin; good quality is defined in the methods section.

a P-value for heterogeneity <0.10

b CHD events in CARE, LIPID and ALLHAT defined as CHD mortality or nonfatal MI; in 4S as CHD mortality, non fatal MI or resuscitated cardiac arrest; in AFCAPS as CHD mortality, nonfatal MI, unstable angina or sudden cardiac death, and in HPS as CHD mortality, nonfatal MI, stroke or revascularization. See Tables 1 and 2 for full names of studies.

9, 38 Only one trial provided data on this outcome

Note: Superscripted numbers correspond with citations on reference list for Chapter 3.

Evidence Table 9. Diabetes: Characteristics of studies of coronary heart disease risk in diabetics vs. nondiabetic subjects

| | | | | Number of Subjects
Source | Study Name or Location | Quality Score | Mean Followup (years) | Mean Age (range), y | M | F | M | F
Barrett-Connor et al, ^70^1991^a^ | Rancho Bernardo, CA | good | 14.4 | 63 (50-89) | 207 | 127 | 893 | 1244
Collins et al, ^71^1996 | Asian Indian, Fiji | fair | 11 | 20+ | 102 | 129 | 1077 | 1236
Fujimoto et al, ^16, 17^ 1987, 1991 | King County, WA | fair | NA | 62- 64 | 78 | 52 | 79 | 72
Howard et al, ^21^1995 | Strong Heart Study | fair | 4.8 | 55-57 | 797 | 1412 | 1049 | 1291
Jousilahti et al, ^72^ 1999 | WHO-MONICA | fair | 7-12 | 25-64 | 262 | 254 | 6828 | 7442
Keil et al, ^73^ 1993 | Charleston Heart Study | fair | 30 | 50 (35-74) | 30 | 42 | 956 | 1153
Kleinman et al, ^74^ 1998 | NHANES I | fair | 9 | 57,63^b^ (40-77) | 189 | 218 | 3151 | 3823
Lindeman et al, ^19^ 1998 | Bernalillo County, NM | fair | NA | [underlined: >] 65 | 115 | 73 | 330 | 321
Lowe et al, ^75^1997^a^ andPan et al, ^76^1986^a^ | Chicago, IL | fair | 9-22 | 45,52^b^ (35-64) | 926 | 170 | 7975 7860
Niskanen et al, ^15^ 1998 | Finland-Kuopio | fair | 15 | 55 (45-64) | 70 | 63 | 62 | 82
Rewers et al, ^18^ 1992 | San Luis Valley, CO | fair | NA | 25-74 | 186 | 521 | 243 | 571
Scheidt-Nave et al, ^77^1021990^a^ | Rancho Bernardo, CA | good | 14.4 | 50-89 | 159 | 157 | 591 | 732
Sievers et al, ^20^ 1998 | Gila River, AZ | fair | 12.1 | [underlined: >] 15 | 630 | 813 | 1542 1552
Vilbergsson et al, ^12^ | Reykjavik Study | good | 17 | 52 (34-79) | 267 | 210 | 8861 9549
Wei et al, ^78^ 1998 | San Antonio Heart Study | fair | 7.5 | 43,53^b^ (25-64) | 190 | 281 | 1910 2494

CI indicates confidence interval; NA indicates not available; WHO-MONICA indicates World Health Organization-Monitoring of Trends and Determinants in Cardiovascular Disease; NHANES I indicates National Health and Nutrition Examination Survey I

a Duplicate publication, but separate outcomes or subgroups reported in each article.

b Values represent mean age for nondiabetic and diabetic subjects, respectively.

Note: Superscripted numbers correspond with citations on reference list for Chapter 4.

Evidence Table 10. Diabetes: Adjusted odds ratios (95% confidence intervals) for coronary heart disease mortality, nonfatal myocardial infarction (NFMI) , and all-cause mortality by sex

| | CHD Mortality | | Nonfatal MI | | All-Cause Mortality
Source | Race/Ethnicity | Male | Female | Male | Female | Male | Female
| | OR (95% CI) | | OR (95% CI) | | OR (95% CI)
Barrett-Connor, ^70^ 1991 | W | 1.9 (1.3-2.8) | 3.3 (2.0-5.6)
Scheidt-Nave, ^77^ 1990 | W | | | 1.3 (0.8-2.1) | 1.8 (1.0-3.0)
Collins, ^71^ 1996 | I | 3.2 (1.3-2.0) | 20.7 (2.5-171) | | | 4.4 (2.7-6.9) | 3.1 (1.7-5.8)
| Me | 1.6 (0.4-6.0) | 5.4 (1.2-24.3) | | | 1.3 (0.7-2.5) | 2.3 (1.2-4.6)
Fujimoto^a^, ^16^ 1987 | JA | | | 2.1 (1.3-3.3)
Fujimoto^a^, ^17^ 1991 | JA | | | | 1.2 (0.8-1.9)
Howard^a^, ^21^ 1995 | NA | | | 1.59 (.74-3.21) | 7.11 (2.24-22.58)
Jousilahti, ^72^ 1999 | W | 2.4 (1.6-3.4) | 4.3 (2.4-7.6)
Keil, ^73^ 1993 | W | 0.8 (0.5-2.4) | 1.3 (0.4-4.5) | | | 1.2 (0.7-2.0) | 2.2 (1.1-4.2)
| B | 2.5 (0.3-18.7) | 2.0 (0.9-4.5) | | | 3.1 (1.4-7.2) | 1.8 (1.1-2.8)
Kleinman,^74^1988 | W | 2.8 (2.0-3.8) | 2.5 (1.6-3.8) | | | 2.3 (1.8-2.8) | 2.0 (1.6-2.6)
Lindeman^a^, ^19^ 1998 | W | | | 3.4 (1.2-5.5) | 3.6 (1.3-10)
Lindeman^a, 19^ 1998 | L | | | 1.7 (0.9-3.3) | 1.4 (0.5-3.7)
Lowe, ^75^ 1997 | W | | | | | 1.9 (1.6-2.2)
| B | | | | | 1.8 (1.0-3.3)
Pan, ^76^ 1986 | W | 3.8 (1.7-8.4) | 4.7 (1.9-11.9)
Niskanen^a^, ^15^ 1998 | W | | | | | 5.4 (1.7-14.7) | 5.2 (1.8-15)
Rewers^a^, ^18^ 1992 | W | | | 1.7 (1.0-2.8) | 2.7 (1.5-4.7)
| L | | | 0.9 (0.5-1.4) | 1.4 (0.9-2.1)
Sievers^a^, ^20^ 1992 | P | 5.3 (2.2-13) | 6.3 (0.8-50) | | | 1.8 (1.4-2.4) | 1.4 (1.0-2.0)
Vilbergsson, ^12^ 1998 | W | 2.0 (1.5-2.6) | 2.2 (1.7-2.8) | | | 1.9 (1.6-2.3) | 1.7 (1.3-2.1)
Wei, ^78^1998 | M | | | | | 2.1 (1.3-3.5) | 3.2 (1.9-5.4)

a Multivariate results received via personal communication with authors; OR indicates odds ratio; CI indicates confidence interval; W=white, B=black, I=East Indian, Me=Melanesian, JA=Japanese- American, L=Latino, P=Pima Indian, M=multiple races, INA=Native American

Note: Superscripted numbers correspond with citations on reference list for Chapter 4.

Evidenec Table 11. Diabetes: Summary odds ratios for coronary heart disease (CHD) mortality, nonfatal myocardial infarction (NFMI) , and all-cause mortality by sex (comparing diabetics to nondiabetics)

Outcome | Men Summary OR (95%CI) | Women Summary OR (95%CI) | References | p-value^a^
CHD Mortality: (n=8) | 2.33 (1.91-2.85) | 2.92 (2.22-3.84) | ^12, 20, 70-74, 76^ | 0.19
White (n=6) | 2.22 (1.79-2.75) | 2.79 (2.11-3.69) | ^12, 70, 72-74, 76^ | 0.20
Black (n=1) | 2.5 (0.3-18.7) | 2.0 (0.9-4.5) | ^73^ | 0.87
East Indian (n=1) | 3.2 (1.3-2.0) | 20.7 (2.5-171) | ^71^ | 0.11
Melanesian (n=1) | 1.6 (0.4-6.0) | 5.4 (1.2-24.3) | ^71^ | 0.24
Pima India (n=1) | 5.3 (2.2-13) | 6.3 (0.8-50) | ^20^ | 0.88
Nonfatal MI: (n=5) | 1.55 (1.11-2.17) ^b^ | 1.70 (1.27-2.28) | ^16-19, 21, 77^ | 0.68
White (n=3) | 1.65 (1.06-2.56) | 2.29 (1.59-3.30) | ^18,19,77^ | 0.26
Native American (n=1) | 1.59 (0.74-3.21) | 7.11 (2.24-22.58) | ^21^ | 0.03
Japanese American (n=1) | 2.1 (1.3-3.3) | 1.2 (0.8-1.9) | ^16,17^ | 0.08
Latino (n=2) | 1.2 (0.6-2.4) | 1.4 (0.9-2.1) | ^18,19^ | 0.71
Mortality: (n=7) | 2.13 (1.71-2.65) ^b^ | 1.94 (1.65-2.28) | ^12,15, 20, 71, 73, 74,75, 78^ | 0.50
White (n=5) | 2.01 (1.59-2.54) | 1.98 (1.65-2.38) | ^12,15, 73-75^ | 0.92
Black (n=2 male; n=1 female) | 2.19 (1.28-3.73) | 1.8 (1.1-2.8) | ^73,75^ | 0.60
East Indian (n=1) | 4.4 (2.7-6.9) | 3.1 (1.7-5.8) | ^71^ | 0.37
Melanesian (n=1) | 1.3 (0.7-2.5) | 2.3 (1.2-4.6) | ^71^ | 0.21
Pima Indian (n=1) | 1.8 (1.4-2.4) | 1.4 (1.0-2.0) | ^20^ | 0.24

OR indicates odds ratio; CI indicates confidence interval.

a P Value for comparison of odds ratio estimates between men and women.

b P Value for heterogeneity < .10.

Race-ethnicity groups with only one study (n=1) , were not meta-analyzed.

Note: Superscripted numbers correspond with citations on reference list for Chapter 4.

Evidence Table 12. Diabetes: Summary odds ratios (95% confidence intervals) for coronary heart disease mortality by sex (diabetes vs. no diabetes) quality of studies and sensitivity analysis (white race only)

Summary odds ratios (95% Confidence Interval)
Subgroup | Men | Women | P-value^a^ | References
[underlined: Quality of Studies] ^b^
Good (n=2) | 1.96 (1.56-2.47) | 2.54 (1.73-3.72) | .26 | ^12,70^
Fair (n=4) | 2.42 (1.71-3.42) | 3.07 (1.97-4.80) | .41 | ^72,73,74,76^
[underlined: Level of Adjustment for Potential Confounding] ^b^
Age Adjusted only (n=4) | 2.07 (1.39-3.08) | 3.42 (2.55-4.59) | .05 | ^12,70,73,76^
Unadjusted only (n=3) | 2.16 (1.56-2.98) | 3.22 (2.39-4.34) | .08 | ^70,73,74^

OR indicates odds ratio; CI indicates confidence interval

a P value for comparison of odds ratio estimates between men and women.

b The studies included in these subgroup analyses were eligible for inclusion because they provided outcomes adjusted for at least age, hypertension, hyperlipidemia and smoking; these studies also provided unadjusted and/or age-adjusted estimates which are used to calculate these summary estimates.

Note: Superscripted numbers correspond with citations on reference list for Chapter 4.

Evidence Table 13. Troponin: Characteristics of the Study Populations by Gender

Author | Year | Patient Cohort | Age^a^ (years) | | History of MI (%) | | Hypertension (%) | | Diabetes Mellitus (%) | | Smoking (%)
| | | M | F | M | F | M | F | M | F | M | F
Antman 1996^8^ | 1996 | ACS | 58 | 61 | 45 | 30 | 35 | 56 | 12 | 20 | 39 | 34
Antman 1998^9^ | 1998 | ACS | 61 | 64 | 42 | 35 | 59 | 68 | 29 | 41 | 31 | 19
Christenson^10, 16^ | 1996 | ACS | 62 | 69 | 25 | 25 | 39 | 60 | 16 | 26 | 38 | 23
Galvani^21^ | 1997 | Unstable Angina | 66 | | 48 | | na | | na | | na
Hamm^12^ | 1999 | Unstable Angina | 61 | | 20 | | 37 | | 12 | | 41
Heeschen^13^ | 1999 | ACS | 64 | | 46 | | 55 | | 21 | | 69
Ravkilde^20^ | 1993 | Unstable Angina | 68 | | 28 | | 9 | | 9 | | na
Safstrom^6^ | 2000 | ACS | 69 | 72 | 29 | 29 | 30 | 37 | 12 | 16 | 22 | 16

na=not available; ACS=suspected acute coronary syndrome (non-ST elevation) ; UA=unstable angina (MI excluded) . MI=myocardial Infarction.

a Mean or median.

Note: Superscripted numbers correspond with citations on reference list for Chapter 5.

Evidence Table 14. Troponin: Characteristics of the Study Reports

Study | Data Source | Definition of Positive Troponin | StudyType | Troponin | Troponin Threshold (ng/ml) | Exclusions Listed | Providers Blinded to Troponin
Antman 1996^8^ | Author | Any positive | Clinical Trial | I | 0.4 | Yes | Yes
Antman 1998^9^ | Author | Any positive | Clinical Trial | T | 0.2 | Yes | Yes
Christenson^10, 16^ | Author | Initial Positive | Clinical Trial | T | 0.1 | Yes | Yes
Galvani^21^ | Publication | Any positive | Cohort | I | 3.1 | Yes | Yes
Hamm^12^ | Author | Any positive | Clinical Trial | T | 0.1 | Yes | Yes
Heeschen^13^ | Author | Any positive | Clinical Trial | I | 0.1 | Yes | Yes
Ravkilde^20^ | Publication | Any positive | Cohort | T | 0.2 | No | Yes
Safstrom^6^ | Publication | Any positive | Clinical Trial | T | 0.2 | Yes | Yes

I=Troponin I protein; T=Troponin T protein; ng/ml=nanogram per milliliter

Note: Superscripted numbers correspond with citations on reference list for Chapter 5.

Evidence Table 15. Troponin: Outcomes for Women

| | | Death (%) | | Death or MI (%)
| | | Troponin | | Troponin
Author | Total | Troponin Positive (%) | Negative | Positive | Negative | Positive
Antman 1996^8^ | 471 | 179 (38) | 5 (1.7) | 10 (5.6) | 18 (6.2) | 19 (10.6)
Antman 1998^9^ | 194 | 35 (18) | 3 (1.9) | 2 (5.7) | 6 (3.8) | 7 (20.0)
Christenson^10, 16^ | 251 | 102 (41) | 8 (5.4) | 13 (12.7) | 14 (9.4) | 15 (14.7)
Galvani^21^ | 29 | 11 (38) | 0 (0) | 1 (9) | 2 (11) | 2 (18)
Hamm^12^ | 333 | 149 (45) | 2 (1.1) | 3 (2.0) | 16 (8.7) | 26 (17.4)
Heeschen^13^ | 1513 | 464 (31) | 20 (1.9) | 19 (4.1) | 51 (4.9) | 30 (8.2)
Ravkilde^20^ | 36 | 12 (33) | 0 (0) | 0 (0) | 0 (0) | 2 (17)
Safstrom^6^ | 342 | 166 (49) | 4 (2.3) | 13 (7.8) | 10 (5.7) | 30 (18.1)
Total | 3169 | 1118 (35) | 42 (2.0) | 61 (5.5) | 117 (5.7) | 139 (12.4)

MI = myocardial infarction

Note: Superscripted numbers correspond with citations on reference list for Chapter 5.

Evidence Table 16. Troponin: Outcomes for Men

| | | Death (%) | | Death or MI (%)
| | | Troponin | | Troponin
Author | Total N | Troponin Positive (%) | Negative | Positive | Negative | Positive
Antman 1996^8^ | 933 | 394 (42) | 7 (1.3) | 11 (2.8) | 44 (8.2) | 27 (6.9)
Antman 1998^9^ | 344 | 75 (22) | 3 (1.1) | 1 (1.3) | 7 (2.6) | 4 (5.3)
Christenson^10, 16^ | 554 | 187 (34) | 12 (3.2) | 20 (10.7) | 33 (9.0) | 25 (13.4)
Galvani ^21^ | 62 | 11 (18) | 0 (0) | 1 (9.1) | 2 (3.9) | 3 (27.3)
Hamm^12^ | 756 | 297 (39) | 5 (1.1) | 12 (4.1) | 33 (7.2) | 35 (11.8)
Heeschen^13^ | 709 | 180 (25) | 14 (2.6) | 8 (4.4) | 32 (6.0) | 18 (10.0)
Ravkilde^20^ | 91 | 32 (35) | 1 (1.7) | 3 (9.4) | 3 (5.1) | 4 (12.5)
Safstrom^6^ | 621 | 395 (64) | 5 (2.2) | 26 (6.6) | 26 (11.5) | 70 (17.7)
Total | 4070 | 1571 (39) | 47 (1.9) | 82 (5.2) | 180 (7.2) | 186 (11.8)

MI = myocardial infarction

Note: Superscripted numbers correspond with citations on reference list for Chapter 5.