# Bibliography

Abbott RD, Donahue RP, Kannel WB, et al. The impact of diabetes on survival following myocardial infarction in men vs women. The Framingham Study [published erratum appears in JAMA 1989 Apr 7;261(13):1884] [see comments]. JAMA. 1988;260(23):3456-60. [pmid: 2974889].
Abbud ZA, Shindler DM, Wilson AC, et al. Effect of diabetes mellitus on short- and long-term mortality rates of patients with acute myocardial infarction: a statewide study. Myocardial Infarction Data Acquisition System Study Group. Am Heart J. 1995;130(1):51-8. [pmid: 7611123].
ACAPS Group. Rationale and design for the Asymptomatic Carotid Artery Plaque Study (ACAPS) Control Clin Trials 1992 13 4 293 314 1330434
Adlerberth AM, Rosengren A, Wilhelmsen L. Diabetes and long-term risk of mortality from coronary and other causes in middle-aged Swedish men. A general population study. Diabetes Care. 1998;21(4):539-45. [pmid: 9571339].
Alpert JS, Thygesen K, Antman E, et al. Myocardial infarction redefined--a consensus document of The Joint European Society of Cardiology/American College of Cardiology Committee for the redefinition of myocardial infarction. J Am Coll Cardiol. 2000;36(3):959-69. [pmid: 10987628].
American Diabetic Association. Standards of medical care for patients with diabetes mellitus. Diabetes Care 2001;24(Supp. 1):S33-43.
American Heart Association. Heart Disease and Stroke Statistics--2002 Update. Dallas, Tex.: American Heart Association; 2001.
Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT) Officers and Coordinators for the ALLHAT Collaborative Research Group. Major outcomes in moderately hypercholesterolemic, hypertensive patients randomized to pravastatin vs usual care: The Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT-LLT) JAMA 2002 288 23 2998 3007 12479764
Antman EM, Cohen M, Bernink PJ, et al. The TIMI risk score for unstable Angina/Non-ST elevation MI: A method for prognostication and therapeutic decision making [In Process Citation]. JAMA. 2000;284(7):835-42. [pmid: 10938172].
Antman EM, Sacks DB, Rifai N, et al. Time to positivity of a rapid bedside assay for cardiac-specific troponin T predicts prognosis in acute coronary syndromes: a Thrombolysis in Myocardial Infarction (TIMI) 11A substudy. J Am Coll Cardiol. 1998;31(2):326-30. [pmid: 9462575].
Antman EM, Tanasijevic MJ, Thompson B, et al. Cardiac-specific troponin I levels to predict the risk of mortality in patients with acute coronary syndromes. N Engl J Med. 1996;335(18):1342-9. [pmid: 8857017].
Arntz HR, Agrawal R, Wunderlich W, et al. Beneficial effects of pravastatin (+/-colestyramine/niacin) initiated immediately after a coronary event (the randomized Lipid-Coronary Artery Disease [L-CAD] Study). Am J Cardiol. 2000;86(12):1293-8. [pmid: 11113401].
Astarita C, Nicolai E, Liguori E, et al. [Dipyridamole-echocardiography and thallium exercise myocardial scintigraphy in the diagnosis of obstructive coronary or microvascular disease in hypertensive patients with left ventricular hypertrophy and angina]. G Ital Cardiol. 1998;28(9):996-1004. [pmid: 9788038].
Balkau B, Eschwege E, Papoz L, et al. Risk factors for early death in non-insulin dependent diabetes and men with known glucose tolerance status [see comments]. BMJ. 1993;307(6899):295-9. [pmid: 8374376].
Barbash GI, White HD, Modan M, et al. Significance of diabetes mellitus in patients with acute myocardial infarction receiving thrombolytic therapy. Investigators of the International Tissue Plasminogen Activator/Streptokinase Mortality Trial. J Am Coll Cardiol. 1993;22(3):707-13. [pmid: 8354802].
Barish RA, Doherty RJ, Browne BJ. Reengineering the emergency evaluation of chest pain. J Healthc Qual. 1997;19(5):6-12. [pmid: 10173215].
Barolsky SM, Gilbert CA, Faruqui A, et al. Differences in electrocardiographic response to exercise of women and men: a non-Bayesian factor. Circulation. 1979;60(5):1021-7. [pmid: 487535].
Barrett-Connor EL, Cohn BA, Wingard DL, et al. Why is diabetes mellitus a stronger risk factor for fatal ischemic heart disease in women than in men? The Rancho Bernardo Study. JAMA. 1991;265(5):627-31. [pmid: 1987413].
Behar S, Boyko V, Reicher-Reiss H, et al. Ten-year survival after acute myocardial infarction: comparison of patients with and without diabetes. SPRINT Study Group. Secondary Prevention Reinfarction Israeli Nifedipine Trial. Am Heart J. 1997;133(3):290-6. [pmid: 9060796].
Beleslin BD, Ostojic M, Stepanovic J, et al. Stress echocardiography in the detection of myocardial ischemia. Head- to-head comparison of exercise, dobutamine, and dipyridamole tests. Circulation. 1994;90(3):1168-76. [pmid: 7916274].
Berman DS, Kiat H, Friedman JD, et al. Separate acquisition rest thallium-201/stress technetium-99m sestamibi dual-isotope myocardial perfusion single-photon emission computed tomography: a clinical validation study. J Am Coll Cardiol. 1993;22(5):1455-64. [pmid: 8227805].
Bjornstad K, Aakhus S, Hatle L. Comparison of digital dipyridamole stress echocardiography and upright bicycle stress echocardiography for identification of coronary artery stenosis. Cardiology. 1995;86(6):514-20. [pmid: 7585764].
Brensike JF, Levy RI, Kelsey SF, et al. Effects of therapy with cholestyramine on progression of coronary arteriosclerosis: results of the NHLBI Type II Coronary Intervention Study. Circulation. 1984;69(2):313-24. [pmid: 6360414].
Brown BG, Zhao XQ, Chait A, et al. Simvastatin and niacin, antioxidant vitamins, or the combination for the prevention of coronary disease. N Engl J Med. 2001;345(22):1583-92. [pmid: 11757504].
Butler WJ, Ostrander LD Jr., Carman WJ, et al. Mortality from coronary heart disease in the Tecumseh study. Long-term effect of diabetes mellitus, glucose tolerance and other risk factors. Am J Epidemiol. 1985;121(4):541-7. [pmid: 4014143].
Byington RP, Furberg CD, Crouse JR, 3rd, et al. Pravastatin, Lipids, and Atherosclerosis in the Carotid Arteries (PLAC- II). Am J Cardiol. 1995;76(9):54C-59C.
Campeau L, Hunninghake DB, Knatterud GL, et al. Aggressive cholesterol lowering delays saphenous vein graft atherosclerosis in women, the elderly, and patients with associated risk factors. NHLBI post coronary artery bypass graft clinical trial. Post CABG Trial Investigators. Circulation. 1999;99(25):3241-7. [pmid: 10385497].
Cecil MP, Kosinski AS, Jones MT, et al. The importance of work-up (verification) bias correction in assessing the accuracy of SPECT thallium-201 testing for the diagnosis of coronary artery disease. J Clin Epidemiol. 1996;49(7):735-42. [pmid: 8691222].
Chae SC, Heo J, Iskandrian AS, et al. Identification of extensive coronary artery disease in women by exercise single-photon emission computed tomographic (SPECT) thallium imaging. J Am Coll Cardiol. 1993;21(6):1305-11. [pmid: 8473634].
Chaitman BR, Bourassa MG, Davis K, et al. Angiographic prevalence of high-risk coronary artery disease in patient subsets (CASS). Circulation. 1981;64(2):360-7. [pmid: 7249303].
Chandra NC, Ziegelstein RC, Rogers WJ, et al. Observations of the treatment of women in the United States with myocardial infarction: a report from the National Registry of Myocardial Infarction-I. Arch Intern Med. 1998;158(9):981-8. [pmid: 9588431].
Christenson RH, Duh SH, Newby LK, et al. Cardiac troponin T and cardiac troponin I: relative values in short-term risk stratification of patients with acute coronary syndromes. GUSTO-IIa Investigators Clin Chem. 1998;44(3):494-501.
Christian TF, Miller TD, Bailey KR, et al. Noninvasive identification of severe coronary artery disease using exercise tomographic thallium-201 imaging. Am J Cardiol. 1992;70(1):14-20. [pmid: 1615863].
Clearfield M, Downs JR, Weis S, et al. Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS): efficacy and tolerability of long-term treatment with lovastatin in women. J Womens Health Gend Based Med. 2001;10(10):971-81. [pmid: 11788107].
Collins VR, Dowse GK, Ram P, et al. Non-insulin-dependent diabetes and 11-year mortality in Asian Indian and Melanesian Fijians. Diabet Med. 1996;13(2):125-32. [pmid: 8641116].
Cooper RS, Pacold IV, Ford ES. Age-related differences in case-fatality rates among diabetic patients with myocardial infarction. Findings from National Hospital Discharge Survey, 1979-1987. Diabetes Care. 1991;14(10):903-8. [pmid: 1773689].
Crouse LJ, Harbrecht JJ, Vacek JL, et al. Exercise echocardiography as a screening test for coronary artery disease and correlation with coronary arteriography. Am J Cardiol. 1991;67(15):1213-8. [pmid: 2035443].
Cruz-Vidal M, Garcia-Palmieri MR, Costas R Jr., et al. Abnormal blood glucose and coronary heart disease: the Puerto Rico Heart Health Program. Diabetes Care. 1983;6(6):556-61. [pmid: 6606547].
Dagianti A, Penco M, Agati L, et al. Stress echocardiography: comparison of exercise, dipyridamole and dobutamine in detecting and predicting the extent of coronary artery disease. J Am Coll Cardiol. 1995;26(1):18-25. [pmid: 7797748].
de Grauw WJ, van den Hoogen HJ, van de Lisdonk EH, et al. Control group characteristics and study outcomes: empirical data from a study on mortality of patients with type 2 diabetes mellitus in Dutch general practice. J Epidemiol Community Health. 1998;52(Suppl 1):9S-12S. [pmid: 9764264].
de Vegt F, Dekker JM, Ruhe HG, et al. Hyperglycaemia is associated with all-cause and cardiovascular mortality in the Hoorn population: the Hoorn Study. Diabetologia. 1999;42(8):926-31. [pmid: 10491751].
DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
DeStefano F, Ford ES, Newman J, et al. Risk factors for coronary heart disease mortality among persons with diabetes. Ann Epidemiol. 1993;3(1):27-34. [pmid: 8287153].
Donahue RP, Goldberg RJ, Chen Z, et al. The influence of sex and diabetes mellitus on survival following acute myocardial infarction: a community-wide perspective. J Clin Epidemiol. 1993;46(3):245-52. [pmid: 8455049].
Dorr AE, Gundersen K, Schneider JC Jr., et al. Colestipol hydrochloride in hypercholesterolemic patients--effect on serum cholesterol and mortality. J Chronic Dis. 1978;31(1):5-14. [pmid: 346598].
Downs JR, Clearfield M, Weis S, et al. Primary prevention of acute coronary events with lovastatin in men and women with average cholesterol levels: results of AFCAPS/TexCAPS. Air Force/Texas Coronary Atherosclerosis Prevention Study. JAMA. 1998;279(20):1615-22. [pmid: 9613910].
Eschwege E, Richard JL, Thibult N, et al. Coronary heart disease mortality in relation with diabetes, blood glucose and plasma insulin levels. The Paris Prospective Study, ten years later. Horm Metab Res Suppl. 1985;15:41-6. [pmid: 3908280].
Fava S, Azzopardi J, Muscat HA, et al. Factors that influence outcome in diabetic subjects with myocardial infarction. Diabetes Care. 1993;16(12):1615-8. [pmid: 8299458].
Feskens EJ, Kromhout D. Glucose tolerance and the risk of cardiovascular disease: the Zutphen Study. J Clin Epidemiol. 1992;45(11):1327-34. [pmid: 1432012].
Fitzgerald AP, Jarrett RJ. Are conventional risk factors for mortality relevant in type 2 diabetes?. Diabet Med. 1991;8(5):475-80. [pmid: 1830534].
Fleischmann KE, Hunink MG, Kuntz KM, et al. Exercise echocardiography or exercise SPECT imaging? A meta-analysis of diagnostic test performance. JAMA. 1998;280(10):913-20. [pmid: 9739977].
Fleming RM, Kirkeeide RL, Taegtmeyer H, et al. Comparison of technetium-99m teboroxime tomography with automated quantitative coronary arteriography and thallium-201 tomographic imaging. J Am Coll Cardiol. 1991;17(6):1297-302. [pmid: 2016447].
Folsom AR, Szklo M, Stevens J, et al. A prospective study of coronary heart disease in relation to fasting insulin, glucose, and diabetes. The Atherosclerosis Risk in Communities (ARIC) Study. Diabetes Care. 1997;20(6):935-42. [pmid: 9167103].
Fraser GE, Strahan TM, Sabate J, et al. Effects of traditional coronary risk factors on rates of incident coronary events in a low-risk population. The Adventist Health Study. Circulation. 1992;86(2):406-13. [pmid: 1638709].
Fujimoto WY, Leonetti DL, Bergstrom RW, et al. Glucose intolerance and diabetic complications among Japanese-American women. Diabetes Res Clin Pract. 1991;13(1-2):119-29. [pmid: 1773709].
Fujimoto WY, Leonetti DL, Kinyoun JL, et al. Prevalence of complications among second-generation Japanese-American men with diabetes, impaired glucose tolerance, or normal glucose tolerance. Diabetes. 1987;36(6):730-9. [pmid: 3569672].
Fujioka S, Matsuzawa Y, Tokunaga K, et al. Improvement of glucose and lipid metabolism associated with selective reduction of intra-abdominal visceral fat in premenopausal women with visceral fat obesity. Int J Obes. 1991;15(12):853-9. [pmid: 1794928].
Fuller JH, Shipley MJ, Rose G, et al. Mortality from coronary heart disease and stroke in relation to degree of glycaemia: the Whitehall study. BMJ (Clin Res Ed). 1983;287(6396):867-70. [pmcid: 117638].
Furberg CD, Adams HP Jr., Applegate WB, et al. Effect of lovastatin on early carotid atherosclerosis and cardiovascular events. Asymptomatic Carotid Artery Progression Study (ACAPS) Research Group. Circulation. 1994;90(4):1679-87. [pmid: 7734010].
Galanti G, Sciagra R, Comeglio M, et al. Diagnostic accuracy of peak exercise echocardiography in coronary artery disease: comparison with thallium-201 myocardial scintigraphy. Am Heart J. 1991;122(6):1609-16. [pmid: 1957756].
Galvani M, Ottani F, Ferrini D, et al. Prognostic influence of elevated values of cardiac troponin I in patients with unstable angina. Circulation. 1997;95(8):2053-9. [pmid: 9133515].
Goldschmid MG, Barrett-Connor E, Edelstein SL, et al. Dyslipidemia and ischemic heart disease mortality among men and women with diabetes. Circulation. 1994;89(3):991-7. [pmid: 8124839].
Grady D, Chaput L, Kristof M. Results of Systematic Review of Research on the Diagnosis and Treatment of Coronary Heart Disease in Women. Evidence Report/Technology Assessment No. 7. (Prepared by the University of California, San Francisco-Stanford Evidence-based Practice Center under Contract #290-97-0013.): Agency for Healthcare Research and Quality. October 2002.
Grady D, Rubin SM, Petitti DB, et al. Hormone therapy to prevent disease and prolong life in postmenopausal women. Ann Intern Med. 1992;117(12):1016-37. [pmid: 1443971].
Granger CB, Califf RM, Young S, et al. Outcome of patients with diabetes mellitus and acute myocardial infarction treated with thrombolytic agents. The Thrombolysis and Angioplasty in Myocardial Infarction (TAMI) Study Group. J Am Coll Cardiol. 1993;21(4):920-5. [pmid: 8450161].
Greenland S. Invited commentary: a critical look at some popular meta-analytic methods. Am J Epidemiol. 1994;140(3):290-6. [pmid: 8030632].
Group of Physicians of the Newcastle upon Tyne Region. Trial of clofibrate in the treatment of ischemic heart disease BMJ 1971 4 767 775 4943605
Gupta NC, Esterbrooks DJ, Hilleman DE, et al. Comparison of adenosine and exercise thallium-201 single-photon emission computed tomography (SPECT) myocardial perfusion imaging. The GE SPECT Multicenter Adenosine Study Group. J Am Coll Cardiol. 1992;19(2):248-57. [pmid: 1732349].
Haldane J. The estimation and significance of the logarithm of a ratio of frequencies. Ann Hum Genet. 1955;20:309-314. [pmid: 13314400].
Hambye AS, Vervaet A, Lieber S, et al. Diagnostic value and incremental contribution of bicycle exercise, first-pass radionuclide angiography, and 99mTc-labeled sestamibi single- photon emission computed tomography in the identification of coronary artery disease in patients without infarction. J Nucl Cardiol. 1996;3(6 Pt 1):464-74. [pmid: 8989671].
Hamm CW, Goldmann BU, Heeschen C, et al. Emergency room triage of patients with acute chest pain by means of rapid testing for cardiac troponin T or troponin I. N Engl J Med. 1997;337(23):1648-53. [pmid: 9385123].
Hamm CW, Heeschen C, Goldmann B, et al. Benefit of abciximab in patients with refractory unstable angina in relation to serum troponin T levels. c7E3 Fab Antiplatelet Therapy in Unstable Refractory Angina (CAPTURE) Study Investigators. N Engl J Med. 1999;340(21):1623-9. [pmid: 10341274].
Hansen CL, Crabbe D, Rubin S. Lower diagnostic accuracy of thallium-201 SPECT myocardial perfusion imaging in women: an effect of smaller chamber size. J Am Coll Cardiol. 1996;28(5):1214-9. [pmid: 8890818].
Healy B. The Yentl syndrome. N Engl J Med. 1991;325(4):274-6. [pmid: 2057027].
Heart Protection Study Collaborative Group. Medical Research Council/British Heart Foundation (MRC/BHF) Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial Lancet 2002 360 9326 7 22 12114036
Hecht HS, DeBord L, Sotomayor N, et al. Supine bicycle stress echocardiography: peak exercise imaging is superior to postexercise imaging. J Am Soc Echocardiogr. 1993;6(3 Pt 1):265-71. [pmid: 8333974].
Heeschen C, Hamm CW, Goldmann B, et al. Troponin concentrations for stratification of patients with acute coronary syndromes in relation to therapeutic efficacy of tirofiban. PRISM Study Investigators. Platelet Receptor Inhibition in Ischemic Syndrome Management. Lancet. 1999;354(9192):1757-62. [pmid: 10577636].
Heiba SI, Hayat NJ, Salman HS, et al. Technetium-99m-MIBI myocardial SPECT: supine versus right lateral imaging and comparison with coronary arteriography. J Nucl Med. 1997;38(10):1510-4. [pmid: 9379184].
Heidenreich P, Go A, Melsop K, et al. Prediction of risk for patients with unstable angina. Evidence Report/Technology Assessment No. 31 (prepared by the UCSF Stanford Evidence-based Practice Center under Contract No. 290-97-0013). AHRQ Publication No. 01-E001. Rockville, MD: Agency for Healthcare Research and Quality. December 2000.
Heidenreich PA, Alloggiamento T, Melsop K, et al. The prognostic value of troponin in patients with non-ST elevation acute coronary syndromes: a meta-analysis. J Am Coll Cardiol. 2001;38(2):478-85. [pmid: 11499741].
Herd JA, Ballantyne CM, Farmer JA, et al. Effects of fluvastatin on coronary atherosclerosis in patients with mild to moderate cholesterol elevations (Lipoprotein and Coronary Atherosclerosis Study [LCAS]). Am J Cardiol. 1997;80(3):278-86. [pmid: 9264419].
Herman JB, Medalie JH, Goldbourt U. Differences in cardiovascular morbidity and mortality between previously known and newly diagnosed adult diabetics. Diabetologia. 1977;13(3):229-34. [pmid: 873090].
Heyden S, Heiss G, Bartel AG, et al. Sex differences in coronary mortality among diabetics in Evans County, Georgia. J Chronic Dis. 1980;33(5):265-73. [pmid: 7372764].
Ho YL, Wu CC, Huang PJ, et al. Dobutamine stress echocardiography compared with exercise thallium-201 single-photon emission computed tomography in detecting coronary artery disease-effect of exercise level on accuracy. Cardiology. 1997;88(4):379-85. [pmid: 9197434].
Hoffmann R, Lethen H, Kleinhans E, et al. Comparative evaluation of bicycle and dobutamine stress echocardiography with perfusion scintigraphy and bicycle electrocardiogram for identification of coronary artery disease. Am J Cardiol. 1993;72(7):555-9. [pmid: 8362770].
Howard BV, Lee ET, Cowan LD, et al. Coronary heart disease prevalence and its relation to risk factors in American Indians. The Strong Heart Study. Am J Epidemiol. 1995;142(3):254-68. [pmid: 7631630].
Hoy W, Light A, Megill D. Cardiovascular disease in Navajo Indians with type 2 diabetes. Public Health Rep. 1995;110(1):87-94. [pmid: 7838949].
Iskandrian AE, Heo J, Nallamothu N. Detection of coronary artery disease in women with use of stress single-photon emission computed tomography myocardial perfusion imaging. J Nucl Cardiol. 1997;4(4):329-35. [pmid: 9278880].
Jarrett RJ, McCartney P, Keen H. The Bedford survey: ten year mortality rates in newly diagnosed diabetics, borderline diabetics and normoglycaemic controls and risk indices for coronary heart disease in borderline diabetics. Diabetologia. 1982;22(2):79-84. [pmid: 7060853].
Jousilahti P, Vartiainen E, Tuomilehto J, et al. Sex, age, cardiovascular risk factors, and coronary heart disease: a prospective follow-up study of 14 786 middle-aged men and women in Finland. Circulation. 1999;99(9):1165-72. [pmid: 10069784].
Kanaya AM, Grady D, Barrett-Connor E. Explaining the sex difference in coronary heart disease mortality among patients with type 2 diabetes mellitus: a meta-analysis. Arch Intern Med. 2002;162(15):1737-45. [pmid: 12153377].
Kang X, Berman DS, Lewin H, et al. Comparative ability of myocardial perfusion single-photon emission computed tomography to detect coronary artery disease in patients with and without diabetes mellitus. Am Heart J. 1999;137(5):949-57. [pmid: 10220646].
Kannel WB, McGee DL. Diabetes and glucose tolerance as risk factors for cardiovascular disease: the Framingham study. Diabetes Care. 1979;2(2):120-6. [pmid: 520114].
Kannel WB, McGee DL. Diabetes and cardiovascular disease. The Framingham study. JAMA. 1979;241(19):2035-8. [pmid: 430798].
Kannel WB, Wilson PW. Risk factors that attenuate the female coronary disease advantage. Arch Intern Med. 1995;155(1):57-61. [pmid: 7802521].
Keil JE, Sutherland SE, Knapp RG, et al. Mortality rates and risk factors for coronary disease in black as compared with white men and women [see comments]. N Engl J Med. 1993;329(2):73-8. [pmid: 8510705].
Kiat H, Van Train KF, Maddahi J, et al. Development and prospective application of quantitative 2-day stress-rest Tc-99m methoxy isobutyl isonitrile SPECT for the diagnosis of coronary artery disease. Am Heart J. 1990;120(6 Pt 1):1255-66. [pmid: 2248175].
Kleinman JC, Donahue RP, Harris MI, et al. Mortality among diabetics in a national sample. Am J Epidemiol. 1988;128(2):389-401. [pmid: 3394705].
Kuusisto J, Mykkanen L, Pyorala K, et al. NIDDM and its metabolic control predict coronary heart disease in elderly subjects. Diabetes. 1994;43(8):960-7. [pmid: 8039603].
Kwok Y, Kim C, Grady D, et al. Meta-analysis of exercise testing to detect coronary artery disease in women. Am J Cardiol. 1999;83(5):660-6. [pmid: 10080415].
Laakso M, Ronnemaa T, Lehto S, et al. Does NIDDM increase the risk for coronary heart disease similarly in both low- and high-risk populations?. Diabetologia. 1995;38(4):487-93. [pmid: 7796991].
Laakso M, Ronnemaa T, Pyorala K, et al. Atherosclerotic vascular disease and its risk factors in non-insulin-dependent diabetic and nondiabetic subjects in Finland. Diabetes Care. 1988;11(6):449-63. [pmid: 3402300].
Lagerqvist B, Safstrom K, Stahle E, et al. Is early invasive treatment of unstable coronary artery disease equally effective for both women and men? FRISC II Study Group Investigators. J Am Coll Cardiol. 2001;38(1):41-8. [pmid: 11451294].
Lapidus L. Ischaemic heart disease, stroke and total mortality in women--results from a prospective population study in Gothenburg, Sweden. Acta Med Scand Suppl. 1985;705:1-42. [pmid: 3879572].
LaRosa JC. Triglycerides and coronary risk in women and the elderly. Arch Intern Med. 1997;157:961-968. [pmid: 9140266].
LaRosa JC, He J, Vupputuri S. Effect of statins on risk of coronary disease: a meta-analysis of randomized controlled trials. JAMA. 1999;282:2340-6. [pmid: 10612322].
Laurienzo JM, Cannon RO, 3rd, Quyyumi AA, et al. Improved specificity of transesophageal dobutamine stress echocardiography compared to standard tests for evaluation of coronary artery disease in women presenting with chest pain. Am J Cardiol. 1997;80(11):1402-7. [pmid: 9399711].
Lee WL, Cheung AM, Cape D, et al. Impact of diabetes on coronary artery disease in women and men: a meta-analysis of prospective studies. Diabetes Care. 2000;23(7):962-8. [pmid: 10895847].
Lerner DJ, Kannel WB. Patterns of coronary heart disease morbidity and mortality in the sexes: a 26-year follow-up of the Framingham population. Am Heart J. 1986;111(2):383-90. [pmid: 3946178].
Lewis SJ, Sacks FM, Mitchell JS, et al. Effect of pravastatin on cardiovascular events in women after myocardial infarction: the cholesterol and recurrent events (CARE) trial. J Am Coll Cardiol. 1998;32(1):140-6. [pmid: 9669262].
Liao Y, Cooper RS, Ghali JK, et al. Sex differences in the impact of coexistent diabetes on survival in patients with coronary heart disease. Diabetes Care. 1993;16(5):708-13. [pmid: 8495609].
Lindahl B, Venge P, Wallentin L. Relation between troponin T and the risk of subsequent cardiac events in unstable coronary artery disease. The FRISC study group. Circulation. 1996;93(9):1651-7. [pmid: 8653870].
Lindeman RD, Romero LJ, Hundley R, et al. Prevalences of type 2 diabetes, the insulin resistance syndrome, and coronary heart disease in an elderly, biethnic population. Diabetes Care. 1998;21(6):959-66. [pmid: 9614614].
Lomuscio A, Castagnone M, Vergani D, et al. Clinical correlation between diabetic and non diabetic patients with myocardial infarction. Acta Cardiol. 1991;46(5):543-54. [pmid: 1789049].
Long-Term Intervention with Pravastatin in Ischaemic Disease (LIPID) Study Group. Prevention of cardiovascular events and death with pravastatin in patients with coronary heart disease and a broad range of initial cholesterol levels N Engl J Med 1998 339 19 1349 57 9841303
Lowe LP, Liu K, Greenland P, et al. Diabetes, asymptomatic hyperglycemia, and 22-year mortality in black and white men. The Chicago Heart Association Detection Project in Industry Study. Diabetes Care. 1997;20(2):163-9. [pmid: 9118765].
Luotolahti M, Saraste M, Hartiala J. Exercise echocardiography in the diagnosis of coronary artery disease. Ann Med. 1996;28(1):73-7. [pmid: 8932510].
Luscher MS, Thygesen K, Ravkilde J, et al. Applicability of cardiac troponin T and I for early risk stratification in unstable coronary artery disease. TRIM Study Group. Thrombin Inhibition in Myocardial ischemia. Circulation. 1997;96(8):2578-85. [pmid: 9355897].
Mahmarian JJ, Boyce TM, Goldberg RK, et al. Quantitative exercise thallium-201 single photon emission computed tomography for the enhanced diagnosis of ischemic heart disease. J Am Coll Cardiol. 1990;15(2):318-29. [pmid: 2405036].
Mak KH, Ang ES, Goh AS, et al. Myocardial perfusion imaging with technetium-99m sestamibi SPECT in the evaluation of coronary artery disease. Australas Radiol. 1995;39(2):112-7. [pmid: 7605313].
Mak KH, Moliterno DJ, Granger CB, et al. Influence of diabetes mellitus on clinical outcome in the thrombolytic era of acute myocardial infarction. GUSTO-I Investigators. Global Utilization of Streptokinase and Tissue Plasminogen Activator for Occluded Coronary Arteries. J Am Coll Cardiol. 1997;30(1):171-9. [pmid: 9207639].
Manolio TA, Pearson TA, Wenger NK, et al. Cholesterol and heart disease in older persons and women: review of an NHLBI workshop. Ann Epidemiol 1992; 2: 161-176 1992.
Manson JE, Colditz GA, Stampfer MJ, et al. A prospective study of maturity-onset diabetes mellitus and risk of coronary heart disease and stroke in women. Arch Intern Med. 1991;151(6):1141-7. [pmid: 2043016].
Marangelli V, Iliceto S, Piccinni G, et al. Detection of coronary artery disease by digital stress echocardiography: comparison of exercise, transesophageal atrial pacing and dipyridamole echocardiography. J Am Coll Cardiol. 1994;24(1):117-24. [pmid: 8006254].
Marwick TH, D'Hondt AM, Mairesse GH, et al. Comparative ability of dobutamine and exercise stress in inducing myocardial ischaemia in active patients. Br Heart J. 1994;72(1):31-8. [pmid: 8068466].
Marwick TH, Torelli J, Harjai K, et al. Influence of left ventricular hypertrophy on detection of coronary artery disease using exercise echocardiography. J Am Coll Cardiol. 1995;26(5):1180-6. [pmid: 7594030].
Melchior T, Kober L, Madsen CR, et al. Accelerating impact of diabetes mellitus on mortality in the years following an acute myocardial infarction. TRACE Study Group. Trandolapril Cardiac Evaluation. Eur Heart J. 1999;20(13):973-8. [pmid: 10361050].
Miettinen H, Lehto S, Salomaa V, et al. Impact of diabetes on mortality after the first myocardial infarction. The FINMONICA Myocardial Infarction Register Study Group [see comments]. Diabetes Care. 1998;21(1):69-75. [pmid: 9538972].
Miettinen TA, Pyorala K, Olsson AG, et al. Cholesterol-lowering therapy in women and elderly patients with myocardial infarction or angina pectoris: findings from the Scandinavian Simvastatin Survival Study (4S). Circulation. 1997;96(12):4211-8. [pmid: 9416884].
Minoves M, Garcia A, Magrina J, et al. Evaluation of myocardial perfusion defects by means of "bull's eye" images. Clin Cardiol. 1993;16(1):16-22. [pmid: 8416754].
Mitchell BD, Hazuda HP, Haffner SM, et al. Myocardial infarction in Mexican-Americans and non-Hispanic whites. The San Antonio Heart Study. Circulation. 1991;83(1):45-51. [pmid: 1984897].
Morise AP, Diamond GA, Detrano R, et al. Incremental value of exercise electrocardiography and thallium-201 testing in men and women for the presence and extent of coronary artery disease. Am Heart J. 1995;130(2):267-76. [pmid: 7631606].
Moses LE, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. 1993;12(14):1293-316. [pmid: 8210827].
National Institutes of Health Consensus Conference. Triglyceride, high density lipoprotein and coronary heart disease JAMA 1993 269 505 510 8419671
Nguyen T, Heo J, Ogilby JD, et al. Single photon emission computed tomography with thallium-201 during adenosine-induced coronary hyperemia: correlation with coronary arteriography, exercise thallium imaging and two-dimensional echocardiography. J Am Coll Cardiol. 1990;16(6):1375-83. [pmid: 2229789].
Niemeyer MG, Van der Wall EE, Kuyper AF, et al. Discordance of visual and quantitative analysis regarding false negative and false positive test results in thallium-201 myocardial perfusion scintigraphy. Am J Physiol Imaging. 1991;6(1):34-43. [pmid: 2039654].
Niskanen L, Turpeinen A, Penttila I, et al. Hyperglycemia and compositional lipoprotein abnormalities as predictors of cardiovascular mortality in type 2 diabetes: a 15-year follow-up from the time of diagnosis. Diabetes Care. 1998;21(11):1861-9. [pmid: 9802734].
OConnor PJ, Crabtree BF, Nakamura RM. Mortality experience of Navajos with type 2 diabetes mellitus. Ethn Health. 1997;2(3):155-62. [pmid: 9426980].
Ohman EM, Armstrong PW, Christenson RH, et al. Cardiac troponin T levels for risk stratification in acute myocardial ischemia. GUSTO IIA Investigators. N Engl J Med. 1996;335(18):1333-41. [pmid: 8857016].
Orchard TJ. The impact of gender and general risk factors on the occurrence of atherosclerotic vascular disease in non-insulin-dependent diabetes mellitus. Ann Med. 1996;28(4):323-33. [pmid: 8862687].
Orlander PR, Goff DC, Morrissey M, et al. The relation of diabetes to the severity of acute myocardial infarction and post-myocardial infarction survival in Mexican-Americans and non-Hispanic whites. The Corpus Christi Heart Project. Diabetes. 1994;43(7):897-902. [pmid: 8013754].
Ozdemir K, Kisacik HL, Oguzhan A, et al. Comparison of exercise stress testing with dobutamine stress echocardiography and radionuclide ventriculography for diagnosis of coronary artery disease. Jpn Heart J. 1999;40(6):715-27. [pmid: 10737555].
Palmas W, Friedman JD, Diamond GA, et al. Incremental value of simultaneous assessment of myocardial function and perfusion with technetium-99m sestamibi for prediction of extent of coronary artery disease. J Am Coll Cardiol. 1995;25(5):1024-31. [pmid: 7897112].
Pan WH, Cedres LB, Liu K, et al. Relationship of clinical diabetes and asymptomatic hyperglycemia to risk of coronary heart disease mortality in men and women. Am J Epidemiol. 1986;123(3):504-16. [pmid: 3946397].
Pedersen TR, Berg K, Cook TJ, et al. Safety and tolerability of cholesterol lowering with simvastatin during 5 years in the Scandinavian Simvastatin Survival Study. Arch Intern Med. 1996;156(18):2085-92. [pmid: 8862101].
Pell S, D'Alonzo CA. Factors associated with long-term survival of diabetics. JAMA. 1970;214(10):1833-40. [pmid: 5537338].
Petitti D. Statistical Methods in Meta-Analysis. In: Meta-Analysis, Deicion Analysis and Cost-Effectiveness Analysis. New York: Oxford University Press; 1994. p. 90-114.
Pignone M, Phillips C, Mulrow C. Use of lipid lowering drugs for primary prevention of coronary heart disease: meta-analysis of randomised trials. BMJ. 2000;321:1-5. [pmid: 10875807].
Pitt B, Mancini GB, Ellis SG, et al. Pravastatin limitation of atherosclerosis in the coronary arteries (PLAC I): reduction in atherosclerosis progression and clinical events. PLAC I investigation. J Am Coll Cardiol. 1995;26(5):1133-9. [pmid: 7594023].
Plehn JF, Davis BR, Sacks FM, et al. Reduction of stroke incidence after myocardial infarction with pravastatin: the Cholesterol and Recurrent Events (CARE) study. The Care Investigators. Circulation. 1999;99(2):216-23. [pmid: 9892586].
Post Coronary Artery Bypass Graft Trial Investigators. The effect of aggressive lowering of low-density lipoprotein cholesterol levels and low-dose anticoagulation on obstructive changes in saphenous-vein coronary-artery bypass grafts N Engl J Med 1997 336 3 153 62 8992351
The Pravastatin Multinational Study Group for Cardiac Risk Patients. Effects of pravastatin in patients with serum total cholesterol levels from 5.2 to 7.8 mmol/liter (200 to 300 mg/dl) plus two additional atherosclerotic risk factors Am J Cardiol 1993 72 14 1031 7 8213583
Quinones MA, Verani MS, Haichin RM, et al. Exercise echocardiography versus 201Tl single-photon emission computed tomography in evaluation of coronary artery disease. Analysis of 292 patients. Circulation. 1992;85(3):1026-31. [pmid: 1537100].
Ravkilde J, Horder M, Gerhardt W, et al. Diagnostic performance and prognostic value of serum troponin T in suspected acute myocardial infarction. Scand J Clin Lab Invest. 1993;53(7):677-85. [pmid: 8272756].
Research Committee of the Scottish Society of Physicians: Ischemic Heart Disease: a secondary prevention trial using clofibrate. BMJ 1971 4 775 784 4943606
Reunanen A. Mortality in type 2 diabetes. Ann Clin Res. 1983;15(Suppl 37):26-8. [pmid: 6679186].
Rewers M, Shetterly SM, Baxter J, et al. Prevalence of coronary heart disease in subjects with normal and impaired glucose tolerance and non-insulin-dependent diabetes mellitus in a biethnic Colorado population. The San Luis Valley Diabetes Study. Am J Epidemiol. 1992;135(12):1321-30. [pmid: 1510079].
Riegger G, Abletshauser C, Ludwig M, et al. The effect of fluvastatin on cardiac events in patients with symptomatic coronary artery disease during one year of treatment. Atherosclerosis. 1999;144(1):263-70. [pmid: 10381299].
Rodriguez BL, Lau N, Burchfiel CM, et al. Glucose intolerance and 23-year risk of coronary heart disease and total mortality: the Honolulu Heart Program. Diabetes Care. 1999;22(8):1262-5. [pmid: 10480768].
Roger VL, Pellikka PA, Bell MR, et al. Sex and test verification bias. Impact on the diagnostic value of exercise echocardiography. Circulation. 1997;95(2):405-10. [pmid: 9008457].
Roger VL, Pellikka PA, Oh JK, et al. Identification of multivessel coronary artery disease by exercise echocardiography. J Am Coll Cardiol. 1994;24(1):109-14. [pmid: 8006251].
Rubello D, Zanco P, Candelpergher G, et al. Usefulness of 99mTc-MIBI stress myocardial SPECT bull's-eye quantification in coronary artery disease. Q J Nucl Med. 1995;39(2):111-5. [pmid: 8574803].
Rytter L, Troelsen S, Beck-Nielsen H. Prevalence and mortality of acute myocardial infarction in patients with diabetes. Diabetes Care. 1985;8(3):230-4. [pmid: 4006657].
Sacks FM, Pfeffer MA, Moye LA, et al. The effect of pravastatin on coronary events after myocardial infarction in patients with average cholesterol levels. Cholesterol and Recurrent Events Trial investigators. N Engl J Med. 1996;335(14):1001-9. [pmid: 8801446].
Safstrom K, Lindahl B, Swahn E. Risk stratification in unstable coronary artery disease--exercise test and troponin T from a gender perspective. FRISC-Study Group. Fragmin during InStability in Coronary artery disease. J Am Coll Cardiol. 2000;35(7):1791-800. [pmid: 10841226].
Salustri A, Pozzoli MM, Hermans W, et al. Relationship between exercise echocardiography and perfusion single-photon emission computed tomography in patients with single-vessel coronary artery disease. Am Heart J. 1992;124(1):75-83. [pmid: 1615830].
Santana-Boado C, Candell-Riera J, Castell-Conesa J, et al. Diagnostic accuracy of technetium-99m-MIBI myocardial SPECT in women and men. J Nucl Med. 1998;39(5):751-5. [pmid: 9591568].
Sawada SG, Ryan T, Fineberg NS, et al. Exercise echocardiographic detection of coronary artery disease in women. J Am Coll Cardiol. 1989;14(6):1440-7. [pmid: 2809000].
Scandinavian Simvastatin Survival Study Group. Randomised trial of cholesterol lowering in 4444 patients with coronary heart disease: the Scandinavian Simvastatin Survival Study (4S) Lancet 1994 344 8934 1383 9 7968073
Scheidt-Nave C, Barrett-Connor E, Wingard DL. Resting electrocardiographic abnormalities suggestive of asymptomatic ischemic heart disease associated with non-insulin-dependent diabetes mellitus in a defined population. Circulation. 1990;81(3):899-906. [pmid: 2306839].
Sciammarella MG, Fragasso G, Gerundini P, et al. 99Tcm-MIBI single photon emission tomography (SPET) for detecting myocardial ischaemia and necrosis in patients with significant coronary artery disease. Nucl Med Commun. 1992;13(12):871-8. [pmid: 1465270].
Seeman T, Mendes de Leon C, Berkman L, et al. Risk factors for coronary heart disease among older men and women: a prospective study of community-dwelling elderly. Am J Epidemiol. 1993;138(12):1037-49. [pmid: 8266906].
Seyoum B, Abdulkadir J, Berhanu P, et al. Profile of coronary artery risk factors in Ethiopian diabetic patients. East Afr Med J. 1999;76(2):105-7. [pmid: 10442133].
Sharir T, Germano G, Waechter PB, et al. A new algorithm for the quantitation of myocardial perfusion SPECT. II: validation and diagnostic yield. J Nucl Med. 2000;41(4):720-7. [pmid: 10768575].
Shepherd J, Blauw GJ, Murphy MB, et al. Pravastatin in elderly individuals at risk of vascular disease (PROSPER): a randomised controlled trial. Lancet. 2002;360(9346):1623-30. [pmid: 12457784].
Shepherd J, Cobbe SM, Ford I. Prevention of coronary heart disease with pravastatin in men with hypercholesterolemia. N Engl J Med. 1995;333:1301-7. [pmid: 7566020].
Sievers ML, Nelson RG, Knowler WC, et al. Impact of NIDDM on mortality and causes of death in Pima Indians. Diabetes Care. 1992;15(11):1541-9. [pmid: 1468284].
Simons LA, McCallum J, Friedlander Y, et al. Diabetes, mortality and coronary heart disease in the prospective Dubbo study of Australian elderly. Aust N Z J Med. 1996;26(1):66-74. [pmid: 8775531].
Singer DE, Moulton AW, Nathan DM. Diabetic myocardial infarction. Interaction of diabetes with other preinfarction risk factors. Diabetes. 1989;38(3):350-7. [pmid: 2917699].
Sketch MH, Mohiuddin SM, Lynch JD, et al. Significant sex differences in the correlation of electrocardiographic exercise testing and coronary arteriograms. Am J Cardiol. 1975;36(2):169-73. [pmid: 1155337].
Solot G, Hermans J, Merlo P, et al. Correlation of 99Tcm-sestamibi SPECT with coronary angiography in general hospital practice. Nucl Med Commun. 1993;14(1):23-9. [pmid: 8423930].
Stamler J, Vaccaro O, Neaton JD, et al. Diabetes, other risk factors, and 12-year cardiovascular mortality for men screened in the Multiple Risk Factor Intervention Trial. Diabetes Care. 1993;16(2):434-44. [pmid: 8432214].
Steingart RM, Packer M, Hamm P, et al. Sex differences in the management of coronary artery disease. Survival and Ventricular Enlargement Investigators. N Engl J Med. 1991;325(4):226-30. [pmid: 2057023].
Stengard JH, Tuomilehto J, Pekkanen J, et al. Diabetes mellitus, impaired glucose tolerance and mortality among elderly men: the Finnish cohorts of the Seven Countries Study. Diabetologia. 1992;35(8):760-5. [pmid: 1511803].
Stubbs P, Collinson P, Moseley D, et al. Prospective study of the role of cardiac troponin T in patients admitted with unstable angina. BMJ. 1996;313(7052):262-4. [pmid: 8704534].
Sylven C, Hagerman I, Ylen M, et al. Variance ECG detection of coronary artery disease--a comparison with exercise stress test and myocardial scintigraphy. Clin Cardiol. 1994;17(3):132-40. [pmid: 8168281].
Taillefer R, DePuey EG, Udelson JE, et al. Comparative diagnostic accuracy of Tl-201 and Tc-99m sestamibi SPECT imaging (perfusion and ECG-gated SPECT) in detecting coronary artery disease in women. J Am Coll Cardiol. 1997;29(1):69-77. [pmid: 8996297].
Takeuchi M, Sonoda S, Miura Y, et al. Comparative diagnostic value of dobutamine stress echocardiography and stress thallium-201 single-photon-emission computed tomography for detecting coronary artery disease in women. Coron Artery Dis. 1996;7(11):831-5. [pmid: 8993941].
Tansey MJ, Opie LH, Kennelly BM. High mortality in obese women diabetics with acute myocardial infarction. BMJ. 1977;1(6077):1624-6. [pmid: 871698].
Tawa CB, Baker WB, Kleiman NS, et al. Comparison of adenosine echocardiography, with and without isometric handgrip, to exercise echocardiography in the detection of ischemia in patients with coronary artery disease. J Am Soc Echocardiogr. 1996;9(1):33-43. [pmid: 8679235].
Teo KK, Burton JR, Buller CE, et al. Long-term effects of cholesterol lowering and angiotensin-converting enzyme inhibition on coronary atherosclerosis: The Simvastatin/Enalapril Coronary Atherosclerosis Trial (SCAT). Circulation. 2000;102(15):1748-54. [pmid: 11023927].
Thom TJ. Cardiovascular disease mortality among United States women. In: Eaker ED, Packard B, Wenger NK, et al., editors. Coronary Heart Disease in Women. New York: Haymarket Doyma; 1987. p. 270.
Tonkin AM, Colquhoun D, Emberson J, et al. Effects of pravastatin in 3260 patients with unstable angina: results from the LIPID study. Lancet. 2000;356(9245):1871-5. [pmid: 11130382].
UK Prospective Diabetes Study (UKPDS) Group. Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS33). [published erratum appears in Lancet 1999 Aug 14;354(9178):602] [see comments] Lancet 1998 352 9131 837 53 9742976
UK Prospective Diabetes Study (UKPDS) Group. Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS34). [see comments] [published erratum appears in Lancet 1998 Nov 7;352(9139):1557] Lancet 1998 352 9131 854 65 9742977
Van Train KF, Areeda J, Garcia EV, et al. Quantitative same-day rest-stress technetium-99m-sestamibi SPECT: definition and validation of stress normal limits and criteria for abnormality. J Nucl Med. 1993;34(9):1494-502. [pmid: 8355069].
Van Train KF, Garcia EV, Maddahi J, et al. Multicenter trial validation for quantitative analysis of same-day rest-stress technetium-99m-sestamibi myocardial tomograms. J Nucl Med. 1994;35(4):609-18. [pmid: 8151383].
Van Train KF, Maddahi J, Berman DS, et al. Quantitative analysis of tomographic stress thallium-201 myocardial scintigrams: a multicenter trial. J Nucl Med. 1990;31(7):1168-79. [pmid: 2194003].
Vilbergsson S, Sigurdsson G, Sigvaldason H, et al. Coronary heart disease mortality amongst non-insulin-dependent diabetic subjects in Iceland: the independent effect of diabetes. The Reykjavik Study 17-year follow up. J Intern Med. 1998;244(4):309-16. [pmid: 9797494].
Walsh J, Grady D. Treatment of hyperlipidemia in women. JAMA. 1995;274:1152-2258. [pmid: 7563487].
Wei M, Gaskill SP, Haffner SM, et al. Effects of diabetes and level of glycemia on all-cause and cardiovascular mortality. The San Antonio Heart Study. Diabetes Care. 1998;21(7):1167-72. [pmid: 9653614].
Weiner DA, Ryan TJ, McCabe CH, et al. Exercise stress testing. Correlations among history of angina, ST-segment response and prevalence of coronary-artery disease in the Coronary Artery Surgery Study (CASS). N Engl J Med. 1979;301(5):230-5. [pmid: 449990].
Wenger NK, Speroff L, Packard B. Cardiovascular health and disease in women. N Engl J Med. 1993;329(4):247-56. [pmid: 8316269].
White HD, Simes RJ, Anderson NE, et al. Pravastatin therapy and the risk of stroke. N Engl J Med. 2000;343(5):317-26. [pmid: 10922421].
Williams MJ, Marwick TH, O'Gorman D, et al. Comparison of exercise echocardiography with an exercise score to diagnose coronary artery disease in women. Am J Cardiol. 1994;74(5):435-8. [pmid: 8059721].
Yano K, Kagan A, McGee D, et al. Glucose intolerance and nine-year mortality in Japanese men in Hawaii. Am J Med. 1982;72(1):71-80. [pmid: 7058826].
Yusuf S, Sleight P, Pogue J, et al. Effects of an angiotensin-converting-enzyme inhibitor, ramipril, on cardiovascular events in high-risk patients. The Heart Outcomes Prevention Evaluation Study Investigators [see comments] [published errata appear in N Engl J Med 2000 Mar 9;342(10):748 and 2000 May 4;342(18):1376]. N Engl J Med. 2000;342(3):145-53. [pmid: 10639539].
Zuanetti G, Latini R, Maggioni AP, et al. Influence of diabetes on mortality in acute myocardial infarction: data from the GISSI-2 study. J Am Coll Cardiol. 1993;22(7):1788-94. [pmid: 8245329].