# Appendix D Abbreviations and Acronyms

ACE | angiotensin converting enzyme
AHRQ | Agency for Healthcare Research and Quality
CABG | coronary artery bypass grafting
CHD | coronary heart disease
CKMB | creatine kinase myocardial bands
CHF | congestive heart failure
CVD | cardiovascular disease
CI | confidence interval
DTS | Duke Treadmill Score
ECHO | echocardiography
EKG | electrocardiogram
EPC | Evidence-based Practice Center
ETT | exercise treadmill test
HDL | High density lipoprotein
HDL-C | High density lipoprotein cholesterol
ICD-9 | International Classification of Diseases, Ninth Revision
LDL | Low density lipoprotein
LDL-C | Low density lipoprotein cholesterol
LM | Left main coronary artery
Lp(a) | lipoprotein a
mg | milligrams
MI | myocardial infarction
MIBI | technetium Tc 99m sestamibi
mm | millimeter
mmol | millimole
MPI | myocardial perfusion-imaging
MRC/BHF | Medical Research Council/British Heart Foundation
MB | myocardial bands
N | number
NA | not available
NFMI | nonfatal myocardial infarction
ng | nanograms
NHLBI | National Heart Lung and Blood Institute
OR | odds ratio
PCI | percutaneous coronary intervention
PD | perfusion defect
PTCA | percutaneous coronary angioplasty
RWMA | regional wall motion abnormality
RR | relative risk
SPECT | single photon emission computed tomography
TI | thallous chloride TI 201 (thallium)

Names of studies:

4S | Scandinavian Simvastatin Survival Study
ACAPS | Asymptomatic Carotid Artery Progression Study
AFCAPS/TEXCAPS | Air Force/Texas Coronary Artherosclerosis Prevention Study
ALLHAT-LLT | Antihypertensive and Lipid-Lowering treatment to prevent Heart Attack Trial - Lipid-Lowering Trial
CARE | Cholesterol and Recurrent Events trial
HPS | Heart Protection Study
LIPID | Long-term Intervention with Pravastatin in Ischaemic Disease
NHANES I | National Health and Nutrition Examination Survey I
PLAC I | Pravastatin Limitation of Atherosclerosis in the Coronary Arteries
PLAC II | Pravastatin, Lipids and Atherosclerosis in the Carotid Arteries
PROSPER | PROspective Study of Pravastatin in the Elderly at Risk
TIMI | Thrombolysis in Myocardial Infarction
WHO-MONICA | World Health Organization-Monitoring of Trends and Determinants in Cardiovascular Disease