# Appendix A Peer Reviewers

## Expert Peer Reviewers

[underlined: Overall Reviewers]
Elizabeth Barrett-Connor, MD | University of California, San Diego
JoAnn Manson, MD, DrPH | Harvard Medical School, Brigham and Women's Hospital
Lori Mosca, MD, MPH, PhD | Columbia University
Noninvasive Diagnostics:
C. Noel Bairey Merz, MD | Cedars-Sinai Medical Center
Pamela S. Douglas, MD | University of Wisconsin, Madison
Lipid lowering:
Vera Bittner, MD, MSPH | University of Alabama at Birmingham
Robert H. Knopp, MD | Northwest Lipid Research Clinic, University of Washington School of Medicine
Diabetes as a risk factor:
Trevor Orchard, MBBCh, MMedSi | University of Pittsburgh
Troponin:
E. Magnus Ohman, MD | University of North Carolina at Chapel Hill

Advice was also solicited from representatives of Partner Organizations, including:

Robert Christenson, PhD | American Association for Clinical Chemistry
Sharonne N. Hayes, M.D., F.A.C.C. | American College of Cardiology
Rosalind Fabunmi, Ph.D. | American Heart Association
Mary Norine Walsh, MD Mary Winston, Ed.D. | American College of Cardiology American Heart Association