# Evidence Tables

Evidence Table 1. Articles containing evidence on key question arranged by key question, type of research design, and level of quality

1.01 Exercise tolerance testing
Systematic Review
| ^a^Fleischmann KE, Hunink MG, Kuntz KM, Douglas PS. Exercise echocardiography or exercise SPECT imaging? A meta-analysis of diagnostic test performance. JAMA 1998;280(10):913–2.
| ^a^Kwok Y, Kim C, Grady D, Segal M, Redberg R. Meta-analysis of exercise testing to detect coronary artery disease in women. Am J Cardiol 1999;83(5):660–6.
Cross Sectional
| Iskandrian AE, Heo J, Nallamothu N. Detection of coronary artery disease in women with use of stress single-photon emission computed tomography myocardial perfusion imaging. J Nucl Cardiol 1997;4:329–35.
| Miller TD, Roger VL, Milavetz JJ, Hopfenspirger MR, Milavetz DL, Hodge DO, et al. Assessment of the exercise electrocardiogram in women versus men using tomogrphic myocardial perfusion imaging as the reference standard. Am J Cardiol 2001;87:868–73.
1.02 Exercise echocardiogram
Systematic Review
| ^a^Fleischmann KE, Hunink MG, Kuntz KM, Douglas PS. Exercise echocardiography or exercise SPECT imaging? A meta-analysis of diagnostic test performance. JAMA 1998;280(10):913–20.
| ^a^Kwok Y, Kim C, Grady D, Segal M, Redberg R. Meta-analysis of exercise testing to detect coronary artery disease in women. Am J Cardiol 1999;83(5):660–6.
1.03 Coronary artery calcification score
Cross-sectional
| ^a^Budoff MJ, Shokooh S, Shavelle RM, Kim HT, French WJ. Electron beam tomography and angiography: sex differences. Am Heart J 2002;143(5):877–82.
| ^a^Detrano R, Hsiai T, Wang S, Puentes G, Fallavollita J, Shields P, et al. Prognostic value of coronary calcification and angiographic stenoses in patients undergoing coronary angiography. J Am Coll Cardiol 1996;27(2):285–90.
2.01 Aspirin
Systematic Review
| ^a^Collaborative overview of randomised trials of antiplatelet therapy--I: Prevention of death, myocardial infarction, and stroke by prolonged antiplatelet therapy in various categories of patients. Antiplatelet Trialists' Collaboration. BMJ 1994;308(6921):81106.
Clinical Trial
| ^a^Randomised trial of intravenous streptokinase, oral aspirin, both, or neither among 17,187 cases of suspected acute myocardial infarction: ISIS-2. ISIS-2 (Second International Study of Infarct Survival) Collaborative Group. Lancet 1988;2(8607):349–60.
| ^a^de Gaetano G. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. Lancet 2001;357(9250):89–95.
| ^a^Hansson L, Zanchetti A, Carruthers SG, Dahlof B, Elmfeldt D, Julius S, et al. Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. HOT Study Group. Lancet 1998;351(9118):1755–62.
| ^a^Kjeldsen SE, Kolloch RE, Leonetti G, Mallion JM, Zanchetti A, Elmfeldt D, et al. Influence of gender and age on preventing cardiovascular disease by antihypertensive treatment and acetylsalicylic acid. The HOT study. Hypertension Optimal Treatment. J Hypertens 2000;18(5):629–42.
Prospective Cohort
| ^a^Manson JE, Stampfer MJ, Colditz GA, Willett WC, Rosner B, Speizer FE, et al. A prospective study of aspirin use and primary prevention of cardiovascular disease in women. JAMA 1991;266(4):521–7.
2.02 Beta-blockers
Systematic Review
| The Beta-Blocker Pooling Project (BBPP): subgroup findings from randomized trials in post infarction patients. The Beta-Blocker Pooling Project Research Group. Eur Heart J 1988;9(1):8–16.
| Leizorovicz A, Lechat P, Cucherat M, Bugnard F. Bisoprolol for the treatment of chronic heart failure: a meta-analysis on individual data of two placebo-controlled studies--CIBIS and CIBIS II. Cardiac Insufficiency Bisoprolol Study. Am Heart J 2002;143(2):301–7.
| Olsson G, Wikstrand J, Warnold I, Manger Cats V, McBoyle D, Herlitz J, et al. Metoprolol-induced reduction in postinfarction mortality: pooled results from five double-blind randomized trials. Eur Heart J 1992;13(1):28–32.
Clinical Trial
| Ghali JK, Pina IL, Gottlieb SS, Deedwania PC, Wikstrand JC. Metoprolol CR/XL in female patients with heart failure: analysis of the experience in Metoprolol Extended-Release Randomized Intervention Trial in Heart Failure (MERIT-HF). Circulation 2002;105(13):1585–91.
2.03 Angiotensin converting enzyme (ACE) inhibitors
Systematic Review
| ^a^Indications for ACE inhibitors in the early treatment of acute myocardial infarction: systematic overview of individual data from 100,000 patients in randomized trials. ACE Inhibitor Myocardial Infarction Collaborative Group. Circulation 1998;97(22):2202–12.
| ^a^Flather MD, Yusuf S, Kober L, Pfeffer M, Hall A, Murray G, et al. Long-term ACE-inhibitor therapy in patients with heart failure or left-ventricular dysfunction: a systematic overview of data from individual patients. ACE-Inhibitor Myocardial Infarction Collaborative Group. Lancet 2000;355(9215):1575–81.
| ^a^Garg R, Yusuf S. Overview of randomized trials of angiotensin-converting enzyme inhibitors on mortality and morbidity in patients with heart failure. Collaborative Group on ACE Inhibitor Trials. JAMA 1995;273(18):1450–6.
Clinical Trial
| GISSI-3: effects of lisinopril and transdermal glyceryl trinitrate singly and together on 6-week mortality and ventricular function after acute myocardial infarction. Gruppo Italiano per lo Studio della Sopravvivenza nell'infarto Miocardico. Lancet 1994;343(8906):1115–22.
| ^a^Dagenais GR, Yusuf S, Bourassa MG, Yi Q, Bosch J, Lonn EM, et al. Effects of ramipril on coronary events in high-risk persons: results of the Heart Outcomes Prevention Evaluation Study. Circulation 2001;104(5):522–6.
| ^a^Lonn E, Roccafort R, Yi Q, Dagenais G, Sleight P, et al. Effect of long-term therapy with ramipril in high-risk women. J Am Coll Cardiol 2002;40:6930702.
| ^a^Yusuf S, Sleight P, Pogue J, Bosch J, Davies R, Dagenais G. Effects of an angiotensin-converting-enzyme inhibitor, ramipril, on cardiovascular events in high-risk patients. The Heart Outcomes Prevention Evaluation Study Investigators. N Engl J Med 2000;342(3):145–53.
2.05 Nitrates
Clinical Trial
| GISSI-3: effects of lisinopril and transdermal glyceryl trinitrate singly and together on 6-week mortality and ventricular function after acute myocardial infarction. Gruppo Italiano per lo Studio della Sopravvivenza nell'infarto Miocardico. Lancet 1994;343(8906):1115–22.
| ^a^ISIS-4: a randomised factorial trial assessing early oral captopril, oral mononitrate, and intravenous magnesium sulphate in 58,050 patients with suspected acute myocardial infarction. ISIS-4 (Fourth International Study of Infarct Survival) Collaborative Group. Lancet 1995;345(8951):669–85.
| Six-month effects of early treatment with lisinopril and transdermal glyceryl trinitrate singly and together withdrawn six weeks after acute myocardial infarction: the GISSI-3 trial. Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto Miocardico. J Am Coll Cardiol 1996;27(2):337–44.
2.07 Glycoprotein IIb/IIIa Drugs
Systematic Review
| ^a^Boersma E, Harrington RA, Moliterno DJ, White H, Theroux P, Van de Werf F, et al. Platelet glycoprotein IIb/IIIa inhibitors in acute coronary syndromes: a meta-analysis of all major randomised clinical trials. Lancet 2002;359(9302):189–98.
| Cho L, Topol EJ, Balog C, Foody JM, Booth JE, Cabot C, et al. Clinical benefit of glycoprotein IIb/IIIa blockade with Abciximab is independent of gender: pooled analysis from EPIC, EPILOG and EPISTENT trials. Evaluation of 7E3 for the Prevention of Ischemic Complications. Evaluation in Percutaneous Transluminal Coronary Angioplasty to Improve Long-Term Outcome with Abciximab GP IIb/IIIa blockade. Evaluation of Platelet IIb/IIIa Inhibitor for Stent. J Am Coll Cardiol 2000;36(2):381–6.
2.08 Thrombolysis
Systematic Review
| ^a^Indications for fibrinolytic therapy in suspected acute myocardial infarction: collaborative overview of early mortality and major morbidity results from all randomised trials of more than 1000 patients. Fibrinolytic Therapy Trialists' (FTT) Collaborative Group. Lancet 1994;343(8893):311–22.
Clinical Trial
| Stone GW, Grines CL, Browne KF, Marco J, Rothbaum D, O'Keefe J, et al. Comparison of in-hospital outcome in men versus women treated by either thrombolytic therapy or primary coronary angioplasty for acute myocardial infarction. Am J Cardiol 1995;75(15):987–92.
2.10 Clopidogrel
Clinical Trial
| ^a^Mehta SR, Yusuf S, Peters RJ, et al. Effects of pretreatment with clopidogrel and aspirin followed by long-term therapy in patients undergoing percutaneous coronary intervention: the PCI-CURE study. Lancet 2001;358(9281):527–33.
| ^a^Yusuf S, Zhao F, Mehta SR, et al. Effects of clopidogrel in addition to aspirin in patients with acute coronary syndromes without ST-segment elevation. N Engl J Med 2001;345(7):494–502
2.11 Percutaneous transluminal coronary angioplasty (PTCA) and stenting
Clinical Trial
| Stone GW, Grines CL, Browne KF, Marco J, Rothbaum D, O'Keefe J, et al. Comparison of in-hospital outcome in men versus women treated by either thrombolytic therapy or primary coronary angioplasty for acute myocardial infarction. Am J Cardiol 1995;75(15):987–92.
| ^a^First-year results of CABRI (Coronary Angioplasty versus Bypass Revascularisation Investigation). CABRI Trial Participants. Lancet 1995;346(8984):1179–84.
| Coronary angioplasty versus medical therapy for angina: the second Randomised Intervention Treatment of Angina (RITA-2) trial. RITA-2 trial participants. Lancet 1997;350(9076):461–8.
Prospective Cohort
| Bell MR, Grill DE, Garratt KN, Berger PB, Gersh BJ, Holmes DR, Jr. Long-term outcome of women compared with men after successful coronary angioplasty. Circulation 1995;91(12):2876–81.
| Bell MR, Holmes DR, Jr., Berger PB, Garratt KN, Bailey KR, Gersh BJ. The changing in-hospital mortality of women undergoing percutaneous transluminal coronary angioplasty. JAMA 1993;269(16):2091–5.
| ^a^Ellis SG, Roubin GS, King SB, 3^rd^, Douglas JS, Jr., Shaw RE, Stertzer SH, et al. In-hospital cardiac mortality after acute closure after coronary angioplasty: analysis of risk factors from 8,207 procedures. J Am Coll Cardiol 1988;11(2):211–6.
| ^a^Holmes DR, Jr., Holubkov R, Vlietstra RE, Kelsey SF, Reeder GS, Dorros G, et al. Comparison of complications during percutaneous transluminal coronary angioplasty from 1977 to 1981 and from 1985 to 1986: the National Heart, Lung, and Blood Institute Percutaneous Transluminal Coronary Angioplasty Registry. J Am Coll Cardiol 1988;12(5):1149–55.
| ^a^Kelsey SF, James M, Holubkov AL, Holubkov R, Cowley MJ, Detre KM. Results of percutaneous transluminal coronary angioplasty in women. 1985-1986 National Heart, Lung, and Blood Institute's Coronary Angioplasty Registry. Circulation 1993;87(3):720–7.
| ^a^Mehilli J, Kastrati A, Dirschinger J, Bollwein H, Neumann FJ, Schomig A. Differences in prognostic factors and outcomes between women and men undergoing coronary artery stenting. JAMA 2000;284(14):1799–805.
| Shaw LJ, Miller DD, Romeis JC, Kargl D, Younis LT, Chaitman BR. Gender differences in the noninvasive evaluation and management of patients with suspected coronary artery disease. Ann Intern Med 1994;120(7):559–66.
| ^a^Weintraub WS, Wenger NK, Kosinski AS, Douglas JS, Jr., Liberman HA, Morris DC, et al. Percutaneous transluminal coronary angioplasty in women compared with men. J Am Coll Cardiol 1994;24(1):81–90.
2.12 Coronary artery bypass surgery(CABG)
Clinical Trial
| ^a^First-year results of CABRI (Coronary Angioplasty versus Bypass Revascularisation Investigation). CABRI Trial Participants. Lancet 1995;346(8984):1179–84.
| ^a^Jacobs AK, Kelsey SF, Brooks MM, Faxon DP, Chaitman BR, Bittner V, et al. Better outcome for women compared with men undergoing coronary revascularization: a report from the bypass angioplasty revascularization investigation (BARI). Circulation 1998;98(13):1279–85.
Prospective Cohort
| ^a^Davis KB, Chaitman B, Ryan T, Bittner V, Kennedy JW. Comparison of 15-year survival for men and women after initial medical or surgical treatment for coronary artery disease: a CASS registry study. Coronary Artery Surgery Study. J Am Coll Cardiol 1995;25(5):1000–9.
3.01a Hypertension as a risk factor for CHD in women
Prosective Cohort
| ^a^Fiebach NH, Hebert PR, Stampfer MJ, Colditz GA, Willett WC, Rosner B, et al. A prospective study of high blood pressure and cardiovascular disease in women. Am J Epidemiol 1989;130(4):646–54.
| ^a^Kannel WB. Blood pressure as a cardiovascular risk factor: prevention and treatment. JAMA 1996;275(20):1571–6.
| Nielsen WB, Vestbo J, Jensen GB. Isolated systolic hypertension as a major risk factor for stroke and myocardial infarction and an unexploited source of cardiovascular prevention: a prospective population-based study. J Hum Hypertens 1995;9:175–80.
| Perlman JA, Wolf PH, Ray R, Lieberknecht G. Cardiovascular risk factors, premature heart disease, and all-cause mortality in a cohort of Northern California women. Am J Obstet Gynecol. 1988;158:1568–74.
3.01b Treatment of hypertension to reduce risk of CHD events in women
Systematic Review
| Gueyffier F, Boutitie F, Boissel JP, Pocock S, Coope J, Cutler J, et al. Effect of antihypertensive drug treatment on cardiovascular outcomes in women and men. A meta-analysis of individual patient data from randomized, controlled trials. The INDANA Investigators. Ann Intern Med 1997;126(10):761–7.
| ^a^aQuan A, Kerlikowske K, Gueyffier F, Boissel JP. Efficacy of treating hypertension in women. J Gen Intern Med 1999;14(12):718–29.
| ^a^Quan A, Kerlikowske K, Gueyffier F, Boissel JP. Pharmacotherapy for hypertension in women of different races. Cochrane Database Syst Rev 2000(3):CD002146.
Clinical Trial
| Wang J, Staessen JA, Gong L, Liu L. Chinese trial on isolated systolic hypertension in the elderly. The Systolic Hypertension in China (Syst-China) Collaborative Group. Arch Intern Med 2000;160:211–220.
3.02a Diabetes as a risk factor for CHD in women
Systematic Review
| ^a^Lee WL, Cheung AM, Cape D, Zinman B. Impact of diabetes on coronary artery disease in women and men: a meta-analysis of prospective studies. Diabetes Care 2000;23(7):962–8.
| Orchard TJ. The impact of gender and general risk factors on the occurrence of atherosclerotic vascular disease in non-insulin-dependent diabetes mellitus. Ann Med 1996;28(4):323–33.
Prospective Cohort
| ^a^Abbott RD, Donahue RP, Kannel WB, Wilson PW. The impact of diabetes on survival following myocardial infarction in men vs women. The Framingham Study. JAMA 1988;260(23):3456–60.
| ^a^Brand FN, Abbott RD, Kannel WB. Diabetes, intermittent claudication, and risk of cardiovascular events. The Framingham Study. Diabetes 1989;38(4):504–9.
| ^a^Donahue RP, Goldberg RJ, Chen Z, Gore JM, Alpert JS. The influence of sex and diabetes mellitus on survival following acute myocardial infarction: a community-wide perspective. J Clin Epidemiol 1993;46(3):245–52.
| ^a^Hu FB, Stampfer MJ, Solomon CG, Liu S, Willett WC, Speizer FE, et al. The impact of diabetes mellitus on mortality from all causes and coronary heart disease in women: 20 years of follow-up. Arch Intern Med *Kannel WB, D'Agostino RB, Wilson PW,
| ^a^Kannel WB, D'Agostino RB, Wilson PW, Belanger AJ, Gagnon DR. Diabetes, fibrinogen, and risk of cardiovascular disease: the Framingham experience. Am Heart J 1990;120(3):672–6.
| ^a^Malmberg K, Yusuf S, Gerstein HC, Brown J, Zhao F, Hunt D, et al. Impact of diabetes on long-term prognosis in patients with unstable angina and non-Q-wave myocardial infarction: results of the OASIS (Organization to Assess Strategies for Ischemic Syndromes) Registry. Circulation 2000;102(9):1014–9.
| ^a^Manson JE, Colditz GA, Stampfer MJ, Willett WC, Krolewski AS, Rosner B, et al. A prospective study of maturity-onset diabetes mellitus and risk of coronary heart disease and stroke in women. Arch Intern Med 1991;151(6):1141–7.
3.03a Hyperlipidemia as a risk factor for CHD in women
Systematic Review
| ^a^Austin MA, Hokanson JE, Edwards KL. Hypertriglyceridemia as a cardiovascular risk factor. Am J Cardiol 1998;81(4A):7B–12B.
| Craig WY, Neveux LM, Palomaki GE, Cleveland MM, Haddow JE. Lipoprotein(a) as a risk factor for ischemic heart disease:metaanalysis of prospective studies. Clin Chem 1998;44(11):2301–6.
| ^a^Hokanson JE, Austin MA. Plasma triglyceride level is a risk factor for cardiovascular disease independent of high-density lipoprotein cholesterol level: a meta-analysis of population-based prospective studies. J Cardiovasc Risk 1996;3(2):213–9.
| Jacobs D, Blackburn H, Higgins M, Reed D, Iso H, McMillan G, et al. Report of the Conference on Low Blood Cholesterol: Mortality Associations. Circulation 1992;86(3):1046–60.
| Manolio TA, Pearson TA, Wenger NK, Barrett-Connor E, Payne GH, Harlan WR. Cholesterol and heart disease in older persons and women. Review of an NHLBI workshop. Ann Epidemiol 1992;2(1–2):161–76.
3.03b Treatment of hyperlipidemia to reduce risk of CHD events in women
Systematic Review
| Byington RP, Jukema JW, Salonen JT, Pitt B, Bruschke AV, Hoen H, et al. Reduction in cardiovascular events during pravastatin therapy. Pooled analysis of clinical events of the Pravastatin Atherosclerosis Intervention Program. Circulation 1995;92(9):2419–25.
| Buchwald H, Campos CT, Boen JR, Nguyen P, Williams SE, Lau J, et al. Gender-based mortality follow-up from the Program on the Surgical Control of the Hyperlipidemias (POSCH) and meta-analysis of lipid intervention trials. Women in POSCH and other lipid trials. Ann Surg 1996;224(4):486–98; discussion 498–500.
| ^a^LaRosa JC, He J, Vupputuri S. Effect of statins on risk of coronary disease: a meta-analysis of randomized controlled trials. JAMA 1999;282(24):2340–6.
| Walsh JM, Grady D. Treatment of hyperlipidemia in women. JAMA 1995;274(14):1152–8.
Clinical Trial
| ^a^MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,538 high-risk individuals: a randomized placebo controlled trial. Heart Protection Study Collaborative Group. Lancet 2002; 360:7–22.
| ^a^Miettinen TA, Pyorala K, Olsson AG, Musliner TA, Cook TJ, Faergeman O, et al. Cholesterol-lowering therapy in women and elderly patients with myocardial infarction or angina pectoris: findings from the Scandinavian Simvastatin Survival Study (4S). Circulation 1997;96(12):4211–8.
3.04a Elevated homocysteine as a risk factor for CHD in women
Systematic Review
| Boushey CJ, Beresford SA, Omenn GS, Motulsky AG. A quantitative assessment of plasma homocysteine as a risk factor for vascular disease. Probable benefits of increasing folic acid intakes. JAMA 1995;274(13):1049–57.
3.05a C-reactive protein as a risk factor for CHD events in women
Prospective Cohort
| ^a^Ridker PM, Buring JE, Shih J, Matias M, Hennekens CH. Prospective study of C-reactive protein and the risk of future cardiovascular events among apparently healthy women. Circulation 1998;98(8):731–3.
| ^a^Ridker PM, Hennekens CH, Buring JE, Rifai N. C-reactive protein and other markers of inflammation in the prediction of cardiovascular disease in women. N Engl J Med 2000;342(12):836–43.
3.06a Smoking as a risk factor for CHD in women
Prospective Cohort
| ^a^Freund KM, Belanger AJ, D'Agostino RB, Kannel WB. The health risks of smoking. The Framingham Study: 34 years of follow-up. Ann Epidemiol 1993;3(4):417–24.
| ^a^Kannel WB, D'Agostini RB, Belanger AJ. Fibrinogen, Cigarette smoking, and risk of cardiovascular disease: insights from the Framingham Study.” Am Heart J 1987;113:1006–1010.
| ^a^Kawachi I, Colditz GA, Stampfer MJ, Willett WC, Manson JE, Rosner B, et al. Smoking cessation and time course of decreased risks of coronary heart disease in middle-aged women. Arch Intern Med 1994;154(2):169–75.
| ^a^LaCroix AZ, Lang J, Scherr P, Wallace RB, Cornoni-Huntley J, Berkman L, et al. Smoking and mortality among older men and women in three communities. N Engl J Med 1991;324(23):1619–25.
| ^a^Njolstad I, Arnesen E, Lund-Larsen PG. Smoking, serum lipids, blood pressure, and sex differences in myocardial infarction. A 12-year follow-up of the Finnmark Study. Circulation 1996;93(3):450–6.
| ^a^Paganini-Hill A, Hsu G. Smoking and mortality among residents of a California retirement community. Am J Public Health 1994;84(6):992–5.
| ^a^Prescott E, Hippe M, Schnohr P, Hein HO, Vestbo J. Smoking and risk of myocardial infarction in women and men: longitudinal population study. BMJ 1998;316(7137):1043–7.
| ^a^Willett WC, Green A, Stampfer MJ, Speizer FE, Colditz GA, Rosner B, et al. Relative and absolute excess risks of coronary heart disease among women who smoke cigarettes. N Engl J Med 1987;317(21):1303–9.
3.06b Smoking cessation to reduce risk of CHD in women
Prospective Cohort
| ^a^Kawachi I, Colditz GA, Stampfer MJ, Willett WC, Manson JE, Rosner B, et al. Smoking cessation in relation to total mortality rates in women. A prospective cohort study. Ann Intern Med 1993;119(10):992–1000.
| ^a^Kawachi I, Colditz GA, Stampfer MJ, Willett WC, Manson JE, Rosner B, et al. Smoking cessation and time course of decreased risks of coronary heart disease in middle-aged women. Arch Intern Med 1994;154(2):169–75.
| ^a^LaCroix AZ, Lang J, Scherr P, Wallace RB, Cornoni-Huntley J, Berkman L, et al. Smoking and mortality among older men and women in three communities. N Engl J Med 1991;324(23):1619–25.
| ^a^Njolstad I, Arnesen E, Lund-Larsen PG. Smoking, serum lipids, blood pressure, and sex differences in myocardial infarction. A 12-year follow-up of the Finnmark Study. Circulation 1996;93(3):450–6.
| ^a^Omenn GS, Anderson KW, Kronmal RA, Vlietstra RE. The temporal pattern of reduction of mortality risk after smoking cessation. Am J Prev Med 1990;6(5):251–7.
| ^a^Paganini-Hill A, Hsu G. Smoking and mortality among residents of a California retirement community. Am J Public Health 1994;84(6):992–5.
| ^a^Prescott E, Hippe M, Schnohr P, Hein HO, Vestbo J. Smoking and risk of myocardial infarction in women and men: longitudinal population study. BMJ 1998;316(7137):1043–7.
| ^a^Willett WC, Green A, Stampfer MJ, Speizer FE, Colditz GA, Rosner B, et al. Relative and absolute excess risks of coronary heart disease among women who smoke cigarettes. N Engl J Med 1987;317(21):1303–9.
Systematic Review
| ^a^Wilson K, Gibson N, Willan A, Cook D. Effect of smoking cessation on mortality after myocardial infarction: meta-analysis of cohort studies. Arch Intern Med 2000;160(7):939–44.
3.07a Obesity as a risk factor for CHD in women
Prospective Cohort
| ^a^Field AE, Coakley EH, Must A, Spadano JL, Laird N, Dietz WH, et al. Impact of overweight on the risk of developing common chronic diseases during a 10-year period. Arch Intern Med 2001;161(13):1581–6.
| ^a^Folsom AR, Stevens J, Schreiner PJ, McGovern PG. Body mass index, waist/hip ratio, and coronary heart disease incidence in African Americans and whites. Atherosclerosis Risk in Communities Study Investigators. Am J Epidemiol 1998;148(12):1187–94.
| ^a^Folsom AR, Burke GL, Byers CL, Hutchinson RG, Heiss G, Flack JM, et al. Implications of obesity for cardiovascular disease in blacks: the CARDIA and ARIC studies. Am J Clin Nutr 1991;53(6 Suppl):1604S-1611S.
| ^a^Folsom AR, French SA, Zheng W, Baxter JE, Jeffery RW. Weight variability and mortality: the Iowa Women's Health Study. Int J Obes Relat Metab Disord 1996;20(8):704–9.
| ^a^Folsom AR, Kushi LH, Anderson KE, Mink PJ, Olson JE, Hong CP, et al. Associations of general and abdominal obesity with multiple health outcomes in older women: the Iowa Women's Health Study. Arch Intern Med 2000;160(14):2117–28.
| ^a^French SA, Folsom AR, Jeffery RW, Zheng W, Mink PJ, Baxter JE. Weight variability and incident disease in older women: the Iowa Women's Health Study. Int J Obes Relat Metab Disord 1997;21(3):217–23.
| ^a^Harris T, Cook EF, Garrison R, Higgins M, Kannel W, Goldman L. Body mass index and mortality among nonsmoking older persons. The Framingham Heart Study. JAMA 1988;259(10):1520–4.
| ^a^Kannel WB, Cupples LA, Ramaswami R, Stokes J, 3^rd^, Kreger BE, Higgins M. Regional obesity and risk of cardiovascular disease; the Framingham Study. J Clin Epidemiol 1991;44(2):183–90.
| ^a^Manson JE, Willett WC, Stampfer MJ, Colditz GA, Hunter DJ, Hankinson SE, et al. Body weight and mortality among women. N Engl J Med 1995;333(11):677–85.
| ^a^Manson JE, Colditz GA, Stampfer MJ, Willett WC, Rosner B, Monson RR, et al. A prospective study of obesity and risk of coronary heart disease in women. N Engl J Med 1990;322(13):882–9.
| ^a^Rexrode KM, Carey VJ, Hennekens CH, Walters EE, Colditz GA, Stampfer MJ, et al. Abdominal adiposity and coronary heart disease in women. JAMA 1998;280(21):1843–8.
| ^a^Willett WC, Manson JE, Stampfer MJ, Colditz GA, Rosner B, Speizer FE, et al. Weight, weight change, and coronary heart disease in women. Risk within the ‘normal’ weight range. JAMA 1995;273(6):461–5.
3.08a Inactivity as a risk factor for CHD in women
Prospective Cohort
| ^a^Blair SN, Kohl HW, 3^rd^, Paffenbarger RS, Jr., Clark DG, Cooper KH, Gibbons LW. Physical fitness and all-cause mortality. A prospective study of healthy men and women. JAMA 1989;262(17):2395–401.
| ^a^Lee IM, Rexrode KM, Cook NR, Manson JE, Buring JE. Physical activity and coronary heart disease in women: is “no pain, no gain” passe? JAMA 2001;285(11):1447–54.
| ^a^Manson JE, Hu FB, Rich-Edwards JW, Colditz GA, Stampfer MJ, Willett WC, et al. A prospective study of walking as compared with vigorous exercise in the prevention of coronary heart disease in women. N Engl J Med 1999;341(9):650–8.
| ^a^Rockhill B, Willett WC, Manson JE, Leitzmann MF, Stampfer MJ, Hunter DJ, et al. Physical activity and mortality: a prospective study among women. Am J Public Health 2001;91(4):578–83.
| ^a^Sherman SE, D'Agostino RB, Cobb JL, Kannel WB. Physical activity and mortality in women in the Framingham Heart Study. Am Heart J 1994;128(5):879–84.
3.09 Age as a risk for CHD events in women
Systematic Review
| Pocock SJ, McCormack V, Gueyffier F, Boutitie F, Fagard RH, Boissel JP. A score for predicting risk of death from cardiovascular disease in adults with raised blood pressure, based on individual patient data from randomised controlled trials. BMJ 2001;323(7304):75–81.
Prospective Cohort
| ^a^D'Agostino RB, Sr., Grundy S, Sullivan LM, Wilson P. Validation of the Framingham coronary heart disease prediction scores: results of a multiple ethnic groups investigation. JAMA 2001;286(2):180–7.
| ^a^Lerner DJ, Kannel WB. Patterns of coronary heart disease morbidity and mortality in the sexes: a 26-year follow-up of the Framingham population. Am Heart J 1986;111(2):383–90..
3.10 Age at menopause and risk for CHD
Prospective Cohort
| ^a^Cooper GS, Sandler DP. Age at natural menopause and mortality. Ann Epidemiol 1998;8(4):229–35.
| ^a^Hu FB, Grodstein F, Hennekens CH, Colditz GA, Johnson M, Manson JE, et al. Age at natural menopause and risk of cardiovascular disease. Arch Intern Med 1999;159(10):1061–6.
| ^a^van der Schouw YT, van der Graaf Y, Steyerberg EW, Eijkemans JC, Banga JD. Age at menopause as a risk factor for cardiovascular mortality. Lancet 1996;347(9003):714–8.
3.11 Ethnicity
Prospective Cohort
| ^a^Keil JE, Sutherland SE, Knapp RG, Lackland DT, Gazes PC, Tyroler HA. Mortality rates and risk factors for coronary disease in black as compared with white men and women. N Engl J Med 1993;329(2):73–8.
| Roig E, Castaner A, Simmons B, Patel R, Ford E, Cooper R. In-hospital mortality rates from acute myocardial infarction by race in U.S. hospitals: findings from the National Hospital Discharge Survey. Circulation 1987;76(2):280–8.
| White AD, Rosamond WD, Chambless LE, Thomas N, Conwill D, Cooper LS, et al. Sex and race differences in short-term prognosis after acute coronary heart disease events: the Atherosclerosis Risk In Communities (ARIC) study. Am Heart J 1999;138(3 Pt 1):540–8.
3.12 Socioeconomic status and risk for CHD
Prospective Cohort
| ^a^Capewell S, MacIntyre K, Stewart S, Chalmers JW, Boyd J, Finlayson A, et al. Age, sex, and social trends in out-of-hospital cardiac deaths in Scotland 1986-95: a retrospective cohort study. Lancet 2001;358(9289):1213–7.
| ^a^Keil JE, Sutherland SE, Knapp RG, Lackland DT, Gazes PC, Tyroler HA. Mortality rates and risk factors for coronary disease in black as compared with white men and women. N Engl J Med 1993;329(2):73–8.
| ^a^Morrison, M. Woodward, W. Leslie and H. Tunstall-Pedoe (1997) “Effect of socioeconomic group on incidence 3 of, management of, and survival after myocardial infarction and coronary death: analysis of community coronary event register” BMJ 314 541–6.
| ^a^Salomaa V, Miettinen H, Niemela M, Ketonen M, Mahonen M, Immonen-Raiha P, et al. Relation of socioeconomic position to the case fatality, prognosis and treatment of myocardial infarction events; the FINMONICA MI Register Study. J Epidemiol Community Health 2001;55(7):475–82.
4.0 Differences in utilization between women and men
Systematic Review
| Klungel OH, deBoer A, Paes A, Seidell JC, Bakker A. Sex differences in the pharmacological treatment of hypertension: a review of population-based studies. J Hypertension 1997;15:591–600.
Cross-sectional
| ^a^Ayanian JZ, Epstein AM. Differences in the use of procedures between women and men hospitalized for coronary heart disease. N Engl J Med 1991;325:221–5.
| Battleman DS, Callhan M. Gender differences in utilization of exercise treadmill testing: a claims-based analysis. J Healthcare Quality 2001;23:38–41.
| Bergelson BA, Tommaso CL. Gender difference in clinical evaluation and triage in coronary artery disease. Chest 1995;108:1510–13.
| Bickell NA, Pieper KS, Lee KL, Mark DB, Glower DD, et al. Referral patterns for coronary artery disease treatment: gender bias or good clinical judgment? Ann Int Med 1992;116:791–797.
| ^a^Chandra NC, Ziegelstein RC, Rogers WJ, Tiefenbrunn AJ, Gore JM, et al. Observations of the treatment of women in the United States with myocardial infarction. Arch Intern Med 1998;158:981–988.
| ^a^Chiriboga DE, Yarzebski J, Goldberg RJ, Chen Z, Gurwitz J, Gore JM, et al. A community-wide perspective of gender differences and temporal trends in the use of diagnostic and revascularization procedures for acute myocardial infarction. Am J Cardiol 1993;71(4):268–73.
| Clarke KW, Gray D, Keating NA, Hampton JR. Do women with acute myocardial infarction receive the same treatment as men? BMJ 1994;309:563–566.
| ^a^D'Hoore W, Sicotte C, Tilquin C. Sex bias in the management of coronary artery disease in Quebec. Am J Public Health 1994;84(6):1013–5Bergelson BA, Tommaso CL. Gender difference in clinical evaluation and triage in coronary artery disease. Chest 1995;108:1510–13.
| ^a^Davis KB, Chaitman B, Ryan T, Bittner V, Kennedy JW. Comparison of 15-year survival for men and women after initial medical or surgical treatment for coronary artery disease: a CASS registry study. Coronary Artery Surgery Study. J Am Coll Cardiol 1995;25(5):1000–9.
| ^a^Giacomini MK. Gender and ethnic differences in hospital-based procedure utilization in California. Arch Intern Med. 1996;156:1217–1224.
| ^a^Giles TD, Fisher MB, Rush JE. Lisinopril and captopril in the treatment of heart failure in older patients. Comparison of a long- and short-acting angiotensin-converting enzyme inhibitor. Am J Med 1988;85(3B):44–7.
| Goldberg KC, Hartz AJ, Jacobsen SJ, Krakauer H, Rimm AA. Racial and community factors influencing coronary artery bypass graft surgery rates for all 1986 Medicare patients. JAMA 1992;267(11):1473–7.
| ^a^Jaglal SB, Goel V, Naylor CD. Sex differences in the use of invasive coronary procedures in Ontario. Can J Cardiol 1994;10(2):239–44.
| ^a^Johnson PA, Goldman L, Orav J, Zhou L, Garcia T, et al. Gender differences in the management of acute chest pain. Support for the “Yentl Syndrome.” J Gen Intern Med 1996;11:209–217.
| ^a^Krumholz HM, Douglas PS, Lauer MS, Pasternak RC. Selection of patients for coronary angiography and coronary revascularization early after myocardial infarction: is there evidence for a gender bias? Ann Intern Med 1992;116(10):785–90.
| ^a^Kudenchuk PJ, Maynard C, Martin JS, Wirkus M, Weaver WD. Comparison of presentation, treatment, and outcome of acute myocardial infarction in men versus women (The Myocardial Infarction Triage and Intervention Registry). Am J Cardiol 1996;78:9–14.
| Mageed A, Moser K, Maxwell R. Age, sex and practice variations in the use of statins in general practice in England and Wales. J Publ Hlth Med 2000;22:275–279.
| Magrini N, Elinarson T, Vaccheri A, McManus P, Montanaro N, Bergman U. Use of lipid-lowering drugs from 1990 to 1994: an international comparison among Australia, Finland, Italy (Emilia Romagna Region), Norway and Sweden. Eur J Clin Pharmacol 1991;53:185–189.
| Maynard C, Althouse R, Cerqueira M, Olsufka M, Kennedy JW. Underutilization of thrombolytic therapy in eligible women with acute myocardial infarction. Am J Cardiol 1991;68:529–530.
| ^a^Maynard C, Litwin PE, Martin JS, Weaver WD. Gender differences in the treatment and outcome of acute myocardial infarction. Arch Intern Med 1992;152:972–976.
| ^a^Miller TD, Roger VL, Hodge DO, Hopfenspirger MR, Bailey KR, et al. Gender differences and temporal trends in Clinical Characteristics, stress test results and use of invasive procedures in patients undergoing evaluation for coronary artery disease. J am Coll Cardiol 2001;38:690–7.
| ^a^Pagley PR, Yarzebski J, Goldberg R, Chen Z, Chiriboga D, et al. Gender differences in the treatment of patients with acute myocardial infarction. Arch Intern Med 1993;153:625–629.
| ^a^Petticrew M, McKee M, Jones J. Coronary artery surgery: are women discriminated against? BMJ 1993;306(6886):1164–6.
| ^a^Pfeffer Ma, Moye LA, Braunwald E, Basta L, Brown EJ, et al. Selection bias in the use of thrombolytic therapy in acute myocardial infarction. JAMA 1991;266:528–532.
| ^a^Ramsey DJ, Goff DC, Wear ML, Labarthe DR, Nichaman MZ. Sex and ethnic differences in use of myocardial revascularization procedures in Mexican Americans and non-Hispanic whites: the Corpus Christi Heart Project. J Clin Epidemiol 1997;50(5):603–9.
| ^a^Roger VL, Farkouh ME, Weston SA, Reeder GS, Jacobsen SJ, et al. Sex differences in evaluation and outcome of unstable angina. JAMA 2000;283:646–652.
| ^a^Rojas-Fernandez CH, Kephart GC, Sketris IS, Kass K. Underuse of acetylsalicylic acid in individuals with myocardial infarction, ischemic heart disease or stroke: data from the 1995 population-based Nova Scotia Health Survey. Can J Cardiol 1999;15(3):291–6.
| ^a^Shahar E, Folsom AR, Romm FJ, Bisgard KM, Metcalf PA, et al. Patterns of aspirin use in middle-aged adults: the Atherosclerosis Risk in Communities (ARIC) Study. Am Heart J 1996;131:915–22.
| Shaw LJ, Miller DD, Romeis JC, Kargl D, Younis LT, Chaitman BR. Gender differences in the noninvasive evaluation and management of patients with suspected coronary artery disease. Ann Intern Med 1994;120(7):559–66.
| Sketris IS, Kephart GC, Hicks VA, Hubbard EJ, Brown MG, et al. Prescribing patterns of antilipemic drugs and prevalence of hypercholesterolemia in the Nova Scotia population more than 65 years old. Ann Pharmacother 1995;29:576–81.
| ^a^Steingart RM, Packer M, Hamm P, Coglianese ME, Gersh B, et al. Sex differences in the management of coronary artery disease. N Engl J Med 1991;325:226–230.
| ^a^Strauss R, Pfeifer C, Muhlberger V, Ulmer H, Pfeiffer KP. Effects of morbidity, age, gender and region on percutaneous transluminal coronary angioplasty (PTCA) utilisation. Public Health 1999;113(2):79–87.
| Tsuyuki RT, Teo KK, Ikuta RM, Bay KS, Greenwood PV, Montague TJ. Mortality risk and patterns of practice in 2,070 patients with acute myocardial infarction, 1987-92. Chest 1994;105:1687–92.
| Weaver WD, White HD, Wilcox RG, Aylward PE, Morris D, Guerci A, et al. Comparisons of characteristics and outcomes among women and men with acute myocardial infarction treated with thrombolytic therapy. GUSTO-I investigators. JAMA 1996;275(10):777–82.
| ^a^Yarzebski J, Col N, Pagley P, Savageau J, Gore J, Goldberg R. Gender differences and factors associated with the receipt of thrombolytic therapy in patients with acute myocardial infarction: a community-wide perspective. Am Heart J 1996;131(1):43–50.

a indicates “good quality” article